# Methods

The methods for this review follow the methods suggested in the Agency for Healthcare Research and Quality (AHRQ) “Methods Guide for Effectiveness and Comparative Effectiveness Reviews” (www.effectivehealthcare.ahrq.gov/methodsguide.cfm).

## Topic Refinement and Review Protocol

A member of the American Psychological Association nominated the topic of posttraumatic stress disorder (PTSD) in adults; the association aims to use high-quality evidence syntheses to inform guideline development. During the topic development and refinement processes, we engaged in a public process to develop a draft and final protocol for the comparative effectiveness review (CER) process. We generated an analytic framework, preliminary Key Questions (KQs), and preliminary inclusion/exclusion criteria in the form of PICOTS (populations, interventions, comparators, outcomes, timing, settings). The processes were guided by the information provided by the topic nominator, a scan of the literature, methods and content experts, and Key Informants. We worked with six Key Informants during the topic refinement, three of whom were also subsequently members of our Technical Expert Panel (TEP) for this report. Key Informants and TEP members participated in conference calls and discussions through email to review the analytic framework, KQs, and PICOTS; discuss the preliminary assessment of the literature; provide input on the information and categories included in evidence tables; and provide input on the data analysis plan.

Our KQs were posted for public comment on AHRQ’s Effective Health Care Web site from September 6, 2011, through October 4, 2011, and were revised as needed after review of the comments and discussion with the TEP, primarily for clarity and readability. We then drafted a protocol for this CER that was posted on AHRQ’s Effective Health Care Web site on December 20, 2011.

## Literature Search Strategy

### Search Strategy

To identify articles relevant to each KQ, we searched MEDLINE^®^, the Cochrane Library, the Published International Literature on Traumatic Stress (PILOTS) database, International Pharmaceutical Abstracts, CINAHL^®^, PsycINFO^®^, Web of Science, and EMBASE. The full search strategy is presented in Appendix B. We used either medical subject headings (MeSH) or major headings as search terms when available or key words when appropriate, focusing on terms to describe the relevant population and interventions of interest. We reviewed our search strategy with the TEP and incorporated their input into our search strategy. Searches were run by an experienced information scientist/Evidence-based Practice Center (EPC) librarian and were peer-reviewed by another information scientist/EPC librarian.

We limited the electronic searches to English-language and human-only studies. We searched sources for publications from January 1, 1980, to May 24, 2012. The start date was selected based on the introduction of the definition of PTSD as a clinical entity with the publication of DSM-III,27 the earliest publication date of relevant studies found in previous systematic reviews, and expert opinion regarding when the earliest literature on this topic was published.

We manually searched reference lists of pertinent reviews, included trials, and background articles on this topic to look for any relevant citations that our searches might have missed. We imported all citations into an EndNote^®^ X4 electronic database.

We searched for unpublished studies relevant to this review using ClinicalTrials.gov, the Web site for the Food and Drug Administration, and the World Health Organization’s International Clinical Trials Registry Platform. In addition, the Scientific Resource Center requested scientific information packets (SIPs) from the relevant pharmaceutical companies, asking for any unpublished studies or data relevant for this CER. We received seven SIPs (from Alkermes, Inc., Forest Laboratories, Janssen Pharmaceuticals, Jazz Pharmaceuticals, Sanofi-Aventis, Valeant Pharmaceuticals International, and Validus Pharmaceuticals); from these materials, we identified three eligible published studies and no eligible unpublished studies. To include information from SIPs, we required that studies meet all inclusion criteria and contain enough information on research methods to be able to assess risk of bias.

### Inclusion and Exclusion Criteria

We developed eligibility (inclusion and exclusion) criteria with respect to PICOTS, and study designs and durations for each KQ (Table 3). We did not include studies of complementary and alternative medicine interventions in this review. Due to the already large scope of this review, and time and resources, it was important that we focus on the interventions of greatest interest to stakeholders. During the topic development and refinement process, complementary and alternative interventions were considered, and the general consensus was that such interventions were of less interest than psychological and pharmacological interventions, and less likely to have sufficient evidence for synthesis. Using clinical expert and TEP input about the minimal time required for an adequate therapeutic trial (i.e., the treatment duration needed to show benefits), we required studies to be at least 4 weeks in duration from the time of group assignment.

Table 3 Eligibility criteria

Category | Inclusion | Exclusion
Population | Adults with PTSD based on “Diagnostic and Statistical Manual of Mental Disorders” criteria | - Children; - People at risk of developing PTSD; - People with subsyndromal PTSD
Interventions | Psychological interventions including:; - Brief eclectic psychotherapy; - Cognitive-behavioral therapy, such as cognitive restructuring, cognitive processing therapy, exposure-based therapies, and coping skills therapy (may include components such as stress inoculation training, assertiveness training, biofeedback [including brainwave neurofeedback], or relaxation training); - Eye movement desensitization and reprocessing; - Hypnosis or hypnotherapy; - Interpersonal therapy; - Psychodynamic therapy; Pharmacological interventions including:; - Selective serotonin reuptake inhibitors (SSRIs: citalopram, escitalopram, fluoxetine, fluvoxamine, paroxetine, and sertraline); - Serotonin and norepinephrine reuptake inhibitors (SNRIs: desvenlafaxine, venlafaxine, and duloxetine); - Other second-generation antidepressants (bupropion, mirtazapine, nefazodone, and trazodone); - Tricyclic antidepressants (imipramine, amitriptyline, and desipramine); - Alpha blockers (prazosin); - Atypical antipsychotics (olanzapine and risperidone); - Benzodiazepines (alprazolam, diazepam, lorazepam, and clonazepam); - Anticonvulsants/mood stabilizers (topiramate, tiagabine, lamotrigine, carbamazepine, and divalproex) | - Complementary and alternative medicine approaches; - Psychological or pharmacological interventions not listed as included
Comparators | By KQ:; - KQ 1: Psychological interventions listed above compared with one another or with waitlist assignment, usual care (as defined by the study), no intervention, or sham; - KQ 2: Pharmacological interventions listed above compared with one another or to placebo; - KQ 3: Psychological interventions listed above compared with pharmacologic interventions listed above; - KQ 4: Combinations of psychological and pharmacological interventions compared with either one alone (placebo, waitlist assignment, usual care, no intervention, or sham may be used in conjunction with the monotherapy arm); - KQs 5 and 6: All studies including the comparators for KQs 1 through 4 will be eligible
Outcomes | - PTSD symptom reduction, both assessor-rated and self-reported: as measured by the Clinician-Administered PTSD Scale (CAPS), and previous versions of the CAPS, such as the Clinician-Administered PTSD Scale Part 2 (CAPS-2); the Impact of Event Scale (IES); the Impact of Event Scale–Revised (IES-R); the Modified PTSD Symptom Scale (MPSS-SR); the self-rated PTSD symptoms Checklist (PCL); the PTSD Symptom Scale–Interview (PSS-I); the PTSD Symptom Scale–Self-report Version (PSS-SR); or the Structured Interview for PTSD (SI-PTSD); - Prevention or reduction of comorbid medical or psychiatric conditions (e.g., coronary artery disease; depressive symptoms; anxiety symptoms; suicidal ideation, plans, or attempts; and substance use, abuse, or dependence); - Remission (no longer having symptoms); - Loss of PTSD diagnosis; - Quality of life^a^; - Disability or functional impairment^a^; - Return to work or return to active duty; - Adverse events: overall adverse events, withdrawals due to adverse events, and specific adverse events (including, but not limited to, disturbed sleep, increased agitation, sedation, weight gain, metabolic side effects, and mortality)
Publication language | English | All other languages
Time period | 1980 to present; searches to be updated after draft report goes out for peer review
Time period | 1980 to present; searches to be updated after draft report goes out for peer review
Settings | - Outpatient and inpatient primary care or specialty mental health care settings; - Community settings (e.g., churches, community health centers, rape crisis centers); - Military settings
Geography | No limits
Study duration | At least 4 weeks from the time of group assignment for trials
Admissible evidence for KQs 1 through 5 | Original research Randomized controlled trials with no sample size limit For KQ 5 (focused on whether any treatment approaches for PTSD are more effective than others for victims of particular types of trauma), information within the trials meeting inclusion criteria for KQs 1 through 4 | - Observational studies; - Systematic reviews and meta-analyses; - Nonsystematic reviews; - Editorials; - Letters to the editor; - Articles rated as high risk of bias^b^
Admissible evidence for KQ 6 (adverse effects) | - Data from trials included in KQs 1 through 4 that reported adverse effects; - Nonrandomized controlled trials of any sample size; - Prospective cohort studies with an eligible comparison group with a sample size of at least 500; - Case-control studies with a sample size of at least 500 | - Case series; - Case reports; - Systematic reviews and meta-analyses; - Nonsystematic reviews; - Editorials; - Letters to the editor; - Articles rated as high risk of bias^b^; - Studies with historical, rather than concurrent, control groups; - Pre/post studies without a separate control group

Observational studies that compare the effectiveness of various treatments for PTSD have a very high risk of selection bias and confounding. We feel that the results should not be used to make decisions about efficacy/effectiveness. For KQ 6, we chose a sample size cutoff of 500 for prospective cohort studies and case-control studies for several reasons: (1) our topic refinement process found a large number of randomized controlled trials in this field and we weighed the tradeoffs between increasing comprehensiveness by reviewing all possible observational studies that present harms and the decreased quality that may occur from increased risk of bias, as well as considering our resource and time constraints; (2) to supplement the trial literature, large observational studies with the lowest potential risk of bias were eligible for inclusion; and (3) our TEP supported this approach.

### Study Selection

Two trained members of the research team independently reviewed all titles and abstracts (identified through searches) for eligibility against our inclusion/exclusion criteria. Studies marked for possible inclusion by either reviewer underwent a full-text review. For studies that lacked adequate information to determine inclusion or exclusion, we retrieved the full text and then made the determination in that phase.

We retrieved the full text of all articles included during the title and abstract review phase. Two trained members of the research team independently reviewed each full-text article for inclusion or exclusion based on the eligibility criteria described above. If both reviewers agreed that a study did not meet the eligibility criteria, we excluded it. If the reviewers disagreed, they resolved conflicts by discussion and consensus or by consulting a third senior member of the review team.

All results in both review stages were tracked in an EndNote® database. We recorded the principal reason that each excluded full-text publication did not satisfy the eligibility criteria (Appendix C).

### Data Extraction

For studies that met our inclusion criteria, we extracted important information into evidence tables. We designed and used structured data extraction forms to gather pertinent information from each article, including characteristics of study populations, settings, interventions, comparators, study designs, methods, and results. Trained reviewers extracted the relevant data from each included article into the evidence tables. All data abstractions were reviewed for completeness and accuracy by a second member of the team. We recorded intention-to-treat results if available. All data abstraction was performed using Microsoft Excel® software. Evidence tables containing all extracted data of included studies are presented in Appendix D, organized by characteristics of included studies, characteristics of study populations, description of interventions, results for benefits, subgroup analyses, and results for harms. Within each of these evidence tables, studies are ordered alphabetically by the last name of the first author.

## Risk of Bias Assessment of Individual Studies

To assess the risk of bias (i.e., internal validity) of studies, we used predefined criteria based on the AHRQ “Methods Guide for Comparative Effectiveness Reviews,”28 including questions to assess selection bias, confounding, performance bias, detection bias, and attrition bias (i.e., those about adequacy of randomization, allocation concealment, similarity of groups at baseline, masking, attrition, whether intention-to-treat analysis was used, method of handling dropouts and missing data, validity and reliability of outcome measures, and treatment fidelity). Appendix E provides the 12 specific questions used for evaluating the risk of bias of all included studies. It also includes a table showing the responses to these questions and risk of bias ratings for each study and then an explanation of the rationale for all high risk of bias ratings.

In general terms, results from a study assessed as having low risk of bias are considered to be valid. A study with moderate risk of bias is susceptible to some risk of bias but probably not enough to invalidate its results. A study assessed as high risk of bias has significant risk of bias (e.g., stemming from serious issues in design, conduct, or analysis) that may invalidate its results. We determined the risk of bias rating via appraisal of responses to all 12 questions assessing the various types of bias listed above. We did not use a quantitative approach (e.g., adding up how many favorable or unfavorable responses were given), but we did require favorable responses to at least 10 questions to give a low risk of bias rating, with any unfavorable responses being of relatively minor concern (e.g., lack of provider masking in studies of psychological interventions, which is generally not considered possible).

We gave high risk of bias ratings to studies that we determined to have a fatal flaw (defined as a methodological shortcoming that leads to a very high risk of bias) in one or more categories based on our qualitative assessment. Reasons for high risk of bias ratings included high risk of selection bias due to inadequate method of randomization (e.g., alternating) and resulting baseline differences between groups with no subsequent approach to handle potential confounders, attrition ≥40 percent or differential attrition ≥30 percent, risk of attrition bias (attrition over 20% or differential attrition over 15%) along with inadequate handling of missing data (e.g., completers analysis with nothing done to address missing data), and other combinations of multiple risk of bias concerns. Appendix E provides our rationale for each high risk of bias rating.

The majority of studies that we rated as high risk of bias had numerous problems. On average, they received unfavorable responses to 8 of our specific risk of bias assessment questions. All but one study rated as high risk of bias had unfavorable responses to 5 or more questions. For that study, risk of attrition bias was very high (approximately 50% attrition) and we had concerns about selection bias due to baseline differences between groups.29 The most common methodological shortcomings contributing to high risk of bias ratings were high rates of attrition or differential attrition, inadequate methods used to handle missing data, and lack of intention-to-treat analysis.

Two independent reviewers assessed the risk of bias for each study; one of the two reviewers was always an experienced, senior investigator. Disagreements between the two reviewers were resolved by discussion and consensus or by consulting a third member of the team. We excluded studies deemed high risk of bias from our main data synthesis and main analyses; we included them only in sensitivity analyses.

## Data Synthesis

Because of controversy about whether existing evidence supports the efficacy of many of the included interventions, we decided to focus first on assessing which interventions have evidence of efficacy—by evaluating placebo-controlled studies for the pharmacotherapies and by evaluating waitlist, usual care, or placebo-controlled studies of the psychotherapies (i.e., studies with an inactive control). Then, we assessed head-to-head trials.

To determine the comparative effectiveness of the various interventions, we first focused on direct, comparative evidence if it was available. When direct evidence was not available, we used indirect evidence from, for example, comparisons with placebo. For comparing the efficacy of pharmacological interventions with each other, we conducted a network meta-analysis, including both head-to-head and placebo-controlled trials, as described below.

We conducted quantitative synthesis using meta-analyses of outcomes reported by multiple studies that were homogeneous enough to justify combining their results. To determine whether meta-analyses were appropriate, we assessed the clinical and methodological heterogeneity of the studies under consideration following established guidance.30 We did this by qualitatively assessing the PICOTS of the included studies, looking for similarities and differences. When quantitative synthesis was not appropriate (e.g., due to clinical heterogeneity, insufficient numbers of similar studies, or insufficiency or variation in outcome reporting), we synthesized the data qualitatively.

We found sufficient data to conduct meta-analyses for some comparisons of interest for the following outcomes: change in PTSD symptoms (measured by several different instruments, including the Clinician-Administered PTSD Scale [CAPS], Impact of Event Scale [IES], Davidson Trauma Scale [DTS]), remission, loss of PTSD diagnosis, reduction of comorbid depression or anxiety (e.g., measured by Beck Depression Inventory [DBI], Hamilton Depression Scale [HAM-D], Montgomery-Asberg Depression Rating Scale [MADRS], Hamilton Anxiety Scale [HAM-A]), quality of life (e.g., Quality of Life Enjoyment and Life Satisfaction [Q-LES-Q]), functional impairment (e.g., Sheehan Disability Scale [SDS]), rate of withdrawals due to adverse events, and specific adverse events (e.g., headache, nausea, insomnia). For our analyses comparing medications with placebo, we stratified analyses for each drug class by medication to provide pooled point estimates for each medication compared with placebo.

Random-effects models using the inverse-variance weighted method were used to estimate pooled effects.31 For continuous outcomes (e.g., scales for PTSD symptom reduction) measured with the same scale (e.g., CAPS), we report the weighted mean difference between intervention and control. When multiple scales were combined in one meta-analysis, the standardized mean difference, Cohen’s d, was used. For binary outcomes (e.g., remission, loss of PTSD diagnosis, adverse events), we calculated risk differences between groups. We calculated rates using the number of all randomized patients as the denominator to reflect a true intention-to-treat analysis. Forest plots graphically summarize results of individual studies and of the pooled analyses (Appendix F).32

For analyses of the efficacy of psychological interventions, our main analyses include studies with both waitlist and usual care (or treatment as usual) control groups. We stratified our meta-analyses by comparison group to show how the effect size and confidence interval would differ if we only included studies with a waitlist control, as opposed to including those with both waitlist and usual care controls. The usual care control groups in the included trials were often not described in much detail, making it difficult to determine whether the people in those groups were receiving any care at all. In many studies, usual care groups seemed to be very similar to waitlist groups (except that usual care groups were not on a waitlist to receive an intervention later). We only included studies with present-centered therapy, supportive therapy, or supportive counseling control groups in sensitivity analyses. In addition, for studies that referred to a control group as usual care or treatment as usual but described a clear intervention received by that group (e.g., the Seeking Safety study where the “treatment as usual” group was enrolled in a residential substance use treatment program33), we considered the comparison to be a head-to-head comparison, rather than a comparison with an inactive control.

For analyses comparing medications with placebo, we stratified analyses for each drug class by drug—to provide pooled point estimates for each drug compared with placebo and to show pooled point estimates for the drug class. To address differences in efficacy by type of trauma, we performed subgroup analyses of our PTSD symptom reduction meta-analyses, stratifying each analysis by the type of trauma experienced by the study population. We restricted stratification by trauma population to interventions that had evidence of efficacy and that had a sufficient number of studies to warrant the stratification.

For each meta-analysis, we conducted two types of sensitivity analyses. First, we calculated a series of pooled effects by removing each study from the analysis separately to determine the influence of each study on the findings. Second, we added studies excluded for having high risk of bias and calculated a pooled effect to determine whether including such studies would have changed conclusions.

The chi-squared statistic and the I^2^ statistic (the proportion of variation in study estimates due to heterogeneity) were calculated to assess statistical heterogeneity in effects between studies.34,35 An I^2^ from 0 to 40 percent might not be important, 30 percent to 60 percent may represent moderate heterogeneity, 50 percent to 90 percent may represent substantial heterogeneity, and ≥75 percent represents considerable heterogeneity.36 The importance of the observed value of I^2^ depends on the magnitude and direction of effects and on the strength of evidence for heterogeneity (e.g., p value from the chi-squared test, or a confidence interval for I^2^). Whenever we include a meta-analysis with considerable statistical heterogeneity in this report, we provide an explanation for doing so, considering the magnitude and direction of effects.36 We examined potential sources of heterogeneity by analysis of subgroups defined by patient population and variation in interventions or controls. Heterogeneity was also explored through sensitivity analyses, described above. Quantitative pairwise meta-analyses were conducted using Stata^®^ version 11.1 (StataCorp LP, College Station, TX).

We conducted a network meta-analysis using Bayesian methods to compare the efficacy of pharmacologic interventions with each other for improving PTSD symptoms. Although there were a few head-to-head trials comparing active interventions, the majority of the evidence base was limited to placebo-controlled comparisons. By performing a network meta-analysis, all the evidence, both direct and indirect, can be incorporated into a single internally consistent model. We used the methods developed and illustrated in NICE Technical Support Document 2, which details the generalized linear modeling framework for network meta-analyses of randomized controlled trials.37 We used a random effects logistic regression model that adjusted for correlations between arms within each study. Study effect and treatment effect parameters were modeled by noninformative (flat) prior distributions that were normal (0, 10000). For the heterogeneity of the random-effects model, we used a uniform prior distribution centered at zero with sufficiently large variance. The first 20,000 simulations were discarded to allow for model convergence and then a further 80,000 simulations were used in estimating the posterior probabilities. Satisfactory convergence was verified by trace plots and calculation of the Monte Carlo error for each parameter. We also ran a sensitivity analysis, including studies rated as having a high risk of bias, to assess their impact on the comparative efficacy of the pharmacologic interventions used in treating PTSD. Our outcome in each case was the mean change from baseline to endpoint in CAPS total score, and from the model we calculated pairwise odds ratios with 95% credible intervals, as well as the probability that each drug was the most efficacious. The network meta-analyses were performed using WinBUGS Version 1.4.3, a Bayesian software package that uses Markov chain Monte Carlo (MCMC) methods.

## Strength of the Body of Evidence

We graded the strength of evidence based on the guidance established for the EPC Program.38 Developed to grade the overall strength of a body of evidence, this approach incorporates four key domains: risk of bias (including study design and aggregate quality), consistency, directness, and precision of the evidence. It also considers other optional domains that may be relevant for some scenarios, such as a dose-response association, plausible confounding that would decrease the observed effect, strength of association (magnitude of effect), and publication bias.

Table 4 describes the grades of evidence that we assigned. We graded the strength of the body of evidence to answer KQs on the comparative effectiveness and harms of the interventions in this review. Two reviewers assessed each domain for each key outcome and resolved differences by consensus. For each assessment, one of the two reviewers was always an experienced, senior investigator. The overall grade was based on a qualitative decision.

Table 4 Definitions of the grades of overall strength of evidence

Grade | Definition
High | High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
Moderate | Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate.
Low | Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate.
Insufficient | Evidence either is unavailable or does not permit estimation of an effect.

Source: Owens et al.38

We graded the strength of evidence for the following outcomes: PTSD symptom reduction, remission, loss of diagnosis, prevention or reduction of comorbid medical or psychiatric conditions, quality of life, disability or functional impairment, return to work or to active duty, and adverse events. Appendix G includes tables showing our assessments for each domain and the resulting strength of evidence grades for each KQ, organized by intervention-comparison pair and outcome.

## Applicability

We assessed applicability of the evidence following guidance from the “Methods Guide for Comparative Effectiveness Reviews.”39 We used the PICOTS framework to explore factors that affect applicability. Some factors identified a priori that may limit the applicability of evidence include the following: age of enrolled populations; sex of enrolled populations; race or ethnicity of enrolled populations; few studies enrolling subjects with exposure to certain types of trauma; or few studies distinguishing or reporting the type of traumatic exposure for a heterogeneous population.

### Peer Review and Public Commentary

An external peer review was performed on this report. Peer Reviewers were charged with commenting on the content, structure, and format of the evidence report, providing additional relevant citations, and pointing out issues related to how we conceptualized the topic and analyzed the evidence. Our Peer Reviewers (listed in the front matter) gave us permission to acknowledge their review of the draft. We compiled all comments and addressed each one individually, revising the text as appropriate. AHRQ also provided review from its own staff. In addition, the Scientific Resource Center placed the draft report on the AHRQ Web site (www.effectivehealthcare.ahrq.gov) for public review.