# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Laura Fochtmann, M.D.
  Medical Editor of the American Psychiatric
  Association Practice Guidelines
  Professor of Psychiatry and Director of the ECT Service
  Stony Brook University Medical Center
  Stony Brook, NY
- Matthew J. Friedman, M.D., Ph.D.
  Executive Director, National Center for Posttraumatic Stress Disorder, U.S. Department of Veterans Affairs
  Professor of Psychiatry and of Pharmacology and Toxicology
  Dartmouth Medical School
  Hanover, NH
- Helena Kraemer, Ph.D.
  Professor Emerita of Biostatistics in Psychiatry
  Academy Council, Psychiatry & Behavioral Science
  School of Medicine, Stanford University
  Stanford, CA
- Jane Liebschutz, M.D., M.P.H.
  Associate Professor
  Boston University School of Medicine
  Department of Medicine
  Boston, MA
- Paula Schnurr, Ph.D.
  Deputy Executive Director, VA National Center for PTSD
  Research Professor of Psychiatry
  Dartmouth Medical School
  Hanover, NH