# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Naomi Breslau, Ph.D.
  Professor of Epidemiology
  Michigan State University
  East Lansing, MI
- Jonathan R. Davidson, M.D.
  Professor Emeritus, Psychiatry-Psychiatry & Behavioral Sciences and
  Director of the Anxiety and Traumatic Stress Program
  Duke University Medical Center
  Durham, NC
- Laura Fochtmann, M.D.
  Medical Editor of the American Psychiatric Association Practice Guidelines
  Professor of Psychiatry and Director of the ECT Service
  Stony Brook University Medical Center
  Stony Brook, NY
- Daniel I. Galper, Ph.D.
  Director of Research & Special Projects
  American Psychological Association
  Washington, DC
- Melanie S. Harned, Ph.D.
  University of Washington
  Behavioral Research & Therapy Clinics
  Seattle, WA
- Dean G. Kilpatrick, Ph.D.
  Distinguished University Professor of Clinical Psychology
  Director, National Crime Victims Research & Treatment Center
  Vice-Chair for Research and Research Administration
  Department of Psychiatry & Behavioral Sciences
  Medical University of South Carolina
  Charleston, SC
- Jane Liebschutz, M.D., M.P.H.
  Associate Professor
  Boston University School of Medicine
  Department of Medicine
  Boston, MA