# Acknowledgments

We gratefully acknowledge the support of our AHRQ Task Order Officer, Stephanie Chang, M.D., M.P.H., and the support of our former AHRQ Task Order Officer, Sonia Tyutyulkova, M.D., Ph.D. We extend our appreciation to our Key Informants and members of our Technical Expert Panel (listed below), all of whom provided thoughtful advice and input during our research process.

The investigators deeply appreciate the considerable support, commitment, and contributions of the EPC staff at RTI International and the University of North Carolina at Chapel Hill. We express our gratitude to the following individuals for their contributions to this project: Carol Woodell, B.S.P.H., our Project Manager; Megan Van Noord, M.S.L.S., and Christiane Voisin, our EPC Librarians; Kathleen Lohr, Ph.D, scientific editor; Jennifer Drolet, Carol Offen, and Wally Campbell, editors; and Loraine Monroe, our EPC publications specialist.