# Discussion

We aimed to conduct a systematic review and meta-analysis of the comparative effectiveness and harms of psychological and pharmacological interventions for adults with posttraumatic stress disorder (PTSD). Given that there is some disagreement about whether various treatments are efficacious, we first assessed evidence for efficacy of the treatments of interest and then proceeded to assess comparative effectiveness. We also used this approach because our preliminary searches and input from experts during the topic refinement process suggested that we would find little head-to-head comparative evidence and that we might need to rely on indirect evidence to attempt to make conclusions about comparative effectiveness.

Below, we summarize the main findings and strength of evidence (SOE) by Key Question (KQ). We then discuss the findings in relation to what is already known, applicability of the findings, implications for decisionmaking, limitations, research gaps, and conclusions. When we have graded evidence as insufficient, it indicates that evidence is either unavailable, does not permit estimation of an effect, or does not permit us to draw a conclusion with at least a low level of confidence. It does not indicate that a treatment has been proven to lack efficacy.

## Key Findings and Strength of Evidence

Our results are based on studies we rated as low or medium for risk of bias. To determine whether this influenced our conclusions, we used studies rated as high risk of bias in sensitivity analyses. These sensitivity analyses did not produce significantly different results for our pairwise meta-analyses. Point estimates and confidence intervals were generally very similar, and the sensitivity analyses did not alter any of our main conclusions. The results did not change from statistically significant to nonsignificant or vice versa, with two exceptions: risperidone compared with placebo for PTSD symptom reduction and exposure therapy compared with stress inoculation training for loss of PTSD diagnosis. The main analysis found a statistically significant improvement in symptoms for risperidone (weighted mean difference [WMD] for change from baseline in the Clinician-Administered PTSD Scale [CAPS] of −4.6; 95% CI, −9.0 to −0.2), whereas the sensitivity analysis adding high risk of bias studies was nonsignificant (WMD, −4.0; 95% CI, −8.5 to 0.49). The main analysis found no statistically significant difference between exposure therapy and stress inoculation training for achieving loss of diagnosis (risk difference [RD], 0.18; 95% CI, −0.09 to 0.45; 1 trial, N=51), whereas the sensitivity analysis adding the only high risk of bias study found a significant difference favoring exposure therapy (RD, 0.26; 95% CI, 0.04 to 0.48; 2 trials, N=75).

Further, it does not appear that any particular types of studies were more likely to be excluded from our analyses. For example, the proportions of included studies and excluded studies that focused on combat-related trauma or veterans were similar.

### Key Question 1 Psychological Treatments

Among the psychological treatments, the strongest evidence of efficacy for improving PTSD symptoms and achieving loss of PTSD diagnosis was for exposure-based therapy (high and moderate SOE, respectively). Evidence of moderate strength also supports the efficacy of cognitive processing therapy, cognitive therapy (CT), cognitive behavioral therapy (CBT) mixed therapies, eye movement desensitization and reprocessing (EMDR), and narrative exposure therapy for improving PTSD symptoms and/or achieving loss of PTSD diagnosis. Evidence was insufficient to determine efficacy of relaxation, stress inoculation training, seeking safety, or imagery rehearsal therapy. Of note, seeking safety was developed to target substance use disorders, and imagery rehearsal therapy was designed to focus specifically on nightmares rather than on PTSD.

Effect sizes were generally large for the psychological treatments with moderate SOE supporting efficacy for improving PTSD symptoms (e.g., 28.9-point reduction in CAPS and Cohen’s d 1.27 for exposure-based therapies), and numbers needed to treat (NNTs) were 4 or less to achieve one loss of PTSD diagnosis for cognitive processing therapy, CT, exposure, CBT-mixed, and EMDR. Table 48 summarizes the main findings and SOE for the psychological treatments with evidence of efficacy. The outcomes included in the table are those most commonly reported: PTSD symptoms, loss of PTSD diagnosis, and depression symptoms. Evidence was insufficient to determine efficacy for achieving remission (no longer having symptoms) for all psychological treatments except for CBT-mixed treatments (moderate SOE), because trials typically did not report remission as an outcome. Similarly, evidence for improving other outcomes of interest—anxiety symptoms, quality of life, disability or functional impairment, or return to work or active duty—was generally insufficient (often with no trials reporting those outcomes). We noted a few exceptions: some evidence supported efficacy of CT for improving anxiety symptoms and disability (moderate SOE), efficacy of CBT-mixed treatments and brief eclectic psychotherapy for improving anxiety symptoms (low SOE), efficacy of CBT-mixed treatments for improving disability and functional impairment (low SOE), and efficacy of brief eclectic psychotherapy for improving return to work (low SOE).

Table 48 Summary of findings and strength of evidence for efficacy of psychological treatments for improving PTSD symptoms, achieving loss of PTSD diagnosis, and improving depression symptoms

Intervention | Outcome | Results Effect Size (95% CI)^a^ | Strength of Evidence
Cognitive processing therapy | PTSD symptoms | SMD −1.40 (−1.95 to −0.85; 4 trials, N=299) WMD −32.2 (−46.3 to −18.05; 4 trials, N=299) | Moderate
Cognitive processing therapy | Loss of diagnosis | 0.44 (0.26 to 0.62; 4 trials, N=299); NNT 3 | Moderate
Cognitive processing therapy | Depression symptoms | WMD −10.7 (−16.5 to −4.9; 4 trials, N=299) | Moderate
Cognitive therapy^b^ | PTSD symptoms | SMD −1.22 (−1.91 to −0.53; 3 trials, N=221) | Moderate
Cognitive therapy^b^ | Loss of diagnosis | 0.51 (0.24 to 0.78; 3 trials, N=221); NNT 2 | Moderate
Cognitive therapy^b^ | Depression symptoms | SMD −0.91 (−1.20 to −0.62; 3 trials, N=221) | Moderate
CBT-Exposure | PTSD symptoms | SMD −1.27 (−1.54 to −1.00; 7 trials, N=387) WMD −28.9 (−35.5 to −22.3; 4 trials, N=212) | High
CBT-Exposure | Loss of diagnosis | 0.66 (0.42 to 0.91; 3 trials, N=197); NNT 2 | Moderate
CBT-Exposure | Depression symptoms | WMD −8.2 (−10.3 to −6.1; 6 trials, N=363) | High
CBT-M | PTSD symptoms | SMD −1.09 (−1.4 to −0.78; 14 trials, N=825) WMD −31.1 (−42.6 to −19.6; 8 trials, N=476) | Moderate
CBT-M | Loss of diagnosis | 0.26 (0.11, 0.41; 6 trials, N=290); NNT 4 | Moderate
CBT-M | Depression symptoms | WMD −10.4 (−14.4, −6.4; 10 trials, N=662) | Moderate
EMDR | PTSD symptoms | SMD −1.08 (−1.83 to −0.33; 4 trials, N=117) | Low
EMDR | Loss of diagnosis | 0.64 (0.46 to 0.81; 3 trials, N=95); NNT 2 | Moderate
EMDR | Depression symptoms | SMD −1.13 (−1.52, −0.74; 4 trials, N=117) | Moderate
NET | PTSD symptoms | SMD −1.25 (−1.92 to −0.58; 3 trials, N=227) PDS, WMD −10.2 (−13.1 to −7.4; 3 trials, N=227) | Moderate
NET | Loss of diagnosis | 0.15 (0.01 to 0.30; 3 trials, N=227) | Low
NET | Depression symptoms | Mixed evidence; 1 trial reported efficacy and 1 reported no difference from comparators, 2 trials, N=75 | Insufficient
BEP | PTSD symptoms | Likely small to medium effect size (3 trials, N=96) | Low
BEP | Loss of diagnosis | RD ranged from 0.125 to 0.58 across trials (3 trials, N=96) | Low
BEP | Depression symptoms | 3 trials (N=96) found benefits; wide range of effect sizes in the 2 trials reporting sufficient data, from medium to very large | Low

BDI = Beck Depression Inventory; BEP = brief eclectic psychotherapy; CAPS = Clinician-Administered PTSD Scale; CBT = cognitive behavior therapy; CBT-M = cognitive behavior therapy—mixed; CI = confidence interval; EMDR = eye movement desensitization and reprocessing; N = number of subjects; NET = narrative exposure therapy; NNT = number needed to treat; PDS = Posttraumatic Diagnostic Scale; PTSD = posttraumatic stress disorder; RD = risk difference; SMD = standardized mean difference; WMD = weighted mean difference

a WMD data for PTSD symptoms are mean change from baseline (95% CI, number of trials and number of subjects contributing data) in CAPS score compared with inactive comparators unless another outcome measure is specified; SMD data are Cohen’s d—effect sizes. A small effect size is d=0.20, medium effect size is d=0.50, and large effect size is d=0.80.^43^ Baseline PTSD severity was generally in the severe (CAPS of 60 to 79) or extreme (CAPS ≥80) range across the included trials. Using CAPS, PTSD severity has been categorized as asymptomatic/few symptoms (0 to 19), mild PTSD/subthreshold (20 to 39), moderate PTSD/threshold (40 to 59), severe, and extreme.40 Data for loss of diagnosis are risk difference for treatment compared with inactive comparators unless otherwise specified. WMD data for depression symptoms are mean change from baseline in BDI score compared with inactive comparators unless another outcome measure is specified. SMD data for depression symptoms are Cohen’s d.

b For the purposes of summarizing results and conclusions, the cognitive therapy category here summarizes evidence from the cognitive therapy studies that were not specifically cognitive processing therapy.

Most of the direct head-to-head comparative evidence was insufficient to determine if psychotherapies differ in effectiveness, with a few exceptions. Evidence of moderate strength supports greater effectiveness (1) for exposure therapy than for relaxation for achieving loss of PTSD diagnosis and improving depression symptoms and (2) for CBT-mixed therapies than for relaxation for improving PTSD symptoms. Evidence of moderate strength also supports similar effectiveness for (1) exposure and exposure plus cognitive restructuring (CR) for achieving loss of PTSD diagnosis and (2) seeking safety and active controls (e.g., relapse prevention programs) for PTSD symptom reduction. Table 49 summarizes the available head-to-head comparative evidence and SOE for improving PTSD symptoms, achieving loss of PTSD diagnosis, and improving depression symptoms (the outcomes most commonly reported). With few trials and few total subjects, most of our meta-analyses of head-to-head trials were underpowered to detect anything but medium to large differences between therapies. Evidence was insufficient to determine efficacy for achieving remission (no longer having symptoms) for all comparisons because trials typically did not report remission as an outcome. Similarly, evidence for improving other outcomes of interest—anxiety symptoms, quality of life, disability or functional impairment, or return to work or active duty—was insufficient for all comparisons (usually because no trials making the comparison reported those outcomes).

Table 49 Summary of findings and strength of evidence for comparative effectiveness of psychological treatments for improving PTSD symptoms, achieving loss of PTSD diagnosis, and improving depression symptoms

Comparison | Outcome | Results Effect Size (95% CI)^a^ | Strength of Evidence
CR vs. Relaxation | PTSD symptoms | 50% vs. 20% of subjects improved, p=0.04, 1 trial, N=34 | Insufficient
CR vs. Relaxation | Loss of diagnosis | 65% vs. 55% of subjects, p=NS, 1 trial, N=34 | Insufficient
CR vs. Relaxation | Depression symptoms | BDI (mean improvement): 7 (3 to 11) vs. 17 (11 to 22), 1 trial, N=34 | Insufficient
CT vs. Exposure | PTSD symptoms | WMD 4.8 (−4.5 to 14.2; 2 trials, N=100) | Insufficient
CT vs. Exposure | Loss of diagnosis | RD 0.13 (−0.06 to 0.32; 2 trials, N=100) | Insufficient
CT vs. Exposure | Depression symptoms | WMD 2.75 (−1.94 to 7.43; 2 trials, N=100) | Insufficient
Exposure vs. CPT | PTSD symptoms | WMD 3.97 (−5.95 to 13.9; 1 trial, N=124) | Insufficient
Exposure vs. CPT | Loss of diagnosis | 0.00 (−0.18 to 0.18; 1 trial, N=124) | Insufficient
Exposure vs. CPT | Depression symptoms | WMD 2.94 (−0.75 to 6.63; 1 trial, N=124) | Insufficient
Exposure vs. Relaxation | PTSD symptoms | WMD −9.7 (−22.3 to 2.9; 2 trials, N=85) | Insufficient
Exposure vs. Relaxation | Loss of diagnosis | Favors exposure: RD 0.31 (0.04 to 0.58; 2 trials, N=85) | Moderate
Exposure vs. Relaxation | Depression symptoms | WMD −5.5 (−10.2 to −0.79; 2 trials, N=85) | Moderate
Exposure vs. SIT | PTSD symptoms | SMD −0.14 (−0.69 to 0.41; 1 trial, N=51) | Insufficient
Exposure vs. SIT | Loss of diagnosis | RD 0.18 (−0.09 to 0.45; 1 trial, N=51) | Insufficient
Exposure vs. SIT | Depression symptoms | WMD −0.15 (−5.8 to 5.5; 1 trial, N=51) | Insufficient
Relaxation vs. EMDR | PTSD symptoms | SMD −0.57 (−1.4 to 0.29; 2 trials, N=64) | Insufficient
Relaxation vs. EMDR | Loss of diagnosis | 0.34 (−0.04 to 0.72; 2 trials, N=64) | Insufficient
Relaxation vs. EMDR | Depression symptoms | Conflicting findings (2 trials, N=64) | Insufficient
Relaxation vs. CBT-M | PTSD symptoms | Favors CBT-M (2 trials, N=85)^b^ | Moderate
Relaxation vs. CBT-M | Loss of diagnosis | No included studies reported the outcome | Insufficient
Relaxation vs. CBT-M | Depression symptoms | No included studies reported the outcome | Insufficient
Exposure vs. EMDR | PTSD symptoms | No difference found (2 trials, N=91) | Insufficient
Exposure vs. EMDR | Loss of diagnosis | Both trials favor exposure, but meta-analysis did not find a statistically significant difference and results were imprecise: RD 0.14 (−0.01 to 0.29; 2 trials, N=91) | Insufficient
Exposure vs. EMDR | Depression symptoms | No difference (2 trials, N=91) | Insufficient
Exposure vs. Exposure plus CR | PTSD symptoms | SMD 0.25 (−0.29 to 0.80; 3 trials, N=259) | Insufficient
Exposure vs. Exposure plus CR | Loss of diagnosis | Similar benefits: RD −0.01 (−0.17 to 0.14; 3 trials, N=259) | Moderate
Exposure vs. Exposure plus CR | Depression symptoms | WMD 2.78 (−1.68 to 7.25; 4 trials, N=299) | Insufficient
Brief eclectic psychotherapy vs. EMDR | PTSD symptoms | 1 trial (N=140) reported more rapid improvement with EMDR but no difference after completion of treatment | Insufficient
Brief eclectic psychotherapy vs. EMDR | Loss of diagnosis | 1 trial (N=140) reported more rapid improvement with EMDR but no difference after treatment | Insufficient
Brief eclectic psychotherapy vs. EMDR | Depression symptoms | 1 trial (N=140) reported more rapid improvement with EMDR but no difference after treatment | Insufficient
Seeking safety vs. active controls^c^ | PTSD symptoms | SMD 0.04 (−0.12 to 0.20; 4 trials, N=594) WMD 1.45 (−2.5 to 5.4; 3 trials, N=477) | Moderate
Seeking safety vs. active controls^c^ | Loss of diagnosis | OR 1.22 (0.48 to 3.13; 1 trial, N=49) | Insufficient
Seeking safety vs. active controls^c^ | Depression symptoms | No trials | Insufficient

CAPS = Clinician-Administered PTSD Scale; CBT-M = cognitive behavior therapy—mixed; CI = confidence interval; CR = cognitive restructuring; CT = cognitive therapy; EMDR = eye movement desensitization and reprocessing; N = number of subjects; PE = prolonged exposure; PTSD = posttraumatic stress disorder; RD = risk difference; SIT = stress inoculation training; SMD = standardized mean difference; WMD = weighted mean difference

a For PTSD symptoms, WMD data are mean change from baseline (95% CI, number of trials and number of subjects contributing data) in CAPS score compared with inactive comparators unless another outcome measure is specified; SMD data are Cohen’s d—effect sizes. Baseline PTSD severity was generally in the severe (CAPS of 60 to 79) or extreme (CAPS ≥80) range across the included trials. Using CAPS, PTSD severity has been categorized as asymptomatic/few symptoms (0 to 19), mild PTSD/subthreshold (20 to 39), moderate PTSD/threshold (40 to 59), severe, and extreme.40 For loss of diagnosis, data are risk difference (95% CI, number of trials and number of subjects contributing data) for the comparison between the two therapies unless otherwise specified. For depression symptoms, WMD data are between-group difference for mean change from baseline in BDI score unless another outcome measure is specified. SMD data for depression symptoms are Cohen’s d.

b Mean CAPS improvement: 38 (95% CI, 26 to 50) vs. 14 (95% CI, 4 to 25) in 1 trial;46 between-group effect size was very large favoring CBT-M (Cohen’s d=1.6) in another.47

c ctive controls were relapse prevention, psychoeducation, and treatment as usual in a VA substance use disorders clinic.

Note: Table only includes rows for comparisons with any available trials. We found no low or medium risk-of-bias trials making other head-to-head comparisons.

### Key Question 2 Pharmacological Treatments

Among the pharmacological treatments, we found evidence of moderate strength supporting the efficacy of fluoxetine, paroxetine, sertraline, topiramate, and venlafaxine for improving PTSD symptoms. Risperidone may also have some benefit for reduction of PTSD symptoms (low SOE). Evidence was insufficient to determine whether other medications are efficacious for improving PTSD symptoms. For most of the medications with evidence of efficacy, the mean size of the effect for improving symptoms was small or medium (mean change from baseline in CAPS compared with placebo ranged from −4.9 to −15.5 for the medications with moderate SOE). However, paroxetine and venlafaxine also had evidence of efficacy for inducing remission with NNTs of ~8 (moderate SOE).

Table 50 summarizes the main findings and SOE for the pharmacological treatments with evidence of efficacy. The outcomes included in the table are those most commonly reported: PTSD symptoms, remission, and reduction of depression symptoms. Unlike the studies of psychological treatments, which often reported loss of PTSD diagnosis as an outcome, evidence was insufficient to determine efficacy for achieving loss of PTSD diagnosis for all of the pharmacological treatments because studies generally did not report it as an outcome. Similarly, evidence for improving other outcomes of interest—anxiety symptoms, quality of life, disability or functional impairment, or return to work or active duty—was usually insufficient (often with no trials reporting those outcomes). We noted a few exceptions: evidence supported efficacy of fluoxetine for improving anxiety symptoms (moderate SOE), efficacy of venlafaxine for improving quality of life (moderate SOE), and efficacy of venlafaxine and paroxetine for improving functional impairment for adults with PTSD (moderate SOE).

Table 50 Summary of findings and strength of evidence for efficacy of pharmacological treatments for improving PTSD symptoms, achieving remission, and improving depression symptoms

Medication Class | Medication | Outcome | Results Effect Size (95% CI)^a^ | Strength of Evidence
Anticonvulsant | Topiramate | PTSD symptoms | WMD −15.5 (−19.4 to −11.7; 3 trials, −N=142) SMD −0.96 (−1.89 to −0.03; 3 trials, N=142) | Moderate
Anticonvulsant | Topiramate | Remission | 42% vs. 21%, p=0.295 (1 trial, N=40) | Insufficient
Anticonvulsant | Topiramate | Depression symptoms | BDI −8.5 vs. −3.9, p=0.72 (1 trial, N=35) HAMD −50.7% vs. −33.3, p=0.253 (1 trial, N=40) | Insufficient
Antipsychotic | Risperidone | PTSD symptoms | WMD −4.60 (−9.0 to −0.2; 4 trials, N=419) SMD −0.26 (−0.52 to −0.00; 4 trials, N=419) | Low
Antipsychotic | Risperidone | Remission | No included studies reported the outcome | Insufficient
Antipsychotic | Risperidone | Depression symptoms | HAMD −3.7 vs. −1.4, p>0.05 (1 trial, N=65) | Insufficient
SNRI | Venlafaxine ER | PTSD symptoms | WMD −7.2 (−11.0 to −3.3; 2 trials, N=687) SMD −0.28 (−0.43 to −0.13; 2 trials, N=687) | Moderate
SNRI | Venlafaxine ER | Remission | RD 0.12 (0.05 to 0.19; 2 trials, N=687); NNT 9 | Moderate
SNRI | Venlafaxine ER | Depression symptoms | HAMD WMD −2.08 (−3.12 to −1.04; 2 trials, N=687) | Moderate
SSRI | Fluoxetine | PTSD symptoms | WMD −6.97 (−10.4 to −3.5; 4 trials, N=835) SMD −0.31 (−0.44 to −0.17; 5 trials, N=889) | Moderate
SSRI | Fluoxetine | Remission | 13% vs. 10%, p=0.72 (1 trial, N=52) | Insufficient
SSRI | Fluoxetine | Depression symptoms | MADRS WMD −2.4 (−3.7 to −1.1; 2 trials, N=712) SMD −0.20 (−0.40 to −0.00; 3 trials, N=771) | Moderate
SSRI | Paroxetine | PTSD symptoms | WMD −12.6 (−15.7 to −9.5; 2 trials, N=886) SMD −0.49 (−0.61 to −0.37; 2 trials, N=886) | Moderate
SSRI | Paroxetine | Remission | 0.129 (p=0.008; 2 trials, N=346); NNT 8^b^ | Moderate
SSRI | Paroxetine | Depression symptoms | MADRS WMD −5.7 (−7.1 to −4.3; 2 trials, N=886) SMD −0.49 (−0.64 to −0.34; 2 trials, N=886) | Moderate
SSRI | Sertraline | PTSD symptoms | WMD −4.9 (−7.4 to −2.4; 7 trials, N=1,085) SMD −0.25 (−0.42 to −0.07; 8 trials, N=1,155) | Moderate
SSRI | Sertraline | Remission | 24.3% vs. 19.6%, p=NS (NR) (1 trial, N=352) | Insufficient
SSRI | Sertraline | Depression symptoms | HAMD WMD −0.77 (−2.1 to 0.55; 5 trials, N=1,010) SMD −0.13 (−0.32 to 0.06; 7 trials, N=1,085) | Low

BDI = Beck Depression Inventory; CAPS = Clinician-Administered PTSD Scale; CI = confidence interval; ER= extended release; HAMD = Hamilton Rating Scale for Depression; MADRS = Montgomery–Åsberg Depression Rating Scale; N = number of subjects; NNT = number needed to treat; NR = not reported; NS = not statistically significant; PTSD = posttraumatic stress disorder; RD = risk difference (for medication compared with placebo); SMD = standardized mean difference; SNRI = serotonin and norepinephrine reuptake inhibitors; SSRI = selective serotonin reuptake inhibitors; WMD = weighted mean difference

a For PTSD symptoms, WMD data are mean change from baseline (95% CI, number of trials and number of subjects contributing data) in CAPS score compared with placebo. Baseline PTSD severity was generally in the severe (CAPS of 60 to 79) or extreme (CAPS ≥80) range across the included trials. Using CAPS, PTSD severity has been categorized as asymptomatic/few symptoms (0 to 19), mild PTSD/subthreshold (20 to 39), moderate PTSD/threshold (40 to 59), severe, and extreme.40 SMD data are Cohen’s d—effect sizes. A small effect size is d=0.20, medium effect size is d=0.50, and large effect size is d=0.80.^43^ For depression symptoms, WMD data are between-group difference for mean change from baseline in BDI, HAMD, or MADRS score—whichever measure is specified.

b The best available evidence is from a trial of paroxetine (N=323) that defined remission as a CAPS-2 total score less than 20 and found a significantly greater proportion of paroxetine-treated subjects achieved remission compared with placebo at week 12 (29.4% vs. 16.5%, p=0.008).134 The other trial contributing data for this outcome found similar percentages of subjects achieving remission (33% vs. 14%).164

Little direct comparative evidence (i.e., head-to-head) was available to determine if pharmacological treatments differ in effectiveness. We identified just three medium-risk-of-bias trials meeting inclusion criteria. Of those three, just one compared medications that have evidence supporting their efficacy—the trial compared 12 weeks of venlafaxine, sertraline, and placebo in 538 subjects with a variety of index trauma types.133 It found no statistically significant difference for improvements in PTSD symptoms between venlafaxine and sertraline.

Our network meta-analysis of 28 trials (4,817 subjects) incorporating both direct and indirect evidence found paroxetine and topiramate to be more effective for reducing PTSD symptoms than most other medications included in the analysis. When compared with other medications with at least moderate SOE supporting efficacy, paroxetine was more effective than sertraline (WMD, −7.6; 95% CrI, −12 to −2.8) but was not significantly different from fluoxetine, topiramate, or venlafaxine. When compared with other medications with moderate SOE supporting efficacy, topiramate was more effective than fluoxetine (WMD, 8.6; 95% CrI, 2.4 to 14.9), sertraline (WMD, 11; 95% CrI, 5.7 to 16.6), and venlafaxine (WMD, −8.8; 95% CrI, −15 to −2.5) but was not significantly different from paroxetine. Of note, these findings have low SOE, because they are based primarily on indirect evidence. Also, our network meta-analysis was based on a single outcome (reduction of PTSD symptoms as measured by CAPS) and does not capture other important information—for example, that there is moderate SOE supporting the efficacy of paroxetine and venlafaxine for achieving remission (with NNTs of ~8) but insufficient evidence to determine the efficacy of other medications for achieving remission.

### Key Question 3 Psychotherapy Compared With Pharmacotherapy

We found just one trial (N=88) meeting inclusion criteria that directly compared a psychological treatment with a pharmacological treatment. It compared EMDR, fluoxetine, and placebo.113 The trial found that EMDR- and fluoxetine-treated subjects had similar improvements in PTSD symptoms, rates of remission, and loss of PTSD diagnosis at the end of treatment. At 6-month followup, those treated with EMDR had higher remission rates and greater reductions in depression symptoms than those who received fluoxetine. We concluded that the head-to-head evidence was insufficient to draw any firm conclusions about comparative effectiveness, because of medium risk of bias, unknown consistency (with data from just one study), and lack of precision (insufficient SOE).

### Key Question 4 Combinations of Psychological Treatments and Pharmacological Treatments Compared With Either One Alone

Our intention was to inform whether clinicians should start with combinations of treatments at the outset instead of a single treatment. Two trials provided limited information related to this KQ.183,184 The most relevant trial (N=37) found greater improvement in PTSD symptoms (CAPS −51.1 versus −29.8, p=0.01) and greater likelihood of remission for those treated with both prolonged exposure and paroxetine than for those treated with prolonged exposure plus placebo.183 Evidence was limited by unknown consistency (single trial), attrition, and lack of precision. Overall, evidence was insufficient to determine whether combinations of psychological treatments and pharmacological treatments are better than either one alone when initiating treatment.

### Key Question 5 Victims of Particular Types of Trauma

Overall, evidence was insufficient to make definitive conclusions about whether any treatment approaches are more effective for victims of particular types of trauma. Analyses were generally not powered to detect anything but large differences. In addition, many other factors (other than trauma type) varied across the studies included in our subgroup analyses. Findings should be considered hypothesis generating. Most of the subgroup analyses (those reported by included studies and those that we conducted of our meta-analyses) found similar benefits for victims of different trauma types. We noted two exceptions: (1) subgroup analyses from one trial (N=88) that compared EMDR, fluoxetine, and placebo found that treatments were less effective for those with child-onset trauma and that EMDR was more effective than paroxetine at 6-month posttreatment followup for those with either child- or adult-onset trauma;113 and (2) our subgroup analyses found a trend toward greater efficacy of EMDR for studies enrolling females with a history of sexual assault compared with those enrolling subjects with other trauma types—we found that EMDR was efficacious for both groups, but we noted a large effect size for females with a history of sexual assault (standardized mean difference [SMD], −1.68; 95% CI, −2.23 to −1.13; 2 trials, N=71) and a small to medium effect size (that did not reach a statistically significant benefit) for those with other trauma types (SMD, −0.44; 95% CI, −1.03 to 0.15; 2 trials, N=46).

### Key Question 6 Adverse Effects of Treatments

For psychological treatments, the vast majority of studies reported no information about adverse effects. With such a small proportion of trials reporting data, evidence was insufficient to draw conclusions about withdrawals due to adverse events, mortality, suicide, suicidal ideation, self-harmful behaviors, or other specific adverse events.

For pharmacological treatments, very few studies reported any information about mortality, suicide, suicidal ideation, or self-harmful behaviors (insufficient SOE). For most other adverse effects, risk of bias of included studies, inconsistency or unknown consistency, and lack of precision all contributed to the insufficient SOE determinations. Study durations ranged from 8 to 24 weeks and were generally not designed to assess adverse events. Adverse events were often not collected using standardized measures, and methods for systematically capturing adverse events were often not reported. Focusing on the medications with moderate SOE supporting efficacy (see KQ 2)—topiramate, venlafaxine, fluoxetine, paroxetine, and sertraline—Table 51 summarizes the findings and SOE for selected specific adverse events. Most of the evidence for these events was insufficient to determine whether the risk was increased, often primarily because of lack of precision.

Table 51 Risk difference and strength of evidence for selected adverse effects of pharmacological treatments compared with placebo^a^

Medication Class | Medication | Outcome | Results Effect Size (95% CI)^b^ | Strength of Evidence
Anticonvulsant | Topiramate | W/D due to AE | 0.01 (−0.08 to 0.10; 3 trials, N=142) | Insufficient
Anticonvulsant | Topiramate | Headache | −0.01 (−0.21 to 0.18; 2 trials, N=75) | Insufficient
Anticonvulsant | Topiramate | Insomnia | 0.12 (−0.05 to 0.28; 2 trials, N=75) | Insufficient
Anticonvulsant | Topiramate | Somnolence | −0.10 (−0.39 to 0.20; 1 trial, N=35) | Insufficient
Anticonvulsant | Topiramate | Taste perversion | 0.25 (0.04 to 0.46; 1 trial, N=40) | Insufficient
Anticonvulsant | Topiramate | Dyspepsia | 0.10 (−0.12 to 0.32; 1 trial, N=40) | Insufficient
Anticonvulsant | Topiramate | Paresthesia | 0.15 (−0.05 to 0.35; 1 trial, N=40) | Insufficient
Anticonvulsant | Topiramate | Nervousness | 0.15 (−0.05 to 0.35; 1 trial, N=40) | Insufficient
Anticonvulsant | Topiramate | Fatigue | 0.20 (0.00 to 0.40; 1 trial, N=40) | Insufficient
SNRI | Venlafaxine ER | W/D due to AE | 0.02 (−0.03 to 0.07; 2 trials, N=687) | Low
SNRI | Venlafaxine ER | Headache | 0.01 (−0.06 to 0.07; 2 trials, N=687) | Low
SNRI | Venlafaxine ER | Nausea | 0.10 (0.05 to 0.16; 2 trials, N=687) | Moderate
SNRI | Venlafaxine ER | Insomnia | 0.01 (−0.06 to 0.08; 2 trials, N=687) | Insufficient
SNRI | Venlafaxine ER | Dry mouth | 0.07 (0.02 to 0.11; 2 trials, N=687) | Moderate
SNRI | Venlafaxine ER | Diarrhea | −0.02 (−0.09 to 0.05; 1 trial, N=358) | Insufficient
SNRI | Venlafaxine ER | Dizziness | 0.06 (0.01 to 0.11; 2 trials, N=687) | Moderate
SNRI | Venlafaxine ER | Fatigue | 0.03 (−0.01 to 0.07; 2 trials, N=687) | Insufficient
SNRI | Venlafaxine ER | Somnolence | −0.00 (−0.04 to 0.04; 2 trials, N=687) | Low
SNRI | Venlafaxine ER | Decreased appetite | 0.06 (−0.00 to 0.11; 1 trial, N=358) | Insufficient
SNRI | Venlafaxine ER | Constipation | 0.06 (−0.02 to 0.13; 2 trials, N=687) | Insufficient
SSRI | Fluoxetine | W/D due to AE | −0.01 (−0.04 to 0.03; 3 trials, N=766) | Low
SSRI | Fluoxetine | Headache | 0.03 (−0.04 to 0.09; 3 trials, N=776) | Insufficient
SSRI | Fluoxetine | Nausea | 0.05 (0.00 to 0.09; 2 trials, N=712) | Low
SSRI | Fluoxetine | Insomnia | 0.03 (−0.06 to 0.11; 1 trial, N=301) | Insufficient
SSRI | Fluoxetine | Diarrhea | 0.24 (0.01 to 0.47; 1 trial, N=64) | Insufficient
SSRI | Fluoxetine | Somnolence | 0.05 (0.00 to 0.10; 1 trial, N=411) | Insufficient
SSRI | Paroxetine | W/D due to AE | 0.04 (0.00 to 0.07; 3 trials, N=911) | Moderate
SSRI | Paroxetine | Nausea | 0.11 (0.04 to 0.18; 2 trials, N=886)^c^ | Low
SSRI | Paroxetine | Dry mouth | 0.10 (0.04 to 0.16; 1 trial, N=323) | Low
SSRI | Paroxetine | Diarrhea | Incidence of at least 10% and twice that of placebo; 1 trial, N=563^163^ | Insufficient
SSRI | Paroxetine | Somnolence | 0.13 (0.07 to 0.20; 2 trials, N=886)^c^ | Low
SSRI | Paroxetine | Drowsiness | −0.15 (−0.51 to 0.21; 1 trial, N=25) | Insufficient
SSRI | Paroxetine | Sexual adverse effects | Incidence of at least 10% and twice that of placebo; 1 trial, N=563^163^ | Insufficient
SSRI | Sertraline | W/D due to AE | 0.01 (−0.01 to 0.04; 7 trials, N=1,122) | Low
SSRI | Sertraline | Headache | 0.03 (−0.03 to 0.08; 6 trials, N=1,028) | Insufficient
SSRI | Sertraline | Nausea | 0.09 (0.04 to 0.13; 7 trials, N=1,061) | Moderate
SSRI | Sertraline | Insomnia | 0.05 (−0.02 to 0.11; 6 trials, N=1,019) | Insufficient
SSRI | Sertraline | Dry mouth | 0.03 (−0.01 to 0.07; 5 trials, N=859) | Insufficient
SSRI | Sertraline | Diarrhea | 0.12 (0.07 to 0.17; 5 trials, N=986) | Moderate
SSRI | Sertraline | Dizziness | 0.04 (−0.02 to 0.10; 2 trials, N=385) | Insufficient
SSRI | Sertraline | Fatigue | 0.07 (0.03 to 0.11; 4 trials, N=762) | Moderate
SSRI | Sertraline | Somnolence | 0.01 (−0.08 to 0.09; 2 trials, N=521) | Insufficient
SSRI | Sertraline | Drowsiness | 0.05 (−0.00 to 0.11; 4 trials, N=507) | Insufficient
SSRI | Sertraline | Decreased appetite | 0.07 (0.01 to 0.13; 5 trials, N=705) | Moderate
SSRI | Sertraline | Increased appetite | −0.01 (−0.19 to 0.16; 2 trials, N=75) | Insufficient
SSRI | Sertraline | Constipation | 0.02 (−0.03 to 0.07; 2 trials, N=422) | Insufficient

AE = adverse events; CI = confidence interval; ER = extended release; N = number; SNRI = serotonin and norepinephrine reuptake inhibitors; SSRI = selective serotonin reuptake inhibitors; W/D = withdrawals

a Table includes only those pharmacological treatments with moderate strength of evidence supporting their efficacy.

b Data reported are risk differences between medications and placebo (95% CI; number of trials, number of subjects). These data are results of our meta-analyses (if more than one trial reported data) or risk difference calculations (if one trial reported data). Positive risk differences favor placebo (more events in the medication group).

c Data are based on the only trial (N=323) reporting sufficient data to determine the risk difference.134 One additional trial (N=563) that provided narrative description reported that the most commonly reported adverse events associated with paroxetine use (with an incidence of at least 10% and twice that of placebo) were asthenia, diarrhea, abnormal ejaculation, impotence, nausea, and somnolence.163

Note: We did not include rows for adverse events with no data (i.e., those with zero included trials reporting data). The adverse events included in the table are those reported by the included studies.

For withdrawals due to adverse events, we found similar rates (within 1% to 2%) for subjects treated with fluoxetine, sertraline, and venlafaxine compared with those who received placebo (low SOE). We found a 4 percent higher rate of withdrawals due to adverse events with paroxetine than with placebo (moderate SOE). For most of the specific adverse events, point estimates favored placebo (more adverse events with medications), but differences were not statistically significant. We found a small increase (~5%) in the risk of nausea for fluoxetine (low SOE); an increase (of 10% to 13%) in the risk of nausea, dry mouth, and somnolence for paroxetine (low SOE); between 7 percent and 12 percent increases in the risk of nausea, diarrhea, fatigue, and decreased appetite for sertraline (moderate SOE); and an increased risk (of 6% to 10%) of nausea, dry mouth, and dizziness for subjects treated with venlafaxine compared with those who received placebo (moderate SOE). Evidence suggests no difference in risk of headache or somnolence between subjects treated with venlafaxine compared with those who received placebo (low SOE). Findings were insufficient to determine whether the risks of other adverse events are increased.

Overall, evidence was insufficient to determine comparative rates of adverse events for various interventions.

However, other systematic reviews have summarized adverse event evidence for second-generation antidepressants, including selective serotonin reuptake inhibitors (SSRIs) and serotonin and norepinephrine reuptake inhibitors (SNRIs), from clinical trials that enroll subjects with depression or other conditions (not subjects with PTSD) and employ similar doses as those used in PTSD trials. Adverse events, including diarrhea, dizziness, dry mouth, fatigue, headache, nausea, sexual dysfunction, sweating, tremor, and weight gain, are commonly reported. Overall, second-generation antidepressants in clinical trials of patients with depression cause similar adverse events; however, the frequency of specific events differs among some antidepressants.186,187 Evidence from multiple randomized controlled trials indicates that sertraline has a higher incidence of diarrhea than other SSRIs (and other second-generation antidepressants, including SNRIs and venlafaxine).186,187 Further, of the SSRIs, paroxetine has the highest rate of discontinuation (and fluoxetine the lowest). It is less clear how SSRIs differ in frequency for other adverse events or that they differ in the severity of such events.186,187

Evidence from clinical trials enrolling patients with depression indicates that venlafaxine has a higher rate of nausea and vomiting than other second-generation antidepressants and that mirtazapine produces greater weight gain than the SSRIs.186,187 Further, venlafaxine (like paroxetine) has a higher rate of discontinuation than the other second-generation antidepressants. Finally, venlafaxine has a higher rate of discontinuation due to adverse events than the SSRIs, but it has a lower rate of discontinuation due to lack of efficacy than the SSRIs.186,187

For topiramate, most of the evidence derives from trials of patients with epilepsy or trials for prevention of migraine headaches (its two U.S. Food and Drug Administration [FDA]-approved indications). The most common adverse event reported is paresthesias; other common side effects include fatigue, decreased appetite, nausea, diarrhea, and weight loss188,189 (which is sometimes seen as a benefit).

For risperidone, the most relevant data come from its use in trials involving its FDA-approved indications for schizophrenia and bipolar disorder. Like the other available second-generation antipsychotics, its side effect profile involves sedation and orthostatic hypotension,190 but the more concerning adverse events include prolactin elevation and extrapyramidal side effects (both greater with risperidone than with the other second-generation antipyschotics) and its high risk for weight gain and associated metabolic complications.191

### Findings in Relation to What Is Already Known

Existing guidelines and systematic reviews agree that some psychological therapies are effective treatments for adults with PTSD.2,13–17,192,193 Our findings support this assertion in that we found evidence to support the efficacy of several psychological treatments for adults with PTSD. Further, we found that exposure therapy was the only treatment with high SOE supporting its efficacy (based primarily on studies of prolonged exposure).

Most guidelines and systematic reviews (with the exception of the Institute of Medicine [IOM] report2) recognize some benefit of pharmacological treatments—our findings support this assertion. We found evidence of moderate strength supporting the efficacy of fluoxetine, paroxetine, sertraline, topiramate, and venlafaxine.

Some guidelines identify psychological treatments over pharmacological treatments as the preferred first step and view medications as an adjunct or a next-line treatment.13–16 We found insufficient direct evidence (from head-to-head trials) to support this approach. Indirect evidence would suggest that psychological treatments are more effective than pharmacological treatments (because effect sizes for reduction of PTSD symptoms are much larger in trials of the efficacious psychological treatments than in trials of the efficacious pharmacological treatments). However, conclusions based on naïve indirect comparisons can be flawed—primarily because it is difficult to determine how similar populations are across two somewhat different bodies of literature (i.e., studies of psychological treatments and pharmacological treatments).

Although patients enrolled in trials of psychological and pharmacological treatments had similar average ages and similar baseline PTSD severity, different types of patients may have been recruited for studies or may have been willing to be enrolled in studies of psychological treatments than for studies of medications. For example, it was often hard to determine how many previous treatments subjects had failed, and studies of medications may have enrolled more “treatment-resistant” subjects. Further, the study designs used for pharmacological treatments could be considered more rigorous in some ways (e.g., generally with masking of patients, providers, and outcome assessors) than those of psychological treatments (e.g., generally with no masking of patients or providers). Thus, further studies are needed to confirm or refute whether psychological treatments are truly more effective first-line treatments.

We reached a few notably different conclusions than those presented in the IOM report.2 First, we concluded that cognitive processing therapy has moderate evidence supporting efficacy for improving some outcomes for adults with PTSD, whereas the IOM report did not make a specific conclusion about cognitive processing therapy. We believe this difference was due to misclassification of three trials of cognitive processing therapy70–72 that provided the bulk of the evidence supporting the efficacy of cognitive processing therapy. The IOM report classified these three trials as exposure therapy. Second, the authors concluded that evidence was inadequate to determine whether EMDR is efficacious, whereas we concluded that evidence supports its efficacy (low SOE for PTSD symptom reduction and moderate SOE for loss of diagnosis). They focused on four trials that they determined to have no major limitations44, 87, 111,113 but noted that only two showed a positive effect for EMDR (thus, with 2 out of 4 positive studies, they could not determine whether EMDR was efficacious). All four of those trials had point estimates favoring EMDR for reduction of PTSD symptoms; however, two of them lacked the power (i.e., they were imprecise) to detect a statistically significant difference between groups. We believe the main reason we reached a different conclusion is that we synthesized the data quantitatively (with meta-analysis) rather than qualitatively—increasing precision and ability to find a difference in these situations. Our meta-analysis for reduction of PTSD symptoms included four trials (3 of those mentioned above plus 1 more112); sensitivity analyses showed that removing any of those trials would not significantly change the findings. Finally, we found evidence supporting efficacy of some of the medications, whereas they concluded that evidence was inadequate to support the efficacy of any medications, including SSRIs. We believe that differences in approach to data synthesis (quantitative versus qualitative approach), similar to what we describe above for EMDR, are likely a main part of the explanation for the different conclusions. Of note, other recent systematic reviews, such as those from the Cochrane Collaboration,194 have also concluded that evidence supports the efficacy of some medications.

Compared with some of the guidelines based on expert consensus and less structured literature reviews (e.g., APA, ISTSS), we reached different conclusions regarding the efficacy of stress inoculation training. For example, the APA guideline supports stress inoculation with moderate clinical confidence (Grade II in the APA system), while we concluded that there was insufficient evidence to determine its efficacy based on one medium risk of bias trial (N=41 total subjects in the stress inoculation training and waitlist arms, combined).49 We also identified one study we rated as high risk of bias (N=27 total subjects in the stress inoculation training and waitlist arms, combined).85 The APA used a different approach to data synthesis (qualitative rather than quantitative) and relied more on expert opinion to develop guidelines. The articles cited in the APA report regarding the efficacy of stress inoculation training are a narrative review,195 the trial that we excluded due to high risk of bias,85 and a nonrandomized trial196 that enrolled subjects with rape-related fear and anxiety. We excluded the nonrandomized trial from our review because it did not require subjects to have a PTSD diagnosis (subjects were not assessed to determine if they met criteria for PTSD at any point in time) and because it did not meet our study design criteria for admissible evidence. Of note, the study did not report any outcome measures of PTSD symptoms.

### Applicability

The included studies assessing efficacious treatments generally enrolled subjects from outpatient settings who had severe to extreme PTSD symptoms. Most studies included participants with chronic PTSD. However, studies inconsistently reported, and had wide variation in, the time between incident trauma and trial entry. The mean age of subjects was generally in the 30s to 40s, but some studies enrolled slightly older populations. The studies included a wide range of trauma exposures, and many enrolled a heterogeneous group of subjects with a variety of index trauma types. Evidence was insufficient to determine whether findings are applicable to all those with PTSD or whether they are applicable only to certain groups. Evidence was insufficient to determine whether any treatment approaches are more or less effective for specific subgroups, including victims of particular types of trauma (see KQ 5).

We recognize the hypothesis that treatments proven to be effective for adults with PTSD should be applicable to all adults with PTSD, but we did not find evidence to confirm or refute this hypothesis. For example, there was often very little evidence from subjects with combat-related trauma that contributed to assessments of the efficacious treatments—making it difficult to determine with any certainty whether findings are applicable to adults with PTSD from combat-related trauma. For example, none of the included studies of paroxetine or venlafaxine enrolled a population with combat-related trauma. In addition, just one included trial for each of the following treatments focused on combat-related trauma: EMDR (N=35),44 CBT-mixed (N=45),65 and topiramate (N=67).137 For each of the following, two trials focused on combat-related trauma: cognitive processing therapy (total N=119),70,74 exposure-based therapy (total N=370;^92,93^ another study of exposure-based therapy enrolled those with combat- and terror-related PTSD90), and fluoxetine (total N=365).159,162 Three trials assessing sertraline enrolled a majority of subjects with combat-related trauma (total N=281).168–170

Similarly, we did not find evidence to confirm or refute whether treatments are more or less efficacious for many other subgroups, including gender groups, racial or ethnic minorities, refugees, first responders, disaster victims, or for those with certain coexisting conditions, different PTSD symptoms, complex PTSD, exposure to childhood trauma, repeat victimization, or different levels of severity at presentation. Although many studies did not exclude subjects in these subgroups (e.g., those with a history of multiple past traumas, service-connected disability, or coexisting psychiatric conditions such as depression), studies generally did not report whether interventions were efficacious for such subjects either.

Providers may wonder about the applicability of the results to populations suffering from substance use disorders or from other psychiatric and medical comorbidities. In general, many studies excluded those with substance use disorders, cognitive disorders, and “serious” medical conditions. In the following paragraphs, we provide some information about how many studies set various exclusion criteria, first addressing substance use disorders for the trials of psychological treatments and then pharmacological treatments; then addressing other comorbidities.

For psychological treatments, 20 trials (35%) meeting our inclusion criteria excluded persons who had “substance dependence,” 18 trials (32%) excluded persons who had “current” or “active” substance abuse or dependence, and two trials (3.5%) excluded those who had active symptoms related to current substance use (withdrawal, intoxication, or other physical symptoms).57,121 Four studies (7.0%) enrolled populations with substance use disorders and PTSD.33,117–119 The remaining studies did not specify any inclusion or exclusion criteria based on substance use.

For the pharmacologic studies, 20 trials (59%) excluded persons who met criteria for alcohol or substance abuse or dependence within a specified time before the start of the study (3 or 6 months). Of the remaining studies, four (11.8%) excluded those with “current” or “active” substance abuse or dependence, five (15%) excluded those with substance dependence only (either implying or stating specifically that abuse was not an exclusion criteria), two (6%) enrolled a population with comorbid PTSD and alcohol dependence, five (15%) required a negative urine-drug screen in addition to other substance use exclusion criteria based on history, and three (9%) did not specify any exclusion criteria related to alcohol or substance use.

Regarding some of the other comorbidities, among the studies of psychological treatments, 47 (82%) excluded those with any psychosis (schizophrenia, current or past history of “psychosis”), 16 (28%) excluded those with bipolar I or II or history of mania, 2 (4%) excluded those with an anxiety disorder, 4 (7%) excluded those with depression, and 2 (4%) excluded those with an eating disorder. These data do not include studies that specified exclusion based only on severe comorbid disorders; for example, some included those with depression but excluded those with “depression severe enough to require immediate treatment.” Thirty-two studies (56%) excluded participants determined to be at high risk of suicide or self-harm, whereas 13 studies (23%) excluded those with homicidal ideation or those at a “high risk of external violence.” Thirty studies (53%) excluded those with any cognitive disorder, including “organic mental disorder,” “organic mental dysfunction,” “cognitive dysfunction,” “traumatic brain injury,” or “mental retardation.”

In the pharmacologic studies, 24 (71%) excluded those with any history of bipolar disorder or mania; 25 (74%) excluded those with schizophrenia, “psychotic disorder,” or any “prior history of psychosis”; 10 excluded those with an anxiety disorder; and 9 excluded those with “depression.” As above, these counts do not include studies that specified exclusion criteria based on the severity of comorbid disease (e.g., this count does not include those who only excluded bipolar disorder if the person had “active, untreated bipolar disorder”). Nineteen studies (56%) excluded participants determined to be at high risk of suicide or self-harm, and 15 studies (44%) excluded those with homicidal ideation or those at “high risk of external violence.” Seventeen studies (50%) excluded persons with any cognitive disorder (“organic mental disorder or dysfunction,” “cognitive dysfunction,” or “traumatic brain injury”).

## Implications for Clinical and Policy Decisionmaking

Although the evidence supports the efficacy of several types of psychological and pharmacological treatments for PTSD, clinical uncertainty exists about what treatment to select for individual patients. Practical considerations, such as presence or lack of availability of psychological treatments and patient preferences, may guide treatment decisions.17 If numerous treatments are available and patients have no preference for a particular treatment, decisionmaking in the absence of direct evidence from head-to-head trials can be challenging. Nevertheless, choices must be made for patients needing treatments. Given the findings, the magnitude of benefit and SOE found for exposure therapy supports its use as a first-line treatment for PTSD. However, other factors must be considered in selecting a treatment for PTSD, including patient preference, access to treatment, and clinical judgment about the appropriateness of an intervention. For example, a majority of the studies reviewed in this report excluded patients with presenting issues such as substance dependence or suicidality. Most clinicians would agree that stabilization of these issues should occur before initiating trauma-focused therapy.

If one decides to pursue treatment with a medication, paroxetine and venlafaxine may have the best evidence supporting their efficacy—unlike the other medications with evidence of efficacy for improving PTSD symptoms, they both also have evidence of efficacy for achieving remission (i.e., no longer having symptoms), with NNTs ~8 to achieve one remission. In addition, paroxetine has evidence of efficacy for improving depression symptoms and functional impairment (moderate SOE), and venlafaxine has evidence of efficacy for improving depression symptoms, quality of life, and functional impairment (moderate SOE). Further, our network meta-analysis found paroxetine to be one of the best treatments.

Evidence was insufficient to determine whether clinicians should begin with combinations of psychological and pharmacological therapies when initiating treatment. The only trial (N=37) that was very relevant for this issue (see KQ 4) found greater improvement in PTSD symptoms for adults treated with prolonged exposure plus an SSRI than for those treated with prolonged exposure alone.183 The evidence was limited by unknown consistency (single trial), attrition, and lack of precision. Until further research is available to confirm or refute the findings, initial treatment with combinations of psychological and pharmacological therapies does not seem to be supported by the evidence.

We found little evidence about which treatments are more or less effective for various subgroups of adults with PTSD—including those with different index trauma types. Further research may identify particular patient characteristics that clearly increase the chances of responding or not responding to certain treatments.

Access to and availability of treatments may vary for individuals and by geography. For example, among all the potential psychological treatments for PTSD, the U.S. Department of Veterans Affairs offers prolonged exposure therapy and cognitive processing therapy for its patients.197 Many people with PTSD never seek or receive treatment—reasons may include symptoms of the disorder itself (e.g., avoidance, anxiety), particular patient characteristics that increase or decrease the likelihood of seeking treatment (e.g., age, marital status, race, comorbidities), lack of availability of treatments, stigma, costs, transportation, or unfamiliarity with accessing treatment.198–200

## Limitations of the Comparative Effectiveness Review Process

The scope of this review was limited to studies that enrolled adults with PTSD. The AHRQ has commissioned a separate report focused on children.201 We did not attempt to review literature on treatments for acute stress disorder or on interventions aimed to prevent PTSD for people exposed to trauma. Our review did not include an assessment of some factors important for clinical decision making, such as adherence or interactions with other therapies that could influence real world effectiveness of treatments. Further, we did not review literature on complementary and alternative medicine treatments.

For KQs 1 through 5, we included randomized controlled trials (RCTs) with no sample size limit. We did not allow for inclusion of observational studies because observational studies that compare the effectiveness of various treatments for PTSD have a very high risk of selection bias and confounding. We believe that the results of such studies should not be used to make decisions about efficacy or effectiveness. For KQ 6, focused on harms, we allowed for observational studies to be included if they were prospective cohort studies or case-control studies with a sample size of 500 or greater. We set this criteria for two main reasons: (1) our topic refinement process found a large number of RCTs in this field and we weighed the tradeoffs between increasing comprehensiveness by reviewing all possible observational studies that present harms information and the decreased quality that may occur from increased risk of bias, as well as considering our resource and time constraints; and (2) related to the previous point, we decided to include large observational studies with the lowest potential risk of bias to supplement the trial literature. Nevertheless, this approach may have led to the exclusion of some observational studies that could provide useful information.

For harms, useful information could possibly have been provided by studies conducted in other populations (i.e., those without PTSD). For example, many studies of some medications reviewed in this report enrolled patients with depression. Such studies could provide important information about adverse effects of the medications.

Our network meta-analysis used methods that do not rely solely on placebo-controlled trials; it allowed for the inclusion of data from head-to-head studies or those with active comparators. However, our network meta-analysis was limited primarily to indirect evidence. Very few head-to-head trials were identified for inclusion. Therefore, findings of the network meta-analysis should be interpreted with caution. Indirect comparisons, in general, have to be interpreted cautiously because the validity of results is based on assumptions that cannot be verified, particularly the assumption that study populations were similar.

Finally, publication bias and selective reporting are potential limitations. Although we searched for unpublished studies and unpublished outcomes, and did not find direct evidence of either of these biases, many of the included trials were published prior to the availability of trial registries (e.g., clinicaltrials.gov) that would allow for greater certainty in determining the potential for either type of bias.

## Limitations of the Evidence Base

The evidence base was inadequate to draw conclusions for many of the questions or subquestions of interest. In particular, we found very few head-to-head studies of treatments. As highlighted in the Key Findings and Strength of Evidence section, too few (and sometimes zero) studies with low- or medium-risk of bias were available to determine (1) whether some of the psychological and pharmacological treatments are efficacious; (2) comparative effectiveness of most of the treatments; (3) whether treatments differ in effectiveness for specific groups, such as those with different types of trauma; and (4) risk of adverse effects for most treatments.

Many of the trials assessing treatments for adults with PTSD had methodological limitations introducing some risk of bias. We excluded 46 articles from our main data synthesis because of high risk of bias. The available evidence for many of the treatments of interest, especially many of the medications, was limited to few low- or medium-risk-of-bias trials. High risk of bias was most frequently due to high rates of attrition or differential attrition and inadequate methods used to handle missing data. Another common methodological limitation was the lack of masking of outcome assessors. High attrition rates are not uncommon in studies of psychiatric conditions.186, 187,202,203 It is unknown whether the attrition rates were due to the underlying condition—given that some of the key features of PTSD are avoidance, loss of interest, and detachment—or whether the attrition rates were related to the treatments (e.g., adverse effects, worsening of symptoms).

Heterogeneity of populations enrolled in the included studies makes it challenging to determine whether findings are applicable to all adults with PTSD or only to certain subgroups (e.g., those with particular trauma types). Many studies enrolled subjects with a wide variety of trauma types (e.g., sexual abuse, nonsexual abuse, combat, motor vehicle accident, natural disaster). We generally found insufficient evidence to determine whether treatments differ in efficacy for specific groups (see Applicability section).

Reporting of previous treatments and ongoing treatments (i.e., co-interventions) was variable across the included studies. We were often unable to determine whether subjects had received any previous treatments for PTSD and whether they were allowed to continue treatments that might be effective for PTSD during studies. In many cases, studies enrolled a heterogeneous group of subjects currently receiving various treatments that have potential benefits for PTSD.

Descriptions of usual care or treatment as usual were often limited for the included studies of psychological treatments. Interventions received by the groups were often not described in much (or any) detail, making it difficult to determine whether the people in those groups were receiving any care at all. In many studies, the groups seemed to be very similar to waitlist groups (except that the subjects were not on a waitlist to receive an intervention later). For analyses of the efficacy of psychological interventions, our main analyses included studies with both waitlist and usual care (or treatment as usual) control groups. We stratified our meta-analyses by comparison group to show how the effect size and confidence interval would differ if we only included studies with a waitlist control, as opposed to including those with both waitlist and usual care controls. Of note, pooled effect sizes were very similar when combining studies with waitlist and usual care control groups and when only combining studies with waitlist control groups. Also, the effect sizes were sometimes slightly greater when combining studies with waitlist and usual care control groups than when only combining studies with waitlist control groups (e.g., PTSD symptoms for exposure therapy), and other times they were slightly lower (e.g., PTSD symptoms for cognitive processing therapy).

Heterogeneity of outcome measures used in the included studies also posed some challenges. For example, many different measures of PTSD symptoms were used (e.g., CAPS, Davidson Trauma Scale [DTS], Impact of Event Scale [IES]). In addition, some measures have several versions, such as the CAPS, which has evolved over the past decades into its current form.40 It was sometimes unclear which version of a measure a study used.

Also, the definitions of loss of PTSD diagnosis and remission were somewhat heterogeneous. They were assessed using several different instruments across the studies. Complete explanations of the approach to assessing remission or loss of PTSD diagnosis were not always provided. For example, it was sometimes implied, but not explicitly stated, that loss of diagnosis was determined by assessment of DSM diagnostic criteria or by using a CAPS score (or another scale, such as the PSS) cutoff indicative of PTSD diagnosis. Further, many studies did not clearly report specific score cutoffs used to define loss of diagnosis or remission when reporting the results.

For many treatments, studies did not include any followup after completion of treatment to assess whether benefits were maintained. This was particularly true for the pharmacological treatments, because trials generally reported outcomes after 8 to 12 weeks of treatment. In addition, pharmaceutical companies funded the majority of trials assessing medications.

The timing of outcome assessment in the trials of psychological treatments was more heterogeneous than for the pharmacological trials. This was due in part to the differences in the duration of psychological treatments, as trials generally assessed outcomes after completion of treatment. For some psychological trials, post-treatment outcome measures were reported after a specified number of sessions, rather than a specific time period (see Appendix F for details). For such studies, if the study reported “posttreatment” as the timing of outcome assessment, we used the duration of treatment to indicate the timing (although we realize it may have been shortly thereafter, but such studies didn’t always report the specific timing). It does not appear that the timing of post-treatment outcome measures has an influence on the overall conclusions, but the variation in timing of outcome assessment does contribute to the overall heterogeneity.

One criticism of psychological treatment trials has been the possibility of “allegiance bias”—the potential for contamination or distortion of results because of the investigators’ theoretical perspective or treatment preferences.204 One marker of allegiance to a treatment preference is when the developer of the method is a primary author in the study of that method. For some of the psychological therapy interventions, the developer of the methods seemed to be an author on the majority of studies, such as narrative exposure therapy125–127 and brief eclectic psychotherapy.21,123 For this report, we did not explore allegiance during our review of the included studies, and it is unclear what effect, if any, this issue has on the overall validity of the results.

## Research Gaps

We identified numerous gaps in the evidence that future research could address. Many of these gaps are highlighted in the Key Findings and Strength of Evidence section and the Limitations of the Evidence Base section. Of note, these gaps relate only to the key questions addressed by this report, and they should not eliminate a wide range of potentially important PTSD-related research that falls outside of the scope of our KQs. Table 52 summarizes the gaps and potential future research that could address the gaps.

Table 52 Evidence gaps for future research, by Key Question

KQ | Evidence Gap | Potential Future Research
1 | Most of the head-to-head evidence was insufficient to determine whether psychological treatments differ in effectiveness. | Future studies could focus on comparisons between the psychological treatments with the best evidence of efficacy (e.g., exposure compared with cognitive processing therapy).
1 | Evidence was insufficient to determine efficacy of some psychological treatments. | Future studies could evaluate promising therapies that have some evidence suggesting possible efficacy or could evaluate new therapies that may be applicable to broader populations or to specific populations (e.g., those with particular comorbid conditions).
2 | Head-to-head comparative evidence was insufficient to determine whether pharmacological treatments differ in effectiveness. | Future studies could focus on comparisons between the medications with moderate strength of evidence supporting their efficacy (fluoxetine, paroxetine, sertraline, topiramate, and venlafaxine).
2 | Evidence was insufficient to determine efficacy of many medications. | Future studies could evaluate medications that have some evidence (often from 1 or 2 small trials) suggesting possible efficacy (e.g., prazosin, olanzapine, mirtazapine) or medications that have not yet been studied with some theoretical basis to support their potential efficacy.
3 | Head-to-head evidence was insufficient to determine comparative effectiveness of psychological and pharmacological treatments. | Future studies could focus on comparisons between the psychological and pharmacological treatments with the best evidence of efficacy (e.g., exposure therapy compared with paroxetine).
4 | Evidence was insufficient to determine comparative effectiveness of combinations of treatments (psychological plus pharmacological) compared with either one alone. | Future studies could focus on comparisons between combinations of the psychological and pharmacological treatments with the best evidence of efficacy compared with either one alone (e.g., exposure plus paroxetine compared with either one alone).
5 | Evidence was insufficient to make definitive conclusions about whether any treatment approaches are more effective for victims of particular types of trauma. | Future trials could include prespecified subgroup analyses to explore differences in effectiveness for specific subgroups. Or, trials could enroll patients all with the same type of trauma to determine whether treatments are effective for that group.
6 | For psychological treatments, the vast majority of studies reported no information about adverse effects. | Future studies could include validated measures of adverse effects, including assessment of mortality, suicide, suicidal ideation, self-harmful behaviors, and hospitalizations.
6 | For pharmacological treatments, few studies reported any information about mortality, suicide, suicidal ideation, self-harmful behaviors, or hospitalizations. | Future studies could include validated measures of adverse effects, including assessment of mortality, suicide, suicidal ideation, self-harmful behaviors, and hospitalizations.
6 | For pharmacologic treatments, most of the evidence for specific adverse effects was insufficient to determine whether the risk was increased, often primarily because of lack of precision. | Future studies could include validated measures of adverse effects to assess the risk of common adverse effects that might limit use of the medications (e.g., headache, gastrointestinal adverse effects, sexual adverse effects).

EMDR = eye movement desensitization and reprocessing

Note: Within the gaps highlighted above, future research could address how various treatments compare for initial treatment and for treatment-refractory populations.

In addition to the evidence gaps identified here, other considerations for future research involve methodological improvements. Development of methods to minimize attrition could help to reduce the risk of bias in studies of treatments for adults with PTSD.205 Also, using best approaches to handling of missing data, such as multiple imputation, could reduce risk of bias. To more completely assess benefits of treatments, studies could include measures of remission and loss of PTSD diagnosis (frequently not reported) in addition to measures of PTSD symptoms (more commonly reported). Also, previous studies rarely assessed adverse effects with adequate rigor. Future studies could include longer followup of subjects, validated measures of adverse events and methods for systematically capturing adverse events, and more complete reporting of adverse events. Moreover, methods to minimize attrition and to obtain more complete followup data will be important to better understand the risk of adverse effects for treatments.

For potential future comparative effectiveness research, perhaps head-to-head trials should be conducted by investigators at clinical equipoise and free of any vested interest in particular treatments. Some of the current literature was conducted by investigators with strong potential conflicts of interest (e.g., developers of a particular treatment).

## Conclusions

Several psychological and pharmacological treatments have at least moderate SOE supporting their efficacy for improving outcomes for adults with PTSD: exposure-based therapy, cognitive processing therapy, CT, CBT-mixed therapies, EMDR, narrative exposure therapy, fluoxetine, paroxetine, sertraline, topiramate, and venlafaxine. Head-to-head evidence was insufficient to determine the comparative effectiveness of these treatments. For exposure-based therapy, cognitive processing therapy, CT, CBT-mixed therapies, and EMDR, effect sizes for improving PTSD symptoms were large (reduction in CAPS from 28.9 to 32.2; Cohen’s d from 1.08 to 1.40), and NNTs to achieve loss of diagnosis were 4 or less. For fluoxetine, paroxetine, sertraline, topiramate, and venlafaxine, effect sizes for improving symptoms were smaller (reduction in CAPS compared with placebo from 4.9 to 15.5; Cohen’s d between 0.25 and 0.49 for fluoxetine, paroxetine, sertraline, and venlafaxine; Cohen’s d 0.96 for topiramate, but with very wide confidence interval from −1.89 to −0.03). Paroxetine and venlafaxine also had evidence of efficacy for inducing remission, with NNTs of ~8. Evidence was generally insufficient to determine whether any treatment approaches are more effective for victims of particular types of trauma or to determine comparative risks of adverse effects.