# Strength of Evidence

## Key Question 1

Table G-1 Cognitive processing therapy compared with inactive controls (waitlist or usual care)

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction: mean change from baseline to end of treatment in CAPS
4; 299 | Medium; RCTs | Consistent^a^ | Direct | Imprecise^a^ | −35.9 (−52.8 to −18.97) vs. WL (3 studies, N=240); −32.2 (−46.3 to −18.05) when also including the study comparing with UC | Moderate
Remission (no longer having symptoms)
0; 0 | NA | NA | NA | NA | NA | Insufficient
Loss of Diagnosis
4; 299 | Medium; RCTs | Consistent^b^ | Direct | Precise | RD 0.52 (0.37 to 0.67) vs. WL; NNT 1.9; RD 0.44 (0.26 to 0.62) when also including the study comparing with UC | Moderate
Prevention/reduction of comorbid depression: mean change from baseline to end of treatment in BDI
4; 299 | Medium; RCTs | Consistent^b^ | Direct | Precise | −11.9 (−18.9 to −4.9) vs. WL; −10.7 (−16.5 to −4.9) when also including the study comparing with UC | Moderate
Prevention/reduction of comorbid anxiety
2; 119 | Medium; RCTs | Inconsistent | Direct | Imprecise | Conflicting results from the two trials | Insufficient
Quality of Life
1; 59 | Medium; RCT | NA, single study | Direct | Imprecise | Significant time by condition interactions for social quality of life measures, but not for physical quality of life measures | Insufficient
Disability/functional impairment: change in SDS from baseline
0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work or return to active duty
0; 0 | NA | NA | NA | NA | NA | Insufficient

a Although the meta-analysis had considerable statistical heterogeneity (I^2^=86.5%), the direction of effects were consistent, the differences were only in the magnitude of benefit; all trials found moderate or large magnitudes of benefit. The lack of precision involves whether the magnitude of benefit is moderate or large. Therefore, we graded the SOE as moderate rather than low despite the lack of precision.

b Like the meta-analysis for PTSD symptoms, the meta-analyses for loss of diagnosis and for BDI had considerable statistical heterogeneity, but the direction of effects were consistent, the differences were only in the magnitude of benefit; all trials found moderate or large magnitudes of benefit.

Abbreviations: CI = confidence interval; CPT = cognitive processing therapy; CR = cognitive restructuring; NA = not applicable; NNT = number needed to treat; RA = repeated assessments (a type of waitlist control group); RCT = randomized controlled trial; RD = risk difference; UC = usual care; WL = waitlist

Table G-2 Cognitive therapy (not including cognitive processing therapy) compared with inactive controls (waitlist, self-help booklet, usual care)

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction: mean change from baseline to end of treatment b
3^a^; 221 | Medium; RCTs | Some inconsistency^c^ (I^2^=79.6%) | Direct | Imprecise | SMD: −1.22 (−1.91, −0.53) SMD: −1.54 (−2.17, −0.92) when only compared with WL (2 trials) | Moderate
Remission (no longer having symptoms)
0; 0 | NA | NA | NA | NA | NA | Insufficient
Loss of Diagnosis
3^a^; 221 | Medium; RCTs | Some inconsistency^c^ (I^2^=84.7%) | Direct | Imprecise | RD: 0.51 (0.24, 0.78); NNT 2 RD: 0.66 (0.50, 0.82) when only compared with WL (2 trials) | Moderate
Prevention/reduction of comorbid depression: mean change from baseline to end of treatment in BDI
3^a^; 221 | Medium; RCTs | Consistent | Direct | Imprecise | SMD: −0.91 (−1.20, −0.62); WMD: −8.34 (−10.8, −5.85) SMD: −1.06 (−1.52, −0.60) when only compared with WL (2 trials) | Moderate
Prevention/reduction of comorbid anxiety: mean change from baseline to end of treatment in BAI
3^a^; 221 | Medium; RCTs | Consistent | Direct | Imprecise | SMD: −0.93 (−1.36, −0.50); WMD: −9.22 (−11.9, −6.5) SMD: −1.20 (−1.67, −0.73) when only compared with WL (2 trials) | Moderate
Quality of Life: SF-12
1; 108 | Medium; RCT | Unknown, single study | Direct | Imprecise | Better quality-of-life outcomes for CT group than usual care group for the Physical Component (p=0.002), but not for the Mental Component (p=0.13). | Insufficient
Disability/functional impairment: change in SDS from baseline
2; 113 | Medium; RCTs | Consistent | Direct | Imprecise | SMD: −1.13 (−1.76, −0.51); WMD −2.66 (−4.0, −1.33) SMD: −1.41 (−2.41, −0.41) when only compared with WL (2 trials) | Moderate
Return to work or return to active duty
0; 0 | NA | NA | NA | NA | NA | Insufficient

a Included trials compared CT with waitlist (Ehlers 2003 and Ehlers 2005), a self-help booklet (Ehlers 2003), and usual care (Muesser 2008).

b Data were based on meta-analysis of CAPS total for Muesser 2008 and CAPS-intensity for the Ehlers 2003 and 2005 studies.

c Direction of effects were consistent; magnitude of effects ranged from very large to small

Abbreviations: CI = confidence interval; NA = not applicable; NNT = number needed to treat; RCT = randomized controlled trial; RD = risk difference; WL = waitlist

Table G-3 Stress inoculation training compared with waitlist

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction: PSS-I
1; 41 | Medium; RCT | NA, single study | Direct | Imprecise | Baseline PSS-I: 29.4 vs. 32.9 for WL; Endpoint: 12.9 vs. 26.9; p<0.05 | Insufficient
Remission (no longer having symptoms
0; 0 | NA | NA | NA | NA | NA | Insufficient
Loss of Diagnosis
1; 41 | Medium; RCT | NA, single study | Direct | Imprecise | 42% vs. 0%, p<0.001 | Insufficient
Prevention/reduction of comorbid depression: BDI
1; 41 | Medium; RCT | NA, single study | Direct | Imprecise | Baseline: SIT 21.7 vs. WL 25.2; Endpoint: 10.1 vs. 22.1; p<0.05 | Insufficient
Prevention/reduction of comorbid anxiety: STAI
1; 41 | Medium; RCT | NA, single study | Direct | Imprecise | Baseline: SIT 51.5 vs. WL 51.4; Endpoint: 39.1 vs. 50.4; p=0.14 | Insufficient
Quality of Life
0; 0 | NA | NA | NA | NA | NA | Insufficient
Disability/functional impairment
0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work or return to active duty
0; 0 | NA | NA | NA | NA | NA | Insufficient

Abbreviations: CI = confidence interval; NA = not applicable; PSS-I = Posttraumatic Stress Disorder Symptom Scale-Interview; RCT = randomized controlled trial

Table G-4 Relaxation compared with treatment as usual

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction
1; 25 | Medium; RCT | NA, single study | Direct | Imprecise | No benefit found for 3 different measures | Insufficient
Remission (no longer having symptoms)
0; 0 | NA | NA | NA | NA | NA | Insufficient
Loss of Diagnosis
1; 25 | Medium; RCT | NA, single study | Direct | Imprecise | Trial did not report data for the inactive comparator group | Insufficient
Prevention/reduction of comorbid depression: BDI
1; 25 | Medium; RCT | NA, single study | Direct | Imprecise | Results trend in favor of relaxation | Insufficient
Prevention/reduction of comorbid anxiety: STAI
1; 25 | Medium; RCT | NA, single study | Direct | Imprecise | Results trend in favor of relaxation | Insufficient
Quality of Life
0; 0 | NA | NA | NA | NA | NA | Insufficient
Disability/functional impairment
0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work or return to active duty
0; 0 | NA | NA | NA | NA | NA | Insufficient

Abbreviations: CI = confidence interval; NA = not applicable; RCT = randomized controlled trial

Table G-5 Relaxation compared with cognitive restructuring

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction: percentage of patients improved (IES)
1; 34^a^ | Medium; RCT | NA, single study | Direct | Imprecise | 20% vs. 50%, p=0.04 | Insufficient
Remission (no longer having symptoms)
0; 0 | NA | NA | NA | NA | NA | Insufficient
Loss of Diagnosis
1; 34^a^ | Medium; RCT | NA, single study | Direct | Imprecise | 55% vs. 65%, p=NS | Insufficient
Prevention/reduction of comorbid depression: BDI, mean change scores (improvement)
1; 34^a^ | Medium; RCT | NA, single study | Direct | Imprecise | 7 (3 to 11) vs. 17 (11 to 22) | Insufficient
Prevention/reduction of comorbid anxiety
0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of Life
0; 0 | NA | NA | NA | NA | NA | Insufficient
Disability/functional impairment: End-state functioning (percent of subjects improved)
0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work or return to active duty
0; 0 | NA | NA | NA | NA | NA | Insufficient

a Total trial N was 81. Subjects were randomized to PE (23), CR (13), CBT- Mb (CR+PE) (24), or relaxation (21).3

Abbreviations: CI = confidence interval; NA = not applicable; RCT = randomized controlled trial

Table G-6 Exposure-based therapies compared with inactive controls (waitlist or usual care)

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction: CAPS
7; 387 | Medium; RCTs | Consistent | Direct | Precise | SMD −1.27 (−1.54 to −1.00) | High
Remission (no longer having symptoms)
1; 284 | Medium; RCT | NA, single study | Direct | Imprecise | OR 2.43 (1.10 to 5.37) | Insufficient
Loss of Diagnosis
3; 197 | Medium; RCTs | Inconsistent (I^2^=86.5%) | Direct | Imprecise | RD 0.66 (0.42 to 0.91); NNT of 1.5 | Moderate^a^
Prevention/reduction of comorbid depression: BDI
6; 363 | Medium; RCTs | Consistent (I^2^=0%) | Direct | Precise | WMD −8.2 (−10.3 to −6.1) | High
Prevention/reduction of comorbid anxiety
0; 0 | N/A | N/A | N/A | N/A | N/A | Insufficient
Quality of Life
0; 0 | N/A | N/A | N/A | N/A | N/A | Insufficient^b^
Disability/functional impairment
2; 221 | Medium; RCTs | Inconsistent | Direct | Imprecise | Cohen’s d 0.8 at 4 wks, 0.6 at 8 wks from one trial (N=31); numerically greater improvements on the Social Adjustment Scale for another trial (N=190) exposure and exposure plus CR than for waitlist, but the differences were not statistically significant. | Insufficient
Return to work or return to active duty
0; 0 | N/A | N/A | N/A | N/A | N/A | N/A

a With the very large effect sizes, we graded the SOE as moderate despite the inconsistency; the direction of effects was the same and the inconsistency was only in magnitude of benefit (which was large or very large in the three trials).

b One study comparing prolonged exposure with present centered therapy reported a quality of life outcome, finding that groups did not differ across time (Cohen’s d 0.09, NS). No studies with a waitlist or usual care comparator reported quality of life outcomes.

Abbreviations: CI = confidence interval; NA = not applicable; RCT = randomized controlled trial

Table G-7 Exposure-based therapy compared with cognitive restructuring

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction: CAPS
2; 100 | Medium; RCTs | Consistent (I^2^=0%) | Direct | Imprecise | WMD 4.8 (−4.5 to 14.2) | Insufficient
Remission (no longer having symptoms)
0; 0 | NA | NA | NA | NA | NA | Insufficient
Loss of Diagnosis
2; 100 | Medium; RCTs | Consistent (I^2^=0%) | Direct | Imprecise | RD 0.13 (−0.06 to 0.32) | Insufficient
Prevention/reduction of comorbid depression: BDI
2; 100 | Medium; RCTs | Consistent (I^2^=0%) | Direct | Imprecise | WMD 2.75 (−1.94 to 7.43) | Insufficient
Prevention/reduction of comorbid anxiety
1; 72 | Medium; RCT | NA, single study | Direct | Imprecise | No significant difference | Insufficient
Quality of Life
0; 0 | NA | NA | NA | NA | NA | Insufficient
Disability/functional impairment
0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work or return to active duty: % of subjects actively working at 6 month follow up
1; 72 | Medium; RCT | NA, single study | Direct | Imprecise | 44% vs. 37% | Insufficient

Abbreviations: CI = confidence interval; NA = not applicable; RCT = randomized controlled trial

Table G-8 Exposure-based therapy compared with cognitive processing therapy

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction: CAPS
1; 124 | Medium; RCT | NA, single study | Direct | Imprecise | WMD 3.97 (−5.95 to 13.9) | Insufficient
Remission (no longer having symptoms)
0; 0 | NA | NA | NA | NA | NA | Insufficient
Loss of Diagnosis
1; 124 | Medium; RCT | NA, single study | Direct | Imprecise | RD 0.00 (−0.18 to 0.18) | Insufficient
Prevention/reduction of comorbid depression: BDI
1; 124 | Medium; RCT | NA, single study | Direct | Imprecise | WMD 2.94 (−0.75 to 6.63) | Insufficient
Prevention/reduction of comorbid anxiety
0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of Life
0; 0 | NA | NA | NA | NA | NA | Insufficient
Disability/functional impairment
0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work or return to active duty: % of subjects actively working at 6 month follow up
0; 0 | NA | NA | NA | NA | NA | Insufficient

Abbreviations: CI = confidence interval; NA = not applicable; RCT = randomized controlled trial

Table G-9 Exposure-based therapy compared with stress inoculation training

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction: CAPS
1; 51 | Medium; RCT | NA, single study | Direct | Imprecise | SMD −0.14 (−0.69 to 0.41) | Insufficient
Remission (no longer having symptoms)
0; 0 | NA | NA | NA | NA | NA | Insufficient
Loss of Diagnosis
1; 51 | Medium; RCT | NA, single study | Direct | Imprecise | RD 0.18 (−0.09 to 0.45) | Insufficient
Prevention/reduction of comorbid depression: BDI
1; 51 | Medium; RCT | NA, single study | Direct | Imprecise | WMD −0.15 (−5.8 to 5.5) | Insufficient
Prevention/reduction of comorbid anxiety: STAI
0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of Life
0; 0 | NA | NA | NA | NA | NA | Insufficient
Disability/functional impairment
0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work or return to active duty
0; 0 | NA | NA | NA | NA | NA | Insufficient

Abbreviations: NA = not applicable

Table G-10 Exposure-based therapy compared with relaxation

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction: CAPS
2; 85 | Medium; RCTs | Consistent | Direct | Imprecise | WMD −9.7 (−22.3 to 2.9) | Insufficient
Remission (no longer having symptoms)
0; 0 | NA | NA | NA | NA | NA | Insufficient
Loss of Diagnosis
2; 85 | Medium; RCTs | Consistent | Direct | Precise | RD 0.31 (0.04 to 0.58) | Moderate
Prevention/reduction of comorbid depression: BDI
2; 85 | Medium; RCTs | Consistent | Direct | Precise | WMD −5.5 (−10.2 to −0.79) | Moderate
Prevention/reduction of comorbid anxiety: STAI
0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of Life
0; 0 | NA | NA | NA | NA | NA | Insufficient
Disability/functional impairment
0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work or return to active duty
0; 0 | NA | NA | NA | NA | NA | Insufficient

Abbreviations: NA = not applicable

Table G-11 Exposure-based therapy compared with EMDR

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction: CAPS
2; 91 | Medium; RCTs | Consistent | Direct | Imprecise | No difference EMDR and PE | Insufficient
Remission (no longer having symptoms)
0; 0 | NA | NA | NA | NA | NA | Insufficient
Loss of Diagnosis
2; 91 | Medium; RCTs | Inconsistent | Direct | Imprecise | RD 0.14 (−0.01 to 0.29) | Insufficient
Prevention/reduction of comorbid depression: BDI
2; 91 | Medium; RCTs | Consistent | Direct | Imprecise | No difference EMDR and PE | Insufficient
Prevention/reduction of comorbid anxiety: STAI
1; 50 | Medium; RCT | NA, single study | Direct | Imprecise | No difference EMDR and PE on state anxiety | Insufficient
Quality of Life
0; 0 | NA | NA | NA | NA | NA | Insufficient
Disability/functional impairment
0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work or return to active duty
0; 0 | NA | NA | NA | NA | NA | Insufficient

Abbreviations: CI = confidence interval; NA = not applicable; PE = prolonged exposure; RCT = randomized controlled trial

Table G-12 Exposure-based therapy compared with exposure therapy + cognitive restructuring

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction: CAPS
3; 259 | Medium; RCTs | Inconsistent | Direct | Imprecise | SMD 0.25 (−0.29 to 0.80) | Insufficient
Remission (no longer having symptoms)
0; 0 | NA | NA | NA | NA | NA | Insufficient
Loss of Diagnosis
3; 146 | Medium; RCTs | Consistent (I^2^=0%) | Direct | Precise | RD −0.01 (−0.17 to 0.14) | Moderate
Prevention/reduction of comorbid depression: BDI
4; 299 | Medium; RCTs | Inconsistent (I^2^=54.4%) | Direct | Imprecise | WMD 2.78 (−1.68 to 7.25) | Insufficient
Prevention/reduction of comorbid anxiety: STAI
2; 99 | Medium; RCTs | Consistent | Direct | Imprecise | No difference between groups | Insufficient
Quality of Life
0; 0 | NA | NA | NA | NA | NA | Insufficient
Disability/functional impairment
0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work or return to active duty
0; 0 | NA | NA | NA | NA | NA | Insufficient

Abbreviations: CI = confidence interval; NA = not applicable; RCT = randomized controlled trial

Table G-13 CBT-mixed interventions compared with inactive controls (waitlist, usual care)

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency^a^ | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction: mean change from baseline to end of treatment for CAPS
8; 476 | Medium; RCTs | Some inconsistency (I^2^=87%) | Direct | Precise | WMD −31.1 (−42.6 to −19.6); WMD −34.4 (−45.5, −23.2) when compared with WL (7 of the 8 trials) | Moderate
PTSD Symptom Reduction: mean change from baseline to end of treatment for various measures (combined to calculate effect size)
14; 825 | Medium; RCTs | Some inconsistency (I^2^=75.3%) | Direct | Precise | SMD −1.09 (−1.4 to −0.78); SMD −1.16 (−1.47, −0.84) when only compared with WL (13 trials) | Moderate
Remission (no longer having symptoms)
2; 114 | Medium; RCTs | Consistent | Direct | Precise | Data not pooled^b^ | Moderate
Loss of Diagnosis
6; 290 | Medium; RCTs | Some inconsistency (I^2^=60.5%) | Direct | Precise | RD 0.26 (0.11 to 0.41); NNT 3.8; RD 0.29 (−0.01 to 0.60) and NNT 3.4 when only compared with WL (3 trials) | Moderate
Prevention/reduction of comorbid depression: mean change from baseline in BDI
10; 662 | Medium; RCTs | Some inconsistency (I^2^=81.3%) | Direct | Precise | WMD −10.4 (−14.4 to −6.4); WMD −10.4 when only compared with WL (9 trials) | Moderate
Prevention/reduction of comorbid anxiety: mean change from baseline in STAI
4; 172 | Medium; RCTs | Some inconsistency (I^2^=83.5%) | Direct | Imprecise | WMD −11.2 (−20 to −2.4); WMD −12.1 when only compared with WL (3 trials) | Low
Quality of Life
3; 182 | Medium; RCTs | Inconsistent | Direct | Imprecise | Mixed results | Insufficient
Disability/functional impairment
5; 268 | Medium; RCTs | Consistent^c^ | Direct | Imprecise | Not calculated, heterogeneous outcome measures | Low
Return to work or return to active duty
0; 0 | NA | NA | NA | NA | NA | Insufficient

a Although meta-analyses often had considerable statistical heterogeneity for the trials comparing CBT mixed interventions with inactive controls, the direction of effects was generally the same across trials—differences were in the magnitude of effects.

b Two trials used different measures for remission found a greater percentages of subjects achieving remission: 61% vs. 21%, p=NR using the PCL;7 82.4% vs. 0%, P<0.001 using the HTQ.8

c Four of the five trials compared CBT-mixed interventions with WL controls and found similar benefits for CBT-mixed interventions compared with WL; one trial compared with standard care and found similar outcomes for subjects treated with CBT-mixed and those who received standard care.9

Abbreviations: CI = confidence interval; NA = not applicable; RCT = randomized controlled trial

Table G-14 CBT-mixed interventions compared with relaxation: Head-to-head trials

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction
2; 85 | Medium; RCTs | Consistent | Direct | Imprecise | Mean CAPS improvement: 38 (26 to 50) vs. 14 (4 to 25) in one trial.3 Between group effect size: d = 1.6 in another10 | Moderate
Remission (no longer having symptoms)
0; 0 | NA | NA | NA | NA | NA | Insufficient
Loss of Diagnosis
0; 0 | NA | NA | NA | NA | NA | Insufficient
Prevention/reduction of comorbid depression
0; 0 | NA | NA | NA | NA | NA | Insufficient
Prevention/reduction of comorbid anxiety
0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of Life
0; 0 | NA | NA | NA | NA | NA | Insufficient
Disability/functional impairment
1; 45 | Medium; RCT | NA, single study | Direct | Imprecise | GHQ Global Improvement measure: percentage of subjects improved functioning: 70–80% vs. 50–55% p=NS | Insufficient
Return to work or return to active duty
0; 0 | NA | NA | NA | NA | NA | Insufficient

Abbreviations: CI = confidence interval; NA = not applicable; RCT = randomized controlled trial

Table G-15 EMDR compared with inactive controls (waitlist, usual care)

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction
4; 117 | Medium; RCTs | Inconsistent (I^2^=70%) | Direct | Imprecise | SMD −1.08 (−1.83 to −0.33); SMD −1.37 (−2.05, −0.69) when only compared with WL (3 trials, N=95) | Low
Remission (no longer having symptoms)
0; 0 | NA | NA | NA | NA | NA | Insufficient
Loss of Diagnosis
3; 95 | Medium; RCTs | Consistent (I^2^=27%) | Direct | Precise | RD 0.64 (0.46 to 0.81); NNT 1.56 | Moderate
Prevention/reduction of comorbid depression
4; 117 | Medium; RCTs | Consistent (I^2^=0%) | Direct | Precise | SMD −1.13 (−1.52 to −0.74) | Moderate
Prevention/reduction of comorbid anxiety: mean change from baseline in STAI
3; 93 | Medium; RCTs | Inconsistent | Direct | Imprecise | No statistically significant difference: WMD −11.08 (−23.06 to 0.90) | Insufficient
Quality of Life
0; 0 | NA | NA | NA | NA | NA | Insufficient
Disability/functional impairment
0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work or return to active duty
0; 0 | NA | NA | NA | NA | NA | Insufficient

Abbreviations: CI = confidence interval; EMDR = eye movement desensitization and reprocessing; NA = not applicable; PTSD = post-traumatic stress disorder; RCT = randomized controlled trial; RD = risk difference; SMD = Standardized mean difference; STAI = State Trait Anxiety Inventory; WMD = weighted mean difference

Table G-16 EMDR compared with relaxation

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction
2; 64 | Medium; RCTs | Inconsistent | Direct | Imprecise | SMD −0.57 (−1.4 to 0.29) SMD −0.3 (−0.8 to 0.2)^a^ | Insufficient
Remission (no longer having symptoms)
0; 0 | NA | NA | NA | NA | NA | Insufficient
Loss of Diagnosis at 3 month post-treatment follow up
2; 64 | Medium; RCTs | Inconsistent | Direct | Imprecise | RD 0.34 (−0.04 to 0.72), trend toward greater reduction for EMDR | Insufficient
Prevention/reduction of comorbid depression: BDI
2; 64 | Medium; RCTs | Inconsistent | Direct | Imprecise | Mixed findings | Insufficient
Prevention/reduction of comorbid anxiety: STAI
1; 23 | Medium; RCT | NA, single study | Direct | Imprecise | Cohen’s d=1.15 (favoring EMDR), p<0.01 | Insufficient
Quality of Life
0; 0 | NA | NA | NA | NA | NA | Insufficient
Disability/functional impairment
0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work or return to active duty
0; 0 | NA | NA | NA | NA | NA | Insufficient

a Two SMDs reported here because two meta-analyses were run because one of the two trials reported two measures of PTSD symptoms.11 The first SMD is from our meta-analysis using the Mississippi Scale for Combat Related PTSD from the study reporting two measures; the second is using the IES from that trial. The other trial reported the CAPS.12

Abbreviations: BDI = Beck Depression Inventory; CAPS = Clinician-Administered Post Traumatic Stress Disorder Scale; CI = confidence interval; EMDR = eye movement desensitization and reprocessing; NA = not applicable; PTSD = post-traumatic stress disorder; RCT = randomized controlled trial

Table G-17 Seeking safety compared with standard community treatment (1 trial13)

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction: CAPS frequency and intensity, reduction from baseline to post-treatment
1; 107 | Medium; RCT | NA, single study | Direct | Imprecise | −15.02 vs. −5.88, p<0.01 | Insufficient
Remission (no longer having symptoms)
0; 0 | NA | NA | NA | NA | NA | Insufficient
Loss of Diagnosis
0; 0 | NA | NA | NA | NA | NA | Insufficient
Prevention/reduction of comorbid substance use
1; 107 | Medium; RCT | NA, single study | Direct | Imprecise | greater reduction in substance use/abuse for SS group, p<0.001 | Insufficient
Quality of Life
0; 0 | NA | NA | NA | NA | NA | Insufficient
Disability/functional impairment
0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work or return to active duty
0; 0 | NA | NA | NA | NA | NA | Insufficient

Abbreviations: CAPS = Clinician-Administered Post Traumatic Stress Disorder Scale; BDI = Beck Depression Inventory; CI = confidence interval; IES = Impact of Events Scale; NA = not applicable; PTSD = post-traumatic stress disorder; RCT = randomized controlled trial

Table G-18 Seeking safety compared with active controls (relapse prevention, psychoeducation, treatment as usual in a VA substance use disorders clinic)

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction: CAPS
3; 477 | Medium; RCTs | Consistent | Direct | Precise | 1.45 (−2.5 to 5.4) | Moderate
PTSD Symptom Reduction: any measure
4; 594 | Medium; RCTs | Consistent | Direct | Precise | SMD 0.04 (−0.12 to 0.20) | Moderate
Remission (no longer having symptoms)
0; 0 | NA | NA | NA | NA | NA | Insufficient
Loss of Diagnosis
1; 49 | Medium; RCT | NA, single study | Direct | Imprecise | OR for SS vs. RPC=1.22 (0.48 to 3.13) | Insufficient
Prevention/reduction of comorbid substance use/abuse
4; 594 | Medium; RCTs | Inconsistent | Direct | Imprecise | No statistically significant difference in 3 trials (N=477); better substance use outcomes for 1 trial (N=117) | Insufficient
Quality of Life
0; 0 | NA | NA | NA | NA | NA | Insufficient
Disability/functional impairment
0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work or return to active duty
0; 0 | NA | NA | NA | NA | NA | Insufficient

Abbreviations: CAPS = Clinician-Administered Post Traumatic Stress Disorder Scale; CI = confidence interval; NA = not applicable; OR = odds ratio; PTSD = post-traumatic stress disorder; RCT = randomized controlled trial; RPC, relapse prevention; SS, seeking safety

Table G-19 Imagery rehearsal therapy (IRT) compared with waitlist (1 trial14)

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction: CAPS mean change from baseline
1; 168 | Medium; RCT | NA, Single study | Direct | Unknown | −32.3 vs. −11.3, p=0.001 | Insufficient
Remission (no longer having symptoms)
0; 0 | NA | NA | NA | NA | NA | Insufficient
Loss of Diagnosis
0; 0 | NA | NA | NA | NA | NA | Insufficient
Prevention/reduction of comorbid depression: HAMD
1; 168 | Medium; RCT | NA, Single study | Direct | Imprecise | Cohen d: 0.57 vs. 0.33, p=NS | Insufficient
Prevention/reduction of comorbid anxiety: HAMA
1; 168 | Medium; RCT | NA, Single study | Direct | Imprecise | Cohen d: 0.39 vs. −0.16, p=0.04 | Insufficient
Quality of Life: SF-36
1; 168 | Medium; RCT | NA, Single study | Direct | Imprecise | No difference between groups; data not reported | Insufficient
Disability/functional impairment
0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work or return to active duty
0; 0 | NA | NA | NA | NA | NA | Insufficient

Abbreviations: CAPS = Clinician-Administered Post Traumatic Stress Disorder Scale; CI = confidence interval; HAM-D = Hamilton Depression Scale; HAM-A = Hamilton Anxiety Scale; IRT = imagery rehearsal therapy; NA = not applicable; NR = Not Reported; PTSD = post-traumatic stress disorder; RCT = randomized controlled trial; SF-36 = 36-Item Short-Form Health Survey; WL = waitlist

Table G-20 Narrative exposure therapy (NET) compared with an inactive control (waitlist or minimal attention)

| Domains Pertaining to Strength of evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction: mean change from baseline to post-treatment in PDS
3; 227 | Medium; RCTs | Consistent | Direct | Precise | −10.2 (−13.1 to −7.4) | Moderate
Remission (no longer having symptoms)
0; 0 | NA | NA | NA | NA | NA | Insufficient
Loss of Diagnosis
3; 227 | Medium; RCTs | Consistent | Direct | Imprecise | RD 0.15 (0.01 to 0.30) | Low
Prevention/reduction of comorbid depression
2; 75 | Medium; RCTs | Inconsistent | Direct | Imprecise | Mixed evidence; one trial reported efficacy (HSCL-25 Depression scale: cohen’s d 0.54); one reported no difference from comparators (SRQ-20: data NR) | Insufficient
Prevention/reduction of comorbid pain
1; 32 | Medium; RCT | NA, single study | Direct | Imprecise | d=0.65 for CIDI-C pain score, a significant time by treatment interaction was found, p=0.034, but no significant main effect of time, p=0.46, or treatment, p=0.35 | Insufficient
Quality of Life
1; 43 | Medium; RCT | NA, single study | Direct | Imprecise | NET was not significantly different from psychoeducation for improving QOL, p=0.54 | Insufficient
Disability/functional impairment
0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work or return to active duty
0; 0 | NA | NA | NA | NA | NA | Insufficient

Abbreviations: CI = confidence interval; HSCL-25 = Hopkins Symptom Check List-25; NA = not applicable; NR = not reported; PDS = Posttraumatic Stress Diagnostic Scale; PTSD = post-traumatic stress disorder; RCT = randomized controlled trial; SRQ-20 = Self-Reporting Questionnaire

Table G-21 Brief eclectic psychotherapy (BEP) compared with waitlist

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction: various outcome measures
3; 96 | Medium; RCTs | Consistent | Direct | Imprecise | Not calculated, likely small to medium effect size^a^ | Low
Remission (no longer having symptoms)
1; 30^15^ | Medium; RCT | NA, single study | Direct | Imprecise | 12.5% vs. 0% posttreatment; 18.8% vs. 0% at 6 months | Insufficient
Loss of Diagnosis
3; 96 | Medium; RCTs | Inconsistent^b^ | Direct | Imprecise | Range from 12.5% vs. 0% to 83.3 vs. 25% to 91% vs. 50% | Low
Prevention/reduction of comorbid depression
3; 96 | Medium; RCTs | Inconsistent | Direct | Imprecise | All 3 found benefits, wide range of effect sizes in the 2 trials reporting sufficient data to determine, from medium to very large | Low
Prevention/reduction of comorbid anxiety
3; 96 | Medium; RCTs | Inconsistent | Direct | Imprecise | All 3 found benefits, wide range of effect sizes in the 2 trials reporting sufficient data to determine, from medium to very large | Low
Quality of Life
0; 0 | NA | NA | NA | NA | NA | Insufficient
Disability/functional impairment
0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work
2; 66 | Medium; RCTs | Inconsistent | Direct | Imprecise | One trial found d=0.33 p=0.06 for percentage of subjects on sick leave; the other found more subjects had returned to work (86% vs. 60%, p<0.05) | Low

a The three trials used different outcome measures—two found small or medium effect sizes using the CAPS15 and SI-PTSD,16 respectively. The other did not report enough data to determine effect sizes.17

b The three trials were consistent in the sense that they all found more subjects in the BEP group with loss of PTSD diagnosis compared with the WL group. However, the differences between groups were inconsistent, ranging from a small difference (12.5%)15 to a large difference (58.3%) between groups.16

Abbreviations: CI = confidence interval; mths, months; NA = not applicable; PTSD = post-traumatic stress disorder; RCT = randomized controlled trial

Table G-22 Brief eclectic psychotherapy (BEP) compared with EMDR

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction: IES-R and SI-PTSD
1; 140 | Medium; RCT | NA, single study | Direct | Imprecise | Greater improvement from baseline to the first assessment for those treated with EMDR (SI-PTSD, mean difference 10.80; 95% CI, 6.37 to 15.23); difference was no longer significant at the second assessment, after both groups had completed treatment | Insufficient
Remission (no longer having symptoms)
0; 0 | NA | NA | NA | NA | NA | Insufficient
Loss of Diagnosis
1; 140 | Medium; RCT | NA, single study | Direct | Imprecise | Among completers, EMDR vs. BET: 92.2% vs. 52.3%, p<0.001 at the first assessment; No significant difference at the second assessment: 93.7% vs. 85.7%, p=0.30 | Insufficient
Prevention/reduction of comorbid depression: HADS depression
1; 140 | Medium; RCT | NA, single study | Direct | Imprecise | Greater improvement from baseline to the first assessment for those treated with EMDR, but no significant difference between groups at the second assessment | Insufficient
Prevention/reduction of comorbid anxiety: HADS anxiety
1; 140 | Medium; RCT | NA, single study | Direct | Imprecise | Greater improvement from baseline to the first assessment for those treated with EMDR, but no significant difference between groups at the second assessment | Insufficient
Quality of Life
0; 0 | NA | NA | NA | NA | NA | Insufficient
Disability/functional impairment
0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work
0; 0 | NA | NA | NA | NA | NA | Insufficient

Abbreviations: CI = confidence interval; mths, months; NA = not applicable; PTSD = post-traumatic stress disorder; RCT = randomized controlled trial

Table G-23 Trauma affect regulation compared with waitlist

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction: CAPS
1; 93 | Medium; RCT | NA, single study | Direct | Imprecise | −23.6 vs. −6.2, p<0.001 | Insufficient
Remission (no longer having symptoms)
1; 93 | Medium; RCT | NA, single study | Direct | Imprecise | 21% vs. 0%, p<0.001 | Insufficient
Loss of Diagnosis
1; 93 | Medium; RCT | NA, single study | Direct | Imprecise | 35% vs. 11% | Insufficient
Prevention/reduction of comorbid depression: BDI
1; 93 | Medium; RCT | NA, single study | Direct | Imprecise | −4.4 vs. −0.3, p<0.01 | Insufficient
Prevention/reduction of comorbid anxiety
1; 93 | Medium; RCT | NA, single study | Direct | Imprecise | −6.7 vs. −0.4, p=0.19 | Insufficient
Quality of Life
0; 0 | NA | NA | NA | NA | NA | Insufficient
Disability/functional impairment
0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work
0; 0 | NA | NA | NA | NA | NA | Insufficient

Abbreviations: CI = confidence interval; mths, months; NA = not applicable; PTSD = post-traumatic stress disorder; RCT = randomized controlled trial

## Key Question 2

Table G-24 Placebo-controlled trials of alpha-blockers

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design/Quality | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction: CAPS
2; 50 | Medium; RCTs | Consistent (I^2^ 1.8%) | Direct | Imprecise | WMD −8.86 (−22.06 to 4.33) | Insufficient
Remission (no longer having symptoms)
0; 0 | NA | NA | NA | NA | NA | Insufficient
Loss of Diagnosis
0; 0 | NA | NA | NA | NA | NA | Insufficient
Prevention/reduction of comorbid depression
1; 40 | Medium; RCT | NA, single study | Direct | Imprecise | −5.6 vs. −0.6, p=0.08 | Insufficient
Prevention/reduction of comorbid anxiety
0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of Life
0; 0 | NA | NA | NA | NA | NA | Insufficient
Disability/functional impairment
0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work or return to active duty
0; 0 | NA | NA | NA | NA | NA | Insufficient

Abbreviations: CI = confidence interval; NA = not applicable; RCT = randomized controlled trial

Table G-25 Strength of evidence for divalproex compared with placebo

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction: CAPS
1; 85 | Low; RCT | NA | Direct | Imprecise | WMD 1.40 (−8.22 to 11.02) | Insufficient
PTSD Symptom Reduction: TOP-8
1; 85 | Low; RCT | NA | Direct | Imprecise | −4.0 vs. −3.9, NS | Insufficient
Remission (no longer having symptoms)
0; 0 | NA | NA | NA | NA | NA | Insufficient
Loss of Diagnosis
0; 0 | NA | NA | NA | NA | NA | Insufficient
Prevention/reduction of comorbid depression: MADRS
1; 85 | Low; RCT | NA | Direct | Imprecise | −5.1 vs. −4.5, NS | Insufficient
Prevention/reduction of comorbid anxiety: HAM-A
1; 85 | Low; RCT | NA | Direct | Imprecise | −15.1 vs. −16.5, NS | Insufficient
Quality of Life
0; 0 | NA | NA | NA | NA | NA | Insufficient
Disability/functional impairment
0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work or return to active duty
0; 0 | NA | NA | NA | NA | NA | Insufficient

Table G-26 Strength of evidence for lamotrigine compared with placebo

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction:
0; 0 | NA | NA | NA | NA | NA | Insufficient
Remission (no longer having symptoms)
0; 0 | NA | NA | NA | NA | NA | Insufficient
Loss of Diagnosis
0; 0 | NA | NA | NA | NA | NA | Insufficient
Prevention/reduction of comorbid depression
0; 0 | NA | NA | NA | NA | NA | Insufficient
Prevention/reduction of comorbid anxiety
0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of Life
0; 0 | NA | NA | NA | NA | NA | Insufficient
Disability/functional impairment
0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work or return to active duty
0; 0 | NA | NA | NA | NA | NA | Insufficient

Table G-27 Strength of evidence for tiagabine compared with placebo

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction: CAPS
1; 232 | Medium; RCT | NA | Direct | Imprecise | WMD −0.50 (−7.12 to 6.12) | Insufficient
PTSD Symptom Reduction: TOP-8
1; 232 | Medium; RCT | NA | Direct | Imprecise | “not significant” | Insufficient
Remission (CAPS less than 20)
1; 232 | Medium; RCT | NA | Direct | Imprecise | 16% vs. 14%, p=0.88 | Insufficient
Loss of Diagnosis
0; 0 | NA | NA | NA | NA | NA | Insufficient
Prevention/reduction of comorbid depression
0; 0 | NA | NA | NA | NA | NA | Insufficient
Prevention/reduction of comorbid anxiety
0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of Life
0; 0 | NA | NA | NA | NA | NA | Insufficient
Disability/functional impairment: Sheehan Disability Scale
1; 232 | Medium; RCT | NA | Direct | Imprecise | −5.5 vs. −5.9, p=0.74 | Insufficient
Return to work or return to active duty
0; 0 | NA | NA | NA | NA | NA | Insufficient

Table G-28 Strength of evidence for topiramate compared with placebo

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction: CAPS
3; 142 | Medium; RCT | Consistent | Direct | Precise | WMD −15.53 (−19.40 to −11.65) | Moderate
PTSD Symptom Reduction: TOP-8
1; 40 | Medium; RCT | NA | Direct | Imprecise | −67.9 % vs. −41.6 %, p=0.023 | Insufficient
Remission (no longer having symptoms)
1; 40 | Medium; RCT | NA | Direct | Imprecise | 42% vs. 21%, p=0.295 | Insufficient
Loss of Diagnosis
0; 0 | NA | NA | NA | NA | NA | Insufficient
Prevention/reduction of comorbid depression: BDI
1; 35 | Medium; RCT | NA | Direct | Imprecise | −8.5 vs. −3.9, p=0.72 | Insufficient
Prevention/reduction of comorbid depression: HAM-D
1; 40 | Medium; RCT | NA | Direct | Imprecise | −50.7% vs. −33.3, p=0.253 | Insufficient
Prevention/reduction of comorbid anxiety: HAM-A
1; 40 | Medium; RCT | NA | Direct | Imprecise | −53.9% and −40.0%, p=0.331 | Insufficient
Quality of Life
0; 0 | NA | NA | NA | NA | NA | Insufficient
Disability/functional impairment: Sheehan Disability Scale
1; 40 | Medium; RCT | NA | Direct | Imprecise | −30.6% and −35.4% p=0.804 | Insufficient
Return to work or return to active duty
0; 0 | NA | NA | NA | NA | NA | Insufficient

Table G-29 Olanzapine compared with placebo

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design/Quality | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction: CAPS
1; 19 | Medium; RCT | NA, single study | Direct | Imprecise | −12.13 (−23.29 to −0.97) | Insufficient
PTSD Symptom Reduction: TOP-8
1; 15 | Medium; RCT | NA, single study | Direct | Imprecise | −6.7 vs. −11.3, (p=NR) | Insufficient
PTSD Symptom Reduction: DTS
1; 15 | Medium; RCT | NA, single study | Direct | Imprecise | −34.2 vs. −39.8, p=NR | Insufficient
PTSD Symptom Reduction: SPRINT
1; 15 | Medium, RCT | NA, single study | Direct | Imprecise | −13.6 vs. −14.3, p=NR | Insufficient
Remission (no longer having symptoms)
0; 0 | NA | NA | NA | NA | NA | Insufficient
Loss of Diagnosis
0; 0 | NA | NA | NA | NA | NA | Insufficient
Prevention/reduction of comorbid depression: CES-D
1; 19 | Medium | NA, single study | Direct | Imprecise | −5.25 vs. −4.88, p<0.03 | Insufficient
Prevention/reduction of comorbid depression
0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of Life
0; 0 | NA | NA | NA | NA | NA | Insufficient
Disability/functional impairment: Sheehan
1; 15 | Medium | NA | Direct | Imprecise | −7.7 vs. −8.0, (p<0.001) | Insufficient
Return to work or return to active duty
0; 0 | NA | NA | NA | NA | NA | Insufficient

Abbreviations: CI = confidence interval; NA = not applicable; RCT = randomized controlled trial

Table G-30 Risperidone compared with placebo

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design/Quality | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction: CAPS
4; 419 | Medium; RCTs | Consistent (I^2^ 22.3%) | Direct | Imprecise | WMD −4.60 (−9.01 to −0.20) | Low
PTSD Symptom Reduction: Change in PCL-M
1; 16 | Medium; RCT | NA, single study | Direct | Imprecise | −10.0 vs. −0.50, p=0.02 | Insufficient
Remission (no longer having symptoms)
0; 0 | NA | NA | NA | NA | NA | Insufficient
Loss of Diagnosis
0; 0 | NA | NA | NA | NA | NA | Insufficient
Prevention/reduction of comorbid depression: Ham-D
1; 65 | Medium; RCT | NA, single study | Direct | Imprecise | −3.7 vs. −1.4, p>0.05 | Insufficient
Prevention/reduction of comorbid anxiety: HAM-A
1; 65 | Medium; RCT | NA, single study | Direct | Imprecise | −7.4 vs. −2.0, p<0.001 | Insufficient
Prevention/reduction of comorbid psychosis: PANSS
1; 40 | Medium; RCT | NA, single study | Direct | Imprecise | −10.0 vs. −2.3, p≤0.05 | Insufficient
Quality of Life
0; 0 | NA | NA | NA | NA | NA | Insufficient
Disability/functional impairment: Sheehan
0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work or return to active duty
0; 0 | NA | NA | NA | NA | NA | Insufficient

Abbreviations: CI = confidence interval; NA = not applicable; RCT = randomized controlled trial

Table G-31 Benzodiazepines compared with placebo^a^

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design/Quality | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction: PTSD Scale and IES | | | | | | Low
0; 0 | NA | NA | NA | NA | NA | Insufficient
Remission (no longer having symptoms)
0; 0 | NA | NA | NA | NA | NA | Insufficient
Loss of Diagnosis
0; 0 | NA | NA | NA | NA | NA | Insufficient
Prevention/reduction of comorbid depression
0; 0 | NA | NA | NA | NA | NA | Insufficient
Prevention/reduction of comorbid anxiety
0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of Life
0; 0 | NA | NA | NA | NA | NA | Insufficient
Disability/functional impairment
0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work or return to active duty
0; 0 | NA | NA | NA | NA | NA | Insufficient

a We did not identify any studies of low or medium risk of bias meeting our inclusion criteria. We did find 1 study otherwise meeting criteria that we excluded for high risk of bias. The trial (N=16) reported no statistically significant difference between subjects treated with alprazolam and those treated with placebo for reduction of PTSD symptoms (PTSD Scale: −4.3 vs. −1.2, p=NS; IES: −3.3 vs. −0.3, p=NS) or reduction of comorbid depression (HAM-D: −1.1 vs. −0.8, p=NS). It reported greater reduction in anxiety for subjects treated with alprazolam (HAM-A: −7.7 vs. 0.2, p=0.02).

Abbreviations: NA = not applicable; RCT = randomized controlled trial

Table G-32 Citalopram compared with placebo

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI)^a^ | High, Moderate, Low, Insufficient
PTSD Symptom Reduction: mean change from baseline in CAPS
1; 35 | Medium; RCT | NA, single study | Direct | Imprecise | WMD +7.98 (−10.1 to 26.0) | Insufficient
PTSD Symptom Reduction: mean change from baseline in IES
1; 35 | Medium; RCT | NA, single study | Direct | Imprecise | WMD 7.8 (−4.8 to 20.5) | Insufficient
Remission (no longer having symptoms)
0; 0 | NA | NA | NA | NA | NA | Insufficient
Loss of Diagnosis
0; 0 | NA | NA | NA | NA | NA | Insufficient
Prevention/reduction of comorbid depression: BDI, mean change from baseline
1; 35 | Medium; RCT | NA, single study | Direct | Imprecise | WMD −0.47 (−10.9 to 10.0) | Insufficient
Prevention/reduction of comorbid anxiety
0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of Life
0; 0 | NA | NA | NA | NA | NA | Insufficient
Disability/functional impairment
0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work or return to active duty
0; 0 | NA | NA | NA | NA | NA | Insufficient

a Data are from a single trial comparing citalopram, sertraline, and placebo.18

Abbreviations: CI = confidence interval; NA = not applicable; RCT = randomized controlled trial

Table G-33 Fluoxetine compared with placebo

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction: mean change from baseline in CAPS
4; 923 | Medium; RCTs | Consistent (I^2^=0%) | Direct | Precise | WMD −6.97 (−10.4 to −3.5) | Moderate
PTSD Symptom Reduction: mean change from baseline in DTS
3; 766 | Medium; RCTs | Consistent (I^2^=31.3%) | Direct | Precise | WMD −8.19 (−13.7 to −2.7) | Moderate
Remission (no longer having symptoms): Percent of subjects with CAPS less than 20
1; 52 | Medium; RCT | NA, single study | Direct | Imprecise | 13% vs. 10%, p=0.72 | Insufficient
Loss of Diagnosis: percent of subjects no longer meeting criteria for PTSD diagnosis
1; 59 | Medium; RCT | NA, single study | Direct | Imprecise | 73% vs. 59%, p=0.23 | Insufficient
Prevention/reduction of comorbid depression: mean change from baseline in MADRS
2; 712 | Medium; RCTs | Consistent (I^2^=0%) | Direct | Precise | WMD −2.4 (−3.7 to −1.1) | Moderate
Prevention/reduction of comorbid anxiety: mean change from baseline in HAMA
2; 712 | Medium; RCTs | Consistent (I^2^=0%) | Direct | Precise | WMD −2.1 (−3.2 to −0.9) | Moderate
Quality of Life: change in SF-36 mental and physical sub-scores
1; 144 | Medium; RCT | NA, single study | Direct | | Mental health sub-score: 15.5 vs. 0.33, p<0.001 Physical functioning sub-score: 8.62 vs. 8.07, p=0.891^a^ | Insufficient
Disability/functional impairment: mean change from baseline in SDS
1; 54 | Medium; RCT | NA, single study | Direct | Imprecise | −5.8 (−9.8 to −1.8) | Insufficient
Return to work or return to active duty
0; 0 | NA | NA | NA | NA | NA | Insufficient

a Data from subgroup analysis of subjects with combat-related PTSD in one trial (N=144 of the 301 from the main trial).19

Abbreviations: CI = confidence interval; NA = not applicable; RCT = randomized controlled trial

Table G-34 Paroxetine compared with placebo

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction: mean change from baseline in CAPS
2; 1074 | Medium; RCTs | Consistent (I^2^=0%) | Direct | Precise | WMD −12.6 (−15.7 to −9.5) | Moderate
PTSD Symptom Reduction: mean change from baseline in DTS
2; 1074 | Medium; RCTs | Consistent (I^2^=0%) | Direct | Precise | WMD −12.2 (−15.8 to −8.7) | Moderate
Remission (no longer having symptoms)
2; 346 | Medium; RCTs | Consistent | Direct | Precise | 12.9% more subjects in paroxetine group achieved remission (p=0.008)^a^ | Moderate
Loss of Diagnosis
0; 0 | NA | NA | NA | NA | NA | Insufficient
Prevention/reduction of comorbid depression: mean change from baseline in MADRS
2; 886 | Medium; RCTs | Consistent (I^2^=0%) | Direct | Precise | WMD −5.7 (−7.1 to −4.3) | Moderate
Prevention/reduction of comorbid anxiety
0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of Life
0; 0 | NA | NA | NA | NA | NA | Insufficient
Disability/functional impairment: mean change from baseline in SDS
2; 886 | Medium; RCTs | Consistent (I^2^=0%) | Direct | Precise | WMD −2.3 (−3.3 to −1.4) | Moderate
Return to work or return to active duty
0; 0 | NA | NA | NA | NA | NA | Insufficient

a Data is the best available evidence from a trial of paroxetine (N=323) that defined remission as a CAPS-2 total score less than 20 and found a significantly greater proportion of paroxetine-treated subjects achieved remission compared with placebo at week 12 (29.4% vs. 16.5%, p=0.008). The difference (12.9% difference between paroxetine and placebo) would translate to a number needed to treat of 7.8 to achieve one remission.20 The other trial contributing data for this outcome found similar percentages of subjects achieving remission (33% vs. 14%), but it was underpowered to detect anything but a very large difference for this outcome.21

Abbreviations: CI = confidence interval; NA = not applicable; RCT = randomized controlled trial

Table G-35 Sertraline compared with placebo

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction: mean change from baseline in CAPS
7; 1,085 | Medium; RCTs | Consistent (I^2^=0%) | Direct | Precise | WMD −4.87 (−7.4 to −2.4) | Moderate
PTSD Symptom Reduction: mean change from baseline in DTS
4; 916 | Medium; RCTs | Consistent (I^2^=0%) | Direct | Precise | WMD −7.7 (−12.9 to −2.4) | Moderate
Remission (no longer having symptoms): Percent of subjects achieving CAPS-SX_17_ score less than 20
1; 352 | Medium; RCT | NA, single study | Direct | Unknown | 24.3% vs. 19.6%, p=NS (NR) | Insufficient
Loss of Diagnosis
0; 0 | NA | NA | NA | NA | NA | Insufficient
Prevention/reduction of comorbid depression: mean change from baseline in HAMD
5; 1,010 | Medium; RCTs | Inconsistent: I^2^=25% but 3 trials trended in favor of sertraline; 2 in favor of placebo | Direct | Imprecise | WMD −0.77 (−2.1 to 0.55) | Low
Prevention/reduction of comorbid anxiety: mean change from baseline in HAMA
2; 377 | Medium; RCTs | Inconsistent (I^2^=68.3%) | Direct | Imprecise | WMD 0.19 (−3.14 to 3.51) | Insufficient
Quality of Life: mean change in Q-LES-Q
2; 539 | Medium; RCTs | Inconsistent (I^2^=72.6%) | Direct | Imprecise | WMD 4.9 (−0.88 to 10.7) | Insufficient
Disability/functional impairment: mean change from baseline in SDS
1; 352 | Medium; RCT | NA, single study | Direct | Imprecise | −1.65 (−3.4 to 0.12) | Insufficient
Return to work or return to active duty
0; 0 | NA | NA | NA | NA | NA | Insufficient

Abbreviations: CI = confidence interval; NA = not applicable; RCT = randomized controlled trial

Table G-36 Venlafaxine compared with placebo

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design/Quality | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction: Change in CAPS
2; 687 | Medium/RCT | Consistent (I^2^ 0%) | Direct | Precise | WMD −7.15 (−11.02 to −3.28) | Moderate
Remission (no longer having symptoms): defined by CAPS-Sx total score of 20 or less
2; 687 | Medium/RCT | Consistent (I^2^ 0%) | Direct | Precise | RD 0.12 (0.05 to 0.19) | Moderate
Loss of Diagnosis
0; 0 | NA | NA | NA | NA | NA | Insufficient
Prevention/reduction of comorbid depression: change in HAM-D
2; 687 | Medium/RCT | Consistent (I^2^ 0%) | Direct | Precise | WMD −2.08 (−3.12 to −1.04) | Moderate
Prevention/reduction of comorbid anxiety
0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of Life (change in Q-LES-Q-SF)
2; 687 | Medium/RCT | Consistent (I^2^ 0%) | Direct | Precise | WMD 3.42 (1.58 to 5.26) | Moderate
Disability/functional impairment (change in SDS, and change in GAF)
2; 687 | Medium/RCT | Consistent (I^2^ 0%) | Direct | Precise | WMD −2.06 (−3.28 to −0.84) for SDS WMD 3.41 (1.41 to 5.40) for GAF | Moderate
Return to work or return to active duty
0; 0 | NA | NA | NA | NA | NA | Insufficient

Abbreviations: CI = confidence interval; NA = not applicable; RCT = randomized controlled trial

Table G-37 Strength of evidence for tricyclic antidepressants compared to placebo

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design/Quality | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction
0; 0 | NA | NA | NA | NA | NA | Insufficient
Remission (no longer having symptoms)
0; 0 | NA | NA | NA | NA | NA | Insufficient
Loss of Diagnosis
0; 0 | NA | NA | NA | NA | NA | Insufficient
Prevention/reduction of comorbid depression
0; 0 | NA | NA | NA | NA | NA | Insufficient
Prevention/reduction of comorbid anxiety
0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of Life
0; 0 | NA | NA | NA | NA | NA | Insufficient
Disability/functional impairment
0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work or return to active duty
0; 0 | NA | NA | NA | NA | NA | Insufficient

Table G-38 Placebo-controlled trials of bupropion

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design/Quality | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction: CAPS
1; 30 | Medium; RCT | NA, Single Study | Direct | Imprecise | −12.33 vs. −16.99, NS | Insufficient
PTSD Symptom Reduction: DTS
1; 30 | Medium; RCT | NA, Single Study | Direct | Imprecise | −13.22 vs.−10.6, NS | Insufficient
Remission (no longer having symptoms)
0; 0 | NA | NA | NA | NA | NA | Insufficient
Loss of Diagnosis
0; 0 | NA | NA | NA | NA | NA | Insufficient
Prevention/reduction of comorbid depression: BDI
1; 30 | Medium; RCT | NA, single study | Direct | Imprecise | −3.22 vs. −3.61, NS | Insufficient
Prevention/reduction of comorbid anxiety
0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of Life
0; 0 | NA | NA | NA | NA | NA | Insufficient
Disability/functional impairment
0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work or return to active duty
0; 0 | NA | NA | NA | NA | NA | Insufficient

Abbreviations: CI = confidence interval; NA = not applicable; RCT = randomized controlled trial

Table G-39 Placebo-controlled trials of mirtazapine

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design/Quality | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction: DTS
1; 29 | Medium; RCT | NA, single study | Direct | Imprecise | −20.7 vs.−11.2, NS | Insufficient
PTSD Symptom Reduction: SPRINT
1; 29 | Medium; RCT | NA, single study | Direct | Imprecise | −9.3 vs. −5.6, p=0.20 | Insufficient
PTSD Symptom Reduction: SIPS
1; 29 | Medium; RCT | NA, single study | Direct | Imprecise | −17.3 vs. −6.5, p=0.04 | Insufficient
Remission (no longer having symptoms)
0; 0 | NA | NA | NA | NA | NA | Insufficient
Loss of Diagnosis
0; 0 | NA | NA | NA | NA | NA | Insufficient
Prevention/reduction of comorbid depression: HADS-D
1; 29 | Medium; RCT | NA, single study | Direct | Imprecise | −2.2 vs. −0.5, NS | Insufficient
Prevention/reduction of comorbid anxiety: HADS-A
1; 29 | Medium; RCT | NA, single study | Direct | Imprecise | −2.8 vs. −1.2, p<0.05 | Insufficient
Quality of Life
0; 0 | NA | NA | NA | NA | NA | Insufficient
Disability/functional impairment
0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work or return to active duty
0; 0 | NA | NA | NA | NA | NA | Insufficient

Table G-40 Paroxetine compared with desiprimine: Head-to-head trials^a^

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction: CAPS, mean change from baseline
1; 88 | Medium; RCT | NA, single study | Direct | Imprecise | −33.5 vs. −33.2 vs. −35.7 vs. −36.4, p=NS^a^ | Low
Remission (no longer having symptoms)
0; 0 | NA | NA | NA | NA | NA | Insufficient
Loss of Diagnosis
0; 0 | NA | NA | NA | NA | NA | Insufficient
Prevention/reduction of comorbid depression: HAMD, mean change from baseline
1; 88 | Medium; RCT | NA, single study | Direct | Imprecise | −3.9 vs. −2.7 vs. −2.6 vs. −4.2, p=NS^a^ | Low
Prevention/reduction of comorbid alcohol dependence: heavy drinking days and drinks per drinking day
1; 88 | Medium; RCT | NA, single study | Direct | Imprecise | Greater reduction with desipramine^b^ | Low
Quality of Life
0; 0 | NA | NA | NA | NA | NA | Insufficient
Disability/functional impairment
0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work or return to active duty
0; 0 | NA | NA | NA | NA | NA | Insufficient

a Data are from 1 trial of veterans with PTSD and comorbid alcohol dependence that compared Paroxetine + Naltrexone, Paroxetine + Placebo, Desiprimine + Naltrexone, and Desipramine + Placebo.

b Data NR for drinking outcomes; p=0.009 for percentage of heavy drinking days and p=0.027 for drinks per drinking day; shown in Figure only; magnitude of difference NR and difficult to read clearly from the Figure, all groups ended up less than 20 standard drinks per week (from baselines above 70 drinks per week), but it appears that the Desipramine groups ended up in the 0 to 10 drinks per week range and the paroxetine groups ended up in the 10–20 range at the 12 week endpoint.

Abbreviations: CI = confidence interval; NA = not applicable; NR = not reported; RCT = randomized controlled trial

Table G-41 Venlafaxine ER compared with sertraline: Head-to-head trials

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI)^a^ | High, Moderate, Low, Insufficient
PTSD Symptom Reduction: CAPS-SX_17_, mean change from baseline
1; 538 | Medium; RCT | NA, single study^b^ | Direct | Precise | −41.5 vs. −39.4 p=0.49 | Moderate
PTSD Symptom Reduction: DTS, mean change from baseline
1; 538 | Medium; RCT | NA, single study^b^ | Direct | Precise | −42.9 vs. −38.9, p=0.25 | Moderate
Remission (no longer having symptoms): SX17 score of ≤20 at week 12
1; 538 | Medium; RCT | NA, single study^b^ | Direct | Precise | V vs. S vs. P ~30% vs. ~25% vs. ~20% p<0.05 for V vs. P p=NS S vs. P and for V vs. S | Moderate
Loss of Diagnosis
0; 0 | NA | NA | NA | NA | NA | Insufficient
Prevention/reduction of comorbid depression: HAMD, mean change from baseline
1; 538 | Medium; RCT | NA, single study^b^ | Direct | Precise | −7.09 vs. −6.42 vs. −5.54 P values: 0.38 for V vs. S 0.04 for V vs. P 0.24 for S vs. P | Low
Prevention/reduction of comorbid anxiety
0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of Life: Q-LES-Q, mean change
1; 538 | Medium; RCT | NA, single study^b^ | Direct | Precise | 11.5 vs. 11.2 vs. 8.8 P values: V vs. P 0.033; S vs. P 0.068; V vs. S 0.782 | Moderate
Disability/functional impairment: SDS
1; 538 | Medium; RCT | NA, single study^b^ | Direct | Precise | −8.5 vs. −8.2 vs. −6.5 P values: V vs. P 0.025; S vs. P 0.068; V vs. S 0.683 | Moderate
Return to work or return to active duty
0; 0 | NA | NA | NA | NA | NA | Insufficient

a Data are from 1 multicenter trial comparing venlafaxine ER, sertraline, and placebo.22

b Although this is a single trial, it was a multicenter trial including 59 outpatient centers in the US. We considered this in our SOE grade.

Abbreviations: CI = confidence interval; NA = not applicable; NR = not reported; p=placebo; RCT = randomized controlled trial; S = sertraline; V = venlafaxine ER

Table G-42 Sertraline compared with citalopram: Head-to-head trials

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI)^a^ | High, Moderate, Low, Insufficient
PTSD Symptom Reduction: CAPS, mean change from baseline
1; 58 | Medium; RCT | NA, single study | Direct | Imprecise | S vs. C vs. P: −41.8 vs. −30.7 vs. −38.7, p=NS | Insufficient
PTSD Symptom Reduction: IES, mean change from baseline
1; 58 | Medium; RCT | NA, single study | Direct | Imprecise | −29.1 vs. −19.3 vs. −33.2, p=NS | Insufficient
Remission (no longer having symptoms)
0; 0 | NA | NA | NA | NA | NA | Insufficient
Loss of Diagnosis
0; 0 | NA | NA | NA | NA | NA | Insufficient
Prevention/reduction of comorbid depression: BDI
1; 58 | Medium; RCT | NA, single study | Direct | Imprecise | −13.4 vs. −16.1 vs. −15.6, p=NR | Insufficient
Prevention/reduction of comorbid anxiety
0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of Life: Q-LES-Q, mean change
0; 0 | NA | NA | NA | NA | NA | Insufficient
Disability/functional impairment: SDS
0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work or return to active duty
0; 0 | NA | NA | NA | NA | NA | Insufficient

a Data are from 1 RCT comparing sertraline, citalopram, and placebo.18

Abbreviations: C = citalopram; CI = confidence interval; NA = not applicable; NR = not reported; p=placebo; RCT = randomized controlled trial; S = sertraline

## Key Question 3

Table G-43 Head-to-head trials of psychological and pharmacological treatments: Fluoxetine compared with EMDR

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Mean, %, or Effect Size (ES) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction: CAPS and PSS | | | | | | Insufficient
Fluoxetine vs. EMDR 1; 59 (post) 1; 50 (f/up) | Medium; RCT | Unknown (single study) | Direct | Imprecise | CAPS (1 wk): −31.03 vs. −36.85, NS (post); CAPS (1 month): −33.78 vs. −45.91, p<0.005 (f/up) | Insufficient
Remission (no longer having symptoms):
Fluoxetine vs. EMDR 1; 59 (post) 1; 50 (f/up) | Medium; RCT | Unknown (single study) | Direct | Imprecise | 13% vs. 28%, NS (post) 0% vs. 58%, p<0.001 (f/up) | Insufficient
Loss of Diagnosis
Fluoxetine vs. EMDR 1; 59 (post) 1; 50 (f/up) | Medium; RCT | Unknown (single study) | Direct | Imprecise | 73% vs. 76%, NS (post) 73% vs. 88%, NS (f/up) | Insufficient
Prevention/reduction of comorbid depression
Fluoxetine vs. EMDR 1; 59 (post 1; 50 (f/up) | Medium; RCT | Unknown (single study) | Direct | Imprecise | BDI: −5.78 vs. −6.99, NS (post); −4.2 vs. −10.95, p<0.001 (f/up) | Insufficient
Prevention/reduction of comorbid anxiety
0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of Life
0; 0 | NA | NA | NA | NA | NA | Insufficient
Disability/functional impairment
0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work or return to active duty
0; 0 | NA | NA | NA | NA | NA | Insufficient

Abbreviations: BDI = Beck Depression Inventory; CAPS = Clinician Administered PTSD Scale – total; f/up, 6 month follow-up; NR = not reported; NS = non-significant; post = post-treatment; wk = week.

## Key Question 4

Table G-44 Prolonged exposure plus paroxetine compared with prolonged exposure plus placebo

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction: CAPS, mean change from baseline to week 10
1; 37 | Medium; RCT | NA, single study | Direct | Imprecise | −51.1 vs. −29.8, p=0.01 | Insufficient
Remission (no longer having symptoms): CAPS score less than 20 and a CGI-C of 1 (very much improved)
1; 37 | Medium; RCT | NA, single study | Direct | Imprecise | ITT sample: 42.1% vs. 16.7%; Modeled data: OR, 12.6; 95% CI, 1.23 to 129 | Insufficient
Loss of Diagnosis
0; 0 | NA | NA | NA | NA | NA | Insufficient
Prevention/reduction of comorbid depression: HAMD
1; 37 | Medium; RCT | NA, single study | Direct | Imprecise | HAMD: −9.2 vs. −5.2, p=0.14 | Insufficient
Prevention/reduction of comorbid anxiety
0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of Life: Q-LES-Q
1; 37 | High; RCT | NA, single study | Direct | Imprecise | Increase in Q-LES-Q: 20.8 vs. 9.4, p=0.02 | Insufficient
Disability/functional impairment
0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work or return to active duty
0; 0 | NA | NA | NA | NA | NA | Insufficient

Abbreviations: CI = confidence interval; NA = not applicable; RCT = randomized controlled trial

Table G-45 Sertraline plus prolonged exposure compared with sertraline

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
PTSD Symptom Reduction: mean reduction from baseline in SIP
1; 65 | Medium; RCT | NA, single study | Direct | Imprecise | 5.9 with p<0.001 vs. −0.3 with p NS | Insufficient
Remission (no longer having symptoms)
0; 0 | NA | NA | NA | NA | NA | Insufficient
Loss of Diagnosis
0; 0 | NA | NA | NA | NA | NA | Insufficient
Prevention/reduction of comorbid depression: mean BDI, change from baseline
1; 65 | Medium; RCT | NA, single study | Direct | Imprecise | −3.2 vs. +0.3, p=NS | Insufficient
Prevention/reduction of comorbid anxiety: mean STAI-S, change from baseline
1; 65 | Medium; RCT | NA, single study | Direct | Imprecise | −3.9 vs. 0, p=NS | Insufficient
Quality of Life
0; 0 | NA | NA | NA | NA | NA | Insufficient
Disability/functional impairment
0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work or return to active duty
0; 0 | NA | NA | NA | NA | NA | Insufficient

Abbreviations: CI = confidence interval; NA = not applicable; RCT = randomized controlled trial

## Key Question 6

Table G-46 Strength of evidence for adverse events for topiramate compared with placebo

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
Withdrawals due to Adverse Events
3; 142 | Medium; RCTs | Inconsistent (2 trials trend in favor of placebo; 1 does not) | Direct | Imprecise | RD 0.01 (−0.08 to 0.10) | Insufficient
Headaches
2; 75 | Medium; RCTs | Inconsistent | Direct | Imprecise | RD −0.01 (−0.21 to 0.18) | Insufficient
Insomnia
2; 75 | Medium; RCTs | Inconsistent | Direct | Imprecise | RD 0.12 (−0.05 to 0.28) | Insufficient
Somnolence
1; 35 | Medium; RCT | NA, single study | Direct | Imprecise | RD −0.10 (−0.39 to 0.20) | Insufficient
Taste perversion
1; 40 | Medium; RCT | NA, single study | Direct | Imprecise | RD 0.25 (0.04 to 0.46) | Insufficient
Dyspespsia
1; 40 | Medium; RCT | NA, single study | Direct | Imprecise | RD 0.10 (−0.12 to 0.32) | Insufficient
Paresthesia
1; 40 | Medium; RCT | NA, single study | Direct | Imprecise | RD 0.15 (−0.05 to 0.35) | Insufficient
Nervousness
1; 40 | Medium; RCT | NA, single study | Direct | Imprecise | RD 0.15 (−0.05 to 0.35) | Insufficient
Fatigue
1; 40 | Medium; RCT | NA, single study | Direct | Imprecise | RD 0.20 (0.00 to 0.40) | Insufficient

Abbreviations: CI = confidence interval; NA = not applicable; RCT = randomized controlled trial

Table G-47 Strength of evidence for adverse events for fluoxetine compared with placebo

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
Withdrawals due to Adverse Events
3; 766 | Medium; RCTs | Consistent (I^2^=4.3%) | Direct | Imprecise | RD −0.01 (−0.04 to 0.03) | Low
Headaches
3; 776 | Medium; RCTs | Consistent (I^2^=28.2%) | Direct | Imprecise | RD 0.03 (−0.04 to 0.09) | Insufficient
Nausea
2; 712 | Medium; RCTs | Consistent (I^2^=0%) | Direct | Imprecise | RD 0.05 (0.00 to 0.09) | Low
Insomnia
1; 301 | Medium; RCT | NA, single study | Direct | Imprecise | RD 0.03 (−0.06 to 0.11) | Insufficient
Dry mouth
0; 0 | NA | NA | NA | NA | NA | Insufficient
Diarrhea
1; 64 | Medium; RCT | NA, single study | Direct | Imprecise | RD 0.24 (0.01 to 0.47) | Insufficient
Dizziness
0; 0 | NA | NA | NA | NA | NA | Insufficient
Fatigue
0; 0 | NA | NA | NA | NA | NA | Insufficient
Somnolence
1; 411 | Medium; RCT | NA, single study | Direct | Imprecise | RD 0.05 (0.00 to 0.10) | Insufficient
Drowsiness
0; 0 | NA | NA | NA | NA | NA | Insufficient
Decreased appetite
0; 0 | NA | NA | NA | NA | NA | Insufficient
Increased appetite
0; 0 | NA | NA | NA | NA | NA | Insufficient
Constipation
0; 0 | NA | NA | NA | NA | NA | Insufficient

Abbreviations: CI = confidence interval; NA = not applicable; RCT = randomized controlled trial

Table G-48 Strength of evidence for adverse events for paroxetine compared with placebo

| Domains Pertaining to Strength of evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
Withdrawals due to Adverse Events
3; 911 | Medium; RCTs | Consistent (I^2^=0%) | Direct | Precise | RD 0.04 (0.00 to 0.07) | Moderate
Headaches
0; 0 | NA | NA | NA | NA | NA | Insufficient
Nausea
2; 886 | Medium; RCTs | Consistent | Direct | Imprecise | RD 0.11 (0.04 to 0.18)^a^ | Low
Insomnia
0; 0 | NA | NA | NA | NA | NA | Insufficient
Dry mouth
1; 323 | Medium; RCT | NA, single study | Direct | Precise | RD 0.10 (0.04 to 0.16) | Low
Diarrhea
1; 563 | Medium; RCT | NA, single study | Direct | Imprecise | Incidence of at least 10% and twice that of placebo23 | Insufficient
Dizziness
0; 0 | NA | NA | NA | NA | NA | Insufficient
Fatigue
0; 0 | NA | NA | NA | NA | NA | Insufficient
Somnolence
2; 886 | Medium; RCTs | Consistent | Direct | Imprecise | RD 0.13 (0.07 to 0.20)^a^ | Low
Drowsiness
1; 25 | Medium; RCT | NA, single study | Direct | Imprecise | RD −0.15 (−0.51 to 0.21) | Insufficient
Decreased appetite
0; 0 | NA | NA | NA | NA | NA | Insufficient
Increased appetite
0; 0 | NA | NA | NA | NA | NA | Insufficient
Constipation
0; 0 | NA | NA | NA | NA | NA | Insufficient
Sexual adverse effects
1; 563 | Medium; RCT | NA, single study | Direct | Imprecise | Incidence of at least 10% and twice that of placebo23 | Insufficient

a Data are based on the only trial (N=323) reporting sufficient data to determine the risk difference.20 One additional trial (N=563) that provided narrative description reported that the most commonly reported adverse events associated with paroxetine use (with an incidence of at least 10% and twice that of placebo) were asthenia, diarrhea, abnormal ejaculation, impotence, nausea, and somnolence.23

Abbreviations: CI = confidence interval; NA = not applicable; RCT = randomized controlled trial

Table G-49 Strength of evidence for adverse events for sertraline compared with placebo

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
Withdrawals due to Adverse Events
7; 1122 | Medium; RCTs | Consistent (I^2^=0%) | Direct | Imprecise | RD 0.01 (−0.01 to 0.04) | Low
Headaches
6; 1028 | Medium; RCTs | Consistent (I^2^=0.0%) | Direct | Imprecise | RD 0.03 (−0.03 to 0.08) | Insufficient
Nausea
7; 1061 | Medium; RCTs | Consistent (I^2^=0%) | Direct | Precise | RD 0.09 (0.04 to 0.13) | Moderate
Insomnia
6; 1019 | Medium; RCTs | Inconsistent (I^2^=44.8%) | Direct | Imprecise | RD 0.05 (−0.02 to 0.11) | Insufficient
Dry mouth
5; 859 | Medium; RCTs | Consistent (I^2^=0%) | Direct | Imprecise | RD 0.03 (−0.01 to 0.07) | Insufficient
Diarrhea
5; 986 | Medium; RCTs | Consistent (I^2^=0%) | Direct | Precise | RD 0.12 (0.07 to 0.17) | Moderate
Dizziness
2; 385 | Medium; RCTs | Consistent (I^2^=0%) | Direct | Imprecise | RD 0.04 (−0.02 to 0.10) | Insufficient
Fatigue
4; 762 | Medium; RCTs | Consistent (I^2^=0%) | Direct | Precise | RD 0.07 (0.03 to 0.11) | Moderate
Somnolence
2; 521 | Medium; RCTs | Inconsistent (I^2^=51.6%) | Direct | Imprecise | RD 0.01 (−0.08 to 0.09) | Insufficient
Drowsiness
4; 507 | Medium; RCTs | Consistent (I^2^=0%) | Direct | Imprecise | RD 0.05 (−0.00 to 0.11) | Insufficient
Decreased appetite
5; 705 | Medium; RCTs | Consistent^a^ (I^2^=43.7%) | Direct | Precise | RD 0.07 (0.01 to 0.13) | Moderate
Increased appetite
2; 75 | Medium; RCTs | Consistent (I^2^=0%) | Direct | Imprecise | −0.01 (−0.19 to 0.16) | Insufficient
Constipation
2; 422 | Medium; RCT | Consistent (I^2^=0%) | Direct | Imprecise | 0.02 (−0.03 to 0.07) | Insufficient

a Although there was some variation in magnitude of effect, the direction of effect favored placebo in all five studies

Abbreviations: CI = confidence interval; NA = not applicable; RCT = randomized controlled trial

Table G-50 Strength of evidence for adverse events for venlafaxine compared with placebo

| Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect | Strength of Evidence
Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | High, Moderate, Low, Insufficient
Withdrawals due to Adverse Events
2; 687 | Medium; RCTs | Consistent (I^2^=28.7%) | Direct | Imprecise | RD 0.02 (−0.03 to 0.07) | Low
Headaches
2; 687 | Medium; RCTs | Consistent (I^2^=0%) | Direct | Imprecise | RD 0.01 (−0.06 to 0.07) | Low
Nausea
2; 687 | Medium; RCTs | Consistent (I^2^=0%) | Direct | Precise | RD 0.10 (0.05 to 0.16) | Moderate
Insomnia
2; 687 | Medium; RCTs | Inconsistent (I^2^=59.3%) | Direct | Imprecise | RD 0.01 (−0.06 to 0.08) | Insufficient
Dry mouth
2; 687 | Medium; RCTs | Consistent (I^2^=0%) | Direct | Precise | RD 0.07 (0.02 to 0.11) | Moderate
Diarrhea
1; 358 | Medium; RCTs | NA, single study | Direct | Imprecise | RD −0.02 (−0.09 to 0.05) | Insufficient
Dizziness
2; 687 | Medium; RCTs | Consistent (I^2^=0%) | Direct | Precise | RD 0.06 (0.01 to 0.11) | Moderate
Fatigue
2; 687 | Medium; RCTs | Consistent (I^2^=0%) | Direct | Imprecise | RD 0.03 (−0.01 to 0.07) | Insufficient
Somnolence
2; 687 | Medium; RCTs | Consistent (I^2^=0%) | Direct | Imprecise | RD −0.00 (−0.04 to 0.04) | Low
Decreased appetite
1; 358 | Medium; RCTs | NA, single study | Direct | Imprecise | RD 0.06 (−0.00 to 0.11) | Insufficient
Constipation
2; 687 | Medium; RCTs | Inconsistent (I^2^=68%) | Direct | Imprecise | RD 0.06 (−0.02 to 0.13) | Insufficient

Abbreviations: CI = confidence interval; NA = not applicable; RCT = randomized controlled trial