# Meta-Analysis

## Key Question 1

### Cognitive Processing Therapy: Meta-Analysis Results

Figure F-1 Change in CAPS for cognitive processing therapy compared with control, by type of comparator

Timing of outcome assessment: 17 weeks (Chard, 2005), 10 weeks (Monson, 2006), 6 weeks (Resick, 2002), 12 weeks (Forbes, 2012).

Figure F-1 is titled “Change in CAPS for cognitive processing therapy compared with control, by type of comparator.” The figure displays a forest plot reporting the weighted mean difference in CAPS scores stratified by cognitive processing therapy compared to waitlist and cognitive processing therapy compared to usual care. The plot depicts greater reductions in CAPS scores for patients treated with cognitive processing therapy than waitlist (3 trials, weighted mean difference −35.89, 95% CI −52.81 to −18.97, I2 = 88.1%) or usual care (1 trial, weighted mean difference −20.68, 95% CI −31.95 to −9.41). The overall analysis favored cognitive processing therapy (weighted mean difference −32.17, 95% CI −46.29 to −18.05, I2 = 86.5%).

Table F-1 Change in CAPS for cognitive processing therapy compared with control: Statistics with one study removed

Study Omitted | Overall Estimate | 95% Confidence Interval
Chard, 2005 | −25.85 | (−35.06 to −16.64)
Forbes, 2012 | −35.89 | (−52.81 to −18.97)
Monson, 2006 | −35.77 | (−52.82 to −18.72)
Resick, 2002 | −31.17 | (−51.06 to −11.27)
Combined | −32.17 | (−46.29 to −18.05)

Table F-2 Change in CAPS for cognitive processing therapy compared with control: Statistics with one study removed, by type of comparator

Study Omitted | Overall Estimate | 95% Confidence Interval
Waitlist
Chard, 2005 | −28.23 | (−41.53 to −14.93)
Monson, 2006 | −43.14 | (−58.85 to −27.43)
Resick, 2002 | −36.30 | (−65.31 to −7.30)
Combined | −35.89 | (−52.81 to −18.97)
Usual Care
NA | NA | NA

Figure F-2 Loss of PTSD diagnosis for cognitive processing therapy compared with control, by type of comparator

Timing of outcome assessment: 17 weeks (Chard, 2005), 10 weeks (Monson, 2006), 6 weeks (Resick, 2002), 12 weeks (Forbes, 2012).

Figure F-2 is titled “Loss of PTSD diagnosis for cognitive processing therapy compared with control, by type of comparator.” The figure displays a forest plot reporting the risk difference in loss of PTSD diagnosis stratified by cognitive processing therapy compared to waitlist and cognitive processing therapy compared to usual care. The plot depicts that 52% more patients treated with cognitive processing therapy achieved loss of PTSD diagnosis than waitlist (3 trials, risk difference 0.52, 95% CI 0.37 to 0.67, I2 = 61.4%) and 20% more patients treated with cognitive processing therapy achieved loss of PTSD diagnosis than usual care (1 trial, risk difference 0.20, 95% CI −0.00 to 0.39). The overall analysis favored cognitive processing therapy (risk difference 0.44, 95% CI 0.26 to 0.62, I2 = 77.9%).

Table F-3 Loss of PTSD diagnosis for cognitive processing therapy compared with control: Statistics with one study removed

Study Omitted | Overall Estimate | 95% Confidence Interval
Chard, 2005 | 0.37 | (0.19 to 0.55)
Forbes, 2012 | 0.52 | (0.37 to 0.67)
Monson, 2006 | 0.46 | (0.23 to 0.70)
Resick, 2002 | 0.41 | (0.14 to 0.68)
Combined | 0.44 | (0.26 to 0.62)

Table F-4 Loss of PTSD diagnosis for cognitive processing therapy compared with control: Statistics with one study removed, by type of comparator

Study Omitted | Overall Estimate | 95% Confidence Interval
Waitlist
Chard, 2005 | 0.45 | (0.32 to 0.59)
Monson, 2006 | 0.57 | (0.43 to 0.72)
Resick, 2002 | 0.52 | (0.23 to 0.80)
Combined | 0.52 | (0.37 to 0.67)
Usual Care
NA | NA | NA

Figure F-3 Change in BDI for cognitive processing therapy compared with control, by type of comparator

Timing of outcome assessment: 17 weeks (Chard, 2005), 10 weeks (Monson, 2006), 6 weeks (Resick, 2002), 12 weeks (Forbes, 2012).

Figure F-3 is titled “Change in BDI for cognitive processing therapy compared with control, by type of comparator.” The figure displays a forest plot reporting the weighted mean difference in BDI scores stratified by cognitive processing therapy compared to waitlist and cognitive processing therapy compared to usual care. The plot depicts greater reductions in BDI scores for patients treated with cognitive processing therapy than waitlist (3 trials, weighted mean difference −11.93, 95% CI −18.92 to −4.93, I2 = 87.2%) or usual care (1 trial, weighted mean difference −6.47, 95% CI −12.49 to −0.45). The overall analysis favored cognitive processing therapy (weighted mean difference −10.69, 95% CI 16.45 to −4.92, I2 = 83.5%).

Table F-5 Change in BDI for cognitive processing therapy compared with control: Statistics with one study removed

Study Omitted | Overall Estimate | 95% Confidence Interval
Chard, 2005 | −8.24 | (−10.91 to −5.57)
Forbes, 2012 | −11.93 | (−18.92 to −4.93)
Monson, 2006 | −12.09 | (−19.13 to −5.05)
Resick, 2002 | −10.78 | (−19.43 to −2.13)
Combined | −10.69 | (−16.45 to −4.92)

Table F-6 Change in BDI for cognitive processing therapy compared with control: Statistics with one study removed, by type of comparator

Study Omitted | Overall Estimate | 95% Confidence Interval
Waitlist
Chard, 2005 | −8.58 | (−12.24 to −4.91)
Monson, 2006 | −14.58 | (−23.21 to −5.96)
Resick, 2002 | −12.79 | (−25.09 to −0.48)
Combined | −11.93 | (−18.92 to −4.93)
Usual Care
NA | NA | NA

### Cognitive Therapy: Meta-Analysis Results

Note: These are the cognitive therapy studies that were not specified as cognitive processing therapy

Figure F-4 Change in PTSD symptoms for cognitive therapy compared with control, by type of comparator

Timing of outcome assessment: 3 months for all studies.

Figure F-4. is titled “Change in PTSD symptoms for cognitive therapy compared with control, by type of comparator.” The figure displays a forest plot reporting the standard mean difference in PTSD symptoms stratified by cognitive therapy compared to waitlist, cognitive therapy compared to self-help booklet, and cognitive therapy compared to usual care. The plot depicts greater reductions in PTSD symptom scores for patients treated with cognitive therapy than waitlist (2 trials, standard mean difference −1.54, 95% CI −2.17 to −0.92, I2 = 31.1%), self-help booklet (1 trial, standard mean difference −1.48, 95% CI −2.09 to −0.87), or usual care (1 trial, standard mean difference −0.34, 95% CI −0.83 to 0.16). The overall analysis favored cognitive therapy (standard mean difference −1.22, 95% CI −1.91 to −0.53, I2 = 79.6%).

Figure F-5 Change in PTSD symptoms for cognitive therapy compared with control, by type of comparator

Timing of outcome assessment: 3 months for all studies.

Figure F-5. is titled “Change in PTSD symptoms for cognitive therapy compared with control, by type of comparator.” The figure displays a forest plot reporting the standard mean difference in PTSD symptoms stratified by cognitive therapy compared to waitlist, cognitive therapy compared to self-help booklet, and cognitive therapy compared to usual care. The plot depicts greater reductions in PTSD symptom scores for patients treated with cognitive therapy than waitlist (2 trials, standard mean difference −1.44, 95% CI −2.06 to −0.81, I2 = 33.5%), self-help booklet (1 trial, standard mean difference −1.02, 95% CI −1.59 to −0.44), or usual care (1 trial, standard mean difference −0.34, 95% CI −0.83 to 0.16). The overall analysis favored cognitive therapy (standard mean difference −1.03, 95% CI −1.61 to −0.46, I2 = 71.8%).

Figure F-6 Loss of PTSD diagnosis for cognitive therapy compared with control, by type of comparator

Figure F-6 is titled “Loss of PTSD diagnosis for cognitive therapy compared with control, by type of comparator.” The figure displays a forest plot reporting the risk difference in loss of PTSD diagnosis stratified by cognitive therapy compared to waitlist, cognitive therapy compared to self-help booklet, and cognitive therapy compared to usual care. The plot depicts that 66% more patients treated with cognitive therapy achieved loss of PTSD diagnosis than waitlist (2 trials, risk difference 0.66, 95% CI 0.50 to 0.82, I2 = 0.0%), 57% more patients treated with cognitive therapy achieved loss of PTSD diagnosis than self-help booklet (1 trial, risk difference 0.57, 95% CI 0.36 to 0.79), and 15% more patients treated with cognitive therapy achieved loss of PTSD diagnosis than usual care (1 trial, risk difference 0.15, 95% CI −0.04 to 0.33). The overall analysis favored cognitive therapy (risk difference 0.51, 95% CI 0.24 to 0.78, I2 = 84.7%).

Figure F-7 Change in BDI for cognitive therapy compared with control, by type of comparator, weighted mean difference

Timing of outcome assessment: 3 months for all studies.

Figure F-7 is titled “Change in BDI for cognitive therapy compared with control, by type of comparator, weighted mean difference.” The figure displays a forest plot reporting the weighted mean difference in BDI scores stratified by cognitive therapy compared to waitlist, cognitive therapy compared to self-help booklet, and cognitive therapy compared to usual care. The plot depicts greater reductions in BDI scores for patients treated with cognitive therapy than waitlist (2 trials, weighted mean difference −9.12, 95% CI −12.87 to −5.38, I2 = 0.0%), self-help booklet (1 trial, weighted mean difference −9.12, 95% CI −12.87 to −5.38), or usual care (1 trial, weighted mean difference −8.71, 95% CI −15.49 to 1.93). The overall analysis favored cognitive therapy (weighted mean difference −8.34, 95% CI −10.83 to −5.85, I2 = 0.0%).

Figure F-8 Change in BDI for cognitive therapy compared with control, by type of comparator, Cohen’s d

Timing of outcome assessment: 3 months for all studies.

Figure F-8 is titled “Change in BDI for cognitive therapy compared with control, by type of comparator, Cohen’s d.” The figure displays a forest plot reporting the standard mean difference in BDI scores stratified by cognitive therapy compared to waitlist, cognitive therapy compared to self-help booklet, and cognitive therapy compared to usual care. The plot depicts greater reductions in BDI scores for patients treated with cognitive therapy than waitlist (2 trials, standard mean difference −1.06, 95% CI −1.52 to −0.60, I2 = 0.0%), self-help booklet (1 trial, standard mean difference −1.06, 95% CI −1.63 to −0.48), or usual care (1 trial, standard mean difference −0.62, 95% CI −1.12 to −0.12). The overall analysis favored cognitive therapy (standard mean difference −0.91, 95% CI −1.20 to −0.62, I2 = 0.0%).

Figure F-9 Change in BAI for cognitive therapy compared with control, by type of comparator, weighted mean difference

Timing of outcome assessment: 3 months for all studies.

Figure F-9 is titled “Change in BAI for cognitive therapy compared with control, by type of comparator, weighted mean difference.” The figure displays a forest plot reporting the weighted mean difference in BAI scores stratified by cognitive therapy compared to waitlist, cognitive therapy compared to self-help booklet, and cognitive therapy compared to usual care. The plot depicts greater reductions in BAI scores for patients treated with cognitive therapy than waitlist (2 trials, weighted mean difference −10.51, 95% CI −14.33 to −6.68, I2 = 0.0%), self-help booklet (1 trial, weighted mean difference −9.00, 95% CI −13.64 to −4.36), or usual care (1 trial, weighted mean difference −5.55, 95% CI −12.44 to 1.34). The overall analysis favored cognitive therapy (weighted mean difference −9.22, 95% CI −11.93 to −6.51, I2 = 0.0%).

Figure F-10 Change in BAI for cognitive therapy compared with control, by type of comparator, Cohen’s d

Timing of outcome assessment: 3 months for all studies.

Figure F-10 is titled “Change in BAI for cognitive therapy compared with control, by type of comparator, Cohen’s d.” The figure displays a forest plot reporting the standard mean difference in BAI scores stratified by cognitive therapy compared to waitlist, cognitive therapy compared to self-help booklet, and cognitive therapy compared to usual care. The plot depicts greater reductions in BAI scores for patients treated with cognitive therapy than waitlist (2 trials, standard mean difference −1.20, 95% CI −1.67 to −0.73, I2 = 0.0%), self-help booklet (1 trial, standard mean difference −1.07, 95% CI −1.65 to −0.49), or usual care (1 trial, standard mean difference −0.39, 95% CI −0.88 to 0.10). The overall analysis favored cognitive therapy (standard mean difference −0.93, 95% CI −1.36 to −0.50, I2 = 51.1%).

Figure F-11 Change in Sheehan’s Disability Score for cognitive therapy compared with control, by type of comparator, weighted mean difference

Timing of outcome assessment: 3 months for all studies.

Figure F-11 is titled “Change in Sheehan’s Disability Score for cognitive therapy compared with control, by type of comparator, weighted mean difference.” The figure displays a forest plot reporting the weighted mean difference in SDS scores stratified by cognitive therapy compared to waitlist, cognitive therapy compared to self-help booklet, and cognitive therapy compared to usual care. The plot depicts greater reductions in Sheehan’s Disability scores for patients treated with cognitive therapy than waitlist (2 trials, weighted mean difference −3.13, 95% CI −5.09 to −1.18, I2 = 74.9%), self-help booklet (1 trial, weighted mean difference −1.80, 95% CI −3.12 to −0.48), or usual care (1 trial, weighted mean difference −1.80, 95% CI −3.12 to −0.48). The overall analysis favored cognitive therapy (weighted mean difference −2.66, 95% CI −4.00 to −1.33, I2 = 65.9%).

Figure F-12 Change in Sheehan’s Disability Score for cognitive therapy compared with control, by type of comparator, Cohen’s d

Timing of outcome assessment: 3 months for all studies.

Figure F-12 is titled “Change in Sheehan’s Disability Score for cognitive therapy compared with control, by type of comparator, Cohen’s d.” The figure displays a forest plot reporting the standard mean difference in SDS scores stratified by cognitive therapy compared to waitlist and cognitive therapy compared to self-help booklet. The plot depicts greater reductions in Sheehan’s Disability scores for patients treated with cognitive therapy than waitlist (2 trials, standard mean difference −1.41, 95% CI −2.41 to −0.41, I2 = 71.6%) or self-help booklet (1 trial, standard mean difference −0.73, 95% CI −1.29 to −0.17). The overall analysis favored cognitive therapy (standard mean difference −1.13, 95% CI −1.76 to −0.51, I2 = 63.1%).

### CBT Exposure-Based Therapy: Meta-Analysis Results

Figure F-13 PTSD symptom reduction (any measure) for exposure therapy compared with control, by type of comparator

Timing of outcome assessment: 8 weeks (Basoglu, 2007), 12 weeks (Foa, 2005), 9 weeks (Foa, 1999), 6 weeks (Resick, 2002), 4.5 weeks (Rothbaum, 2005), 9 to 15 weeks (Nacasch), “post-treatment” or 8 to15 weeks (Asukai, 2010).

Figure F-13 is titled “PTSD symptom reduction (any measure) for exposure compared with control, by type of comparator.” The figure displays a forest plot reporting the standard mean difference in PTSD symptoms stratified by exposure therapy compared to waitlist and exposure therapy compared to usual care. The plot depicts greater reductions in PTSD symptoms for patients treated with exposure therapy than waitlist (5 trials, standardized mean difference −1.16, 95% CI −1.40 to −0.91, I2 = 0.0%) or usual care (2 trials, standardized mean difference −1.79, 95% CI −2.43 to −1.15, I2 = 0.0%). The overall analysis favored exposure therapy (standardized mean difference −1.27, 95% CI −1.54 to −1.00, I2 = 23.3%).

Table F-7 PTSD symptom reduction (any measure) for exposure therapy compared with control, by type of comparator: Statistics with one study removed

Study Omitted | Overall Estimate | 95% Confidence Interval
Basoglu, 2007 | −1.30 | (−1.62 to −0.99)
Foa, 2005 | −1.38 | (−1.64 to −1.11)
Foa, 1999 | −1.26 | (−1.58 to −0.95)
Resick, 2002 | −1.31 | (−1.67 to −0.95)
Rothbaum, 2005 | −1.24 | (−1.55 to −0.93)
Asukai, 2010 | −1.26 | (−1.56 to −0.96)
Nacasch, 2011 | −1.18 | (−1.42 to –−0.94)
Combined | −1.27 | (−1.54 to −1.00)

Table F-8 PTSD symptom reduction (any measure) for exposure therapy compared with control, by type of comparator: Statistics with one study removed, by type of comparator

Study Omitted | Overall Estimate | 95% Confidence Interval
Waitlist
Basoglu, 2007 | −1.17 | (−1.47 to −0.88)
Foa, 2005 | −1.29 | (−1.58 to −1.00)
Foa, 1999 | −1.13 | (−1.40 to −0.85)
Resick, 2002 | −1.14 | (−1.48 to −0.80)
Rothbaum, 2005 | −1.10 | (−1.36 to −0.84)
Combined | −1.16 | (−1.40 to −0.91)
Usual Care
Asukai, 2010 | −2.07 | (−2.97 to −1.17)
Nacasch, 2011 | −1.49 | (−2.40 to −0.58)
Combined | −1.79 | (−2.43 to −1.15)

Figure F-14 PTSD symptom reduction (any measure) for exposure therapy compared with control, by type of comparator: Sensitivity analysis including high risk of bias studies

Note: Difede et al., 2007, Johnson et al., 2006, and Foa et al., 1991 were rated as having a high risk of bias.

Timing of outcome assessment: 8 weeks (Basoglu, 2007), 24 weeks (Difede 2007), 12 weeks (Foa, 2005), 9 weeks (Foa, 1999 and Foa, 1991), 6 to 9 sessions (Johnson, 2006), 6 weeks (Resick, 2002), 4.5 weeks (Rothbaum, 2005) “post-treatment” or 8 to 15 weeks (Asukai, 2010), 9 to 15 weeks (Nacasch).

Figure F-14 is titled “PTSD symptom reduction (any measure) for exposure compared with control, by type of comparator: Sensitivity analysis including high risk of bias studies.” The figure displays a forest plot reporting the standardized mean difference in PTSD symptoms stratified by exposure therapy compared to waitlist or exposure therapy compared to usual care. The plot depicts greater reductions in PTSD symptoms for patients treated with exposure therapy than waitlist (9 trials, standardized mean difference −1.13, 95% CI −1.33 to −0.92, I2 = 0.0%) or usual care (2 trials standardized mean difference −1.79, 95% CI −2.43 to −1.15, I2 = 0.0%). The overall analysis favored exposure therapy (standardized mean difference −1.19, 95% CI −1.38 to −0.99, I2 = 0.472).

Figure F-15 PTSD symptom reduction (any measure) for exposure therapy compared with control, by type of comparator: Sensitivity analysis including present centered therapy

Timing of outcome assessment: 8 weeks (Basoglu, 2007), 12 weeks (Foa, 2005), 9 weeks (Foa, 1999), 6 weeks (Resick, 2002), 4.5 weeks (Rothbaum, 2005), “post-treatment” or 8 to 15 weeks (Asukai, 2010), 9 to 15 weeks (Nacasch), 10 weeks (Schnurr 2007).

Figure F-15 is titled “PTSD symptom reduction (any measure) for exposure therapy compared with control, by type of comparator: Sensitivity analysis including present centered therapy.” The figure displays a forest plot reporting the standardized mean difference in PTSD symptoms stratified by exposure therapy compared to waitlist, exposure therapy compared to usual care, and exposure therapy compared to present centered therapy. The plot depicts greater reductions in PTSD symptoms for patients treated with exposure therapy than waitlist (5 trials, standardized mean difference −1.16, 95% CI −1.40 to −0.91, I2 = 0.0%), usual care (2 trials, standardized mean difference −1.79, 95% CI −2.43 to −1.15, I2 = 0.0%), or present centered therapy (1 trial, standardized mean difference −0.26, 95% CI −0.50 to −0.03,). The overall analysis favored exposure therapy (standardized mean difference −1.17, 95% CI −1.63 to −0.71, I2 = 83.3%).

Table F-9 PTSD symptom reduction (any measure) for exposure therapy compared with control: Sensitivity analysis including present centered therapy, statistics with one study removed

Study Omitted | Overall Estimate | 95% Confidence Interval
Basoglu, 2007 | −1.18 | (−1.69 to −0.67)
Foa, 2005 | −1.24 | (−1.80 to −0.69)
Foa, 1999 | −1.14 | (−1.64 to −0.64)
Resick, 2002 | −1.17 | (−1.70 to −0.64)
Rothbaum, 2005 | −1.12 | (−1.61 to −0.63)
Asukai, 2010 | −1.14 | (−1.63 to −0.64)
Nacasch, 2011 | −1.06 | (−1.52 to −0.61)
Combined | −1.17 | (−1.63 to −0.71)

Figure F-16 PTSD symptom reduction (any measure) for exposure therapy compared with control, by type of comparator: Sensitivity analysis including present centered therapy and high risk of bias studies

Note: Ready et al., 2010, Difede et al., 2007, Johnson et al., 2006, and Foa et al., 1991 were rated as having a high risk of bias.

Timing of outcome assessment: 8 weeks (Basoglu, 2007), 24 weeks (Difede 2007), 12 weeks (Foa, 2005), 9 weeks (Foa, 1999 and Foa, 1991), 6 to 9 sessions (Johnson, 2006), 4.5 weeks (Resick, 2002), 4.5 weeks (Rothbaum, 2005), “post-treatment” or 8 to 15 weeks (Asukai, 2010), 9 to 15 weeks (Nacasch), 10 sessions (Ready, 2010), 10 weeks (Schnurr 2007).

Figure F-16 is titled “PTSD symptom reduction (any measure) for exposure therapy compared with control, by type of comparator: Sensitivity analysis including present centered therapy and high risk of bias studies.” The figure displays a forest plot reporting the standardized mean difference in PTSD symptoms stratified by exposure therapy compared to waitlist, exposure therapy compared to usual care, and exposure therapy compared to present centered therapy. The plot depicts greater reductions in PTSD symptoms for patients treated with exposure therapy than waitlist (9 trials, standardized mean difference −1.13, 95% CI −1.33 to −0.92, I2 = 0.0%), usual care (2 trials, standardized mean difference −1.79, 95% CI −2.43 to −1.15, I2 = 0.0%), or present centered therapy (2 trials, standardized mean difference −0.26, 95% CI −0.49 to −0.03, I2 = 0.0%). The overall analysis favored exposure therapy (standardized mean difference −1.09, 95% CI −1.43 to −0.75, I2 = 73.7%).

Figure F-17 Change in CAPS for exposure therapy compared with control, by type of comparator

Timing of outcome assessment: 8 weeks (Basoglu, 2007), 12 weeks, 6 weeks (Resick, 2002), 4.5 weeks (Rothbaum, 2005), “post-treatment” or 8 to 15 weeks (Asukai, 2010).

Figure F-17 is titled “Change in CAPS for exposure therapy compared with control, by type of comparator.” This figure displays a forest plot reporting the weighted mean difference in CAPS scores stratified by exposure therapy compared to waitlist and exposure therapy compared to usual care. The plot depicts greater reductions in CAPS scores for patients treated with exposure therapy than waitlist (3 trials, weighted mean difference −27.85, 95% CI −34.36 to −21.34, I2 = 9.7%) or usual care (1 trial, weighted mean difference −41.30, 95% CI −63.47 to −19.13). The overall analysis favored exposure therapy (weighted mean difference −28.89, 95% CI −35.46 to −22.32, I2 = 14.4%).

Table F-10 Change in CAPS for exposure therapy compared with control, by type of comparator: Statistics with one study removed

Study Omitted | Overall Estimate | 95% Confidence Interval
Basoglu, 2007 | −31.54 | (−38.27 to −24.82)
Resick, 2002 | −27.85 | (−38.11 to −17.59)
Rothbaum, 2005 | −28.75 | (−38.91 to −18.59)
Asukai, 2010 | −27.85 | (−34.36 to −21.34)
Combined | −28.89 | (−35.46 to −22.32)

Table F-11 Change in CAPS for exposure therapy compared with control, by type of comparator: Statistics with one study removed, by type of comparator

Study Omitted | Overall Estimate | 95% Confidence Interval
Waitlist
Basoglu, 2007 | −30.56 | (−37.61 to −23.50)
Resick, 2002 | −25.13 | (−34.89 to −15.36)
Rothbaum, 2005 | −26.27 | (−37.34 to −15.21)
Combined | −27.85 | (−34.36 to −21.34)
Usual Care
NA | NA | NA

Figure F-18 Change in CAPS for exposure therapy compared with control, by type of comparator: Sensitivity analysis including high risk of bias studies

Note: Difede et al., 2007, and Johnson et al., 2006 were rated as having a high risk of bias.

Timing of outcome assessment: 8 weeks (Basoglu, 2007), 24 weeks (Difede, 2007), 6–9 sessions (Johnson, 2006), 6 weeks (Resick, 2002), 4.5 weeks (Rothbaum, 2005), “post-treatment” or 8 to 15 weeks (Asukai, 2010).

Figure F-18 is titled “Change in CAPS for exposure therapy compared with control, by type of comparator: Sensitivity analysis including high risk of bias studies.” This figure displays a forest plot reporting the weighted mean difference in CAPS scores stratified by exposure therapy compared to waitlist and exposure therapy compared to usual care. The plot depicts greater reductions in CAPS scores for patients treated with exposure therapy than waitlist (6 trials, weighted mean difference −27.21, 95% CI −32.29 to −22.13, I2 = 0.0%) or usual care (1 trial, weighted mean difference −41.30, 95% CI −63.47 to −19.13). The overall analysis favored exposure therapy (weighted mean difference −27.92, 95% CI −32.87 to −22.96, I2 = 0.0%).

Figure F-19 Change in CAPS for exposure therapy compared with control, by type of comparator: Sensitivity analysis including present centered therapy

Timing of outcome assessment: 8 weeks (Basoglu, 2007), 6 weeks (Resick, 2002), 4.5 weeks (Rothbaum, 2005), “post-treatment” or 8 to 15 weeks (Asukai, 2010), 10 weeks (Schnurr, 2007).

Figure F-19 is titled “Change in CAPS for exposure compared with control, by type of comparator: Sensitivity analysis including present centered therapy.” The figure displays a forest plot reporting the weighted mean difference in CAPS scores stratified by exposure therapy compared to waitlist, exposure therapy compared to usual care, and exposure therapy compared to present centered therapy. The plot depicts greater reductions in CAPS scores for those patients treated with exposure therapy than waitlist (3 trials, weighted mean difference −27.85, 95% CI −34.36 to −21.34, I2 = 9.7%), usual care (1 trial, weighted mean difference −41.30 95% CI −63.47 to −19.13), or present centered therapy (1 trial, weighted mean difference −6.90, 95% CI −12.98 to −0.82). The overall analysis favored exposure therapy (weighted mean difference −24.35, 95% CI −37.20 to −11.51, I2 = 86.3%).

Table F-12 Change in CAPS for exposure therapy compared with control, by type of comparator: Statistics with one study removed

Study Omitted | Overall Estimate | 95% Confidence Interval
Basoglu, 2007 | −25.82 | (−41.91 to −9.74)
Resick, 2002 | −22.48 | (−37.09 to −7.86)
Rothbaum, 2005 | −23.12 | (−38.38 to −7.86)
Asukai, 2010 | −21.53 | (−34.99 to −8.08)
Schnurr, 2007 | −28.89 | (−35.46 to −22.32)
Combined | −24.35 | (−37.20 to −11.51)

Table F-13 Change in CAPS for exposure therapy compared with control, by type of comparator: Statistics with one study removed, by type of comparator

Study Omitted | Overall Estimate | 95% Confidence Interval
Waitlist
Basoglu, 2007 | −30.56 | (−37.62 to −23.50)
Resick, 2002 | −25.13 | (−34.89 to −15.36)
Rothbaum, 2005 | −26.27 | (−37.34 to −15.21)
Combined | −27.85 | (−34.36 to −21.34)
Usual Care
NA | NA | NA
Present Centered Therapy
NA | NA | NA

Figure F-20 Change in CAPS for exposure therapy compared with control, by type of comparator: Sensitivity analysis including present centered therapy and high risk of bias studies

Note: Difede et al., 2007, Ready et al., 2010, and Johnson et al., 2006 were rated as having a high risk of bias.

Timing of outcome assessment: 8 weeks (Basoglu, 2007), 24 weeks (Difede, 2007), 6 to 9 sessions (Johnson, 2006), 6 weeks (Resick, 2002), 4.5 weeks (Rothbaum, 2005), “post-treatment” or 8 to 15 weeks (Asukai, 2010), 10 sessions (Ready, 2010), 10 weeks (Schnurr, 2007).

Figure F-20 is titled “Change in CAPS for exposure compared with control, by type of comparator: Sensitivity analysis including present centered therapy and high risk of bias studies.” This figure displays a forest plot reporting the weighted mean difference in CAPS scores stratified by exposure therapy compared to waitlist, exposure therapy compared to usual care, and exposure therapy compared to present centered therapy. The plot depicts a greater reduction in CAPS scores for patients treated with exposure therapy than waitlist (6 trials, weighted mean difference −27.21, 95% CI −32.29 to −22.13, I2 = 0.0%), usual care (1 trial, weighted mean difference −41.30, 95% CI −63.47 to −19.13), or present centered therapy (2 trials, weighted mean difference −6.94, 95% CI −12.96 to −0.91, I2 = 0.0%). The overall analysis favored exposure therapy (weighted mean difference −23.99, 95% CI −32.72 to −15.26, I2 = 74.9%).

Figure F-21 Loss of PTSD diagnosis for exposure therapy compared with waitlist

Figure F-21 is titled “Loss of PTSD diagnosis for exposure therapy compared with waitlist.” The figure displays a forest plot reporting the risk difference of loss of PTSD diagnosis for exposure therapy compared to waitlist. The overall analysis indicates that 66% more patients treated with exposure therapy achieved loss of PTSD diagnosis than waitlist (3 trials, risk difference 0.66, 95% CI 0.42 to 0.91, I2 = 86.5%).

Table F-14 Loss of PTSD diagnosis for exposure therapy compared with waitlist: Statistics with one study removed

Study Omitted | Overall Estimate | 95% Confidence Interval
Waitlist
Foa, 1999 | 0.69 | (0.34 to 1.05)
Resick, 2002 | 0.75 | (0.48 to 1.02)
Rothbaum, 2005 | 0.54 | (0.43 to −0.65)
Combined | 0.66 | (0.42 to 0.91)

Figure F-22 Loss of PTSD diagnosis for exposure therapy compared with control, by type of comparator: Sensitivity analysis including other comparators

Figure F-22 is titled “Loss of PTSD diagnosis for exposure therapy compared with control, by type of comparator: Sensitivity analysis including other comparators.” This figure displays a forest plot reporting the risk difference of loss of PTSD diagnosis stratified by exposure therapy compared to waitlist and exposure therapy compared to other comparators. The plot depicts that PTSD diagnosis was lost among 66% more patients treated with exposure therapy compared to waitlist (3 trials, risk difference 0.66, 95% CI 0.42 to 0.91, I2 = 86.5%) and 14% more patients treated with exposure therapy compared to other comparators (2 trials, risk difference 0.14, 95% CI 0.03 to 0.24, I2 = 0.0%). The overall analysis favored exposure therapy (risk difference 0.46, 95% CI 0.16 to 0.77, I2 = 94.7%).

Figure F-23 Change in BDI for exposure therapy compared with control, by type of comparator

Timing of outcome assessment: 8 weeks (Basoglu, 2007), 12 weeks (Foa, 2005), 9 weeks (Foa, 1999), 6 weeks (Resick, 2002), 4.5 weeks (Rothbaum, 2005), 9 to 15 weeks (Nacasch, 2011).

Figure F-23 is titled “Change in BDI for exposure therapy compared with control, by type of comparator.” This figure displays a forest plot reporting the weighted mean difference in BDI scores stratified by exposure therapy compared to waitlist and exposure therapy compared to usual care. The plot depicts a greater reduction in BDI scores for patients treated with exposure therapy than waitlist (5 trials, weighted mean difference −8.21, 95% CI −10.42 to −6.00, I2 = 0.0%) or usual care (1 trial, weighted mean difference −8.20, 95% CI −14.56 to −1.84). The overall analysis favored exposure therapy (weighted mean difference −8.21, 95% CI −10.30 to −6.12, I2 = 0.0%).

Table F-15 Change in BDI for exposure therapy compared with control: Statistics with one study removed

Study Omitted | Overall Estimate | 95% Confidence Interval
Basoglu, 2007 | −8.41 | (−10.62 to −6.20)
Foa, 2005 | −8.05 | (−10.36 to −5.75)
Foa, 1999 | −8.17 | (−10.34 to −6.01)
Resick, 2002 | −8.71 | (−11.32 to −6.10)
Rothbaum, 2005 | −7.81 | (−10.09 to −5.52)
Nacasch, 2011 | −8.21 | (−10.42 to −6.00)
Combined | −8.21 | (−10.30 to −6.12)

Table F-16 Change in BDI for exposure therapy compared with control: Statistics with one study removed, by type of comparator

Study Omitted | Overall Estimate | 95% Confidence Interval
Waitlist
Basoglu, 2007 | −8.44 | (−10.79 to −6.08)
Foa, 2005 | −8.03 | (−10.51 to −5.55)
Foa, 1999 | −8.17 | (−10.47 to −5.87)
Resick, 2002 | −8.81 | (−11.68 to −5.95)
Rothbaum, 2005 | −7.75 | (−10.20 to −5.30)
Combined | −8.21 | (−10.42 to −6.00)
Usual Care
NA | NA | NA

Figure F-24 Change in BDI for exposure therapy compared with control, by type of comparator: Sensitivity analysis including high risk of bias studies

Note: Difede et al., 2007, Foa et al., 1991, and Feske et al., 2008 were rated as having a high risk of bias.

Timing of outcome assessment: 8 weeks (Basoglu, 2007), 24 weeks (Difede, 2007), 12 weeks (Foa, 2005), 9 weeks (Foa, 1999 and Foa 1991), 6 weeks (Resick, 2002), 4.5 weeks (Rothbaum, 2005),6 months (Feske, 2008), 9 to 15 weeks (Nacasch, 2011).

Figure F-24 is titled “Change in BDI for exposure therapy compared with control, by type of comparator: Sensitivity analysis including high risk of bias studies.” This figure displays a forest plot reporting the weighted mean difference in BDI scores stratified by exposure therapy compared to waitlist and exposure therapy compared to usual care. The plot depicts a greater reduction in BDI scores for patients treated with exposure therapy than waitlist (7 trials, weighted mean difference −8.03, 95% CI −10.14 to −5.93, I2 = 0.0%) or usual care (2 trials, weighted mean difference −6.70, 95% CI −11.95 to −1.44, I2 = 0.0%). The overall analysis favored exposure therapy (weighted mean difference −7.85, 95% CI −9.80 to −5.89, I2 = 0.0%).

Figure F-25 Change in BDI for exposure therapy compared with control, by type of comparator: Sensitivity analysis including present centered therapy

Timing of outcome assessment: 8 weeks (Basoglu, 2007), 12 weeks (Foa, 2005), 9 weeks (Foa, 1999), 6 weeks (Resick, 2002), 4.5 weeks (Rothbaum, 2005), 9 to 15 weeks (Nacasch, 2011), 10 weeks (Schnurr 2007).

Figure F-25 is titled “Change in BDI for exposure therapy compared with control, by type of comparator: Sensitivity analysis including present centered therapy.” This figure displays a forest plot reporting the weighted mean difference in BDI scores stratified by exposure therapy compared to waitlist, exposure therapy compared to usual care, and exposure therapy compared to present centered therapy. The plot depicts a greater reduction in BDI scores for patients treated with exposure therapy than waitlist (5 trials, weighted mean difference −8.21, 95% CI −10.42 to −6.00, I2 = 0.0%), usual care (1 trial, weighted mean difference −8.20, 95% CI −14.56 to −1.84), or present centered therapy (1 trial, weighted mean difference −3.90, 95% CI −6.50 to −1.30). The overall analysis favored exposure therapy (weighted mean difference −6.91, 95% CI −8.86 to −4.96, I2 = 21.0%).

Table F-17 Change in BDI for exposure therapy compared with control, by type of comparator: Sensitivity analysis including present centered therapy: statistics with one study removed

Study Omitted | Overall Estimate | 95% Confidence Interval
Basoglu, 2007 | −7.12 | (−9.38 to −4.86)
Foa, 2005 | −6.65 | (−8.80 to −4.51)
Foa, 1999 | −6.91 | (−9.06 to −4.76)
Resick, 2002 | −7.05 | (−9.53 to −4.57)
Rothbaum, 2005 | −6.23 | (−8.06 to −4.40)
Nacasch, 2011 | −6.92 | (−9.13 to −4.72)
Schnurr, 2007 | −8.21 | (−10.30 to −6.12)
Combined | −6.91 | (−8.86 to −4.96)

Table F-18 Change in BDI for exposure therapy compared with control, by type of comparator: Sensitivity analysis including present centered therapy: statistics with one study removed, by type of comparator

Study Omitted | Overall Estimate | 95% Confidence Interval
Waitlist
Basoglu, 2007 | −8.44 | (−10.79 to −6.08)
Foa, 2005 | −8.03 | (−10.51 to −5.55)
Foa, 1999 | −8.17 | (−10.47 to −5.87)
Resick, 2002 | −8.82 | (−11.68 to −5.95)
Rothbaum, 2005 | −7.75 | (−10.20 to −5.30)
Combined | −8.21 | (−10.42 to −6.00)
Usual Care
NA | NA | NA
Present Centered Therapy
NA | NA | NA

Figure F-26 Change in BDI for exposure therapy compared with control, by type of comparator: Sensitivity analysis including present centered therapy and high risk of bias studies

Note: Difede et al., 2007, Foa et al., 1991, Ready et al., 2010, and Feske et al., 2008 were rated as having a high risk of bias.

Timing of outcome assessment: 8 weeks (Basoglu, 2007), 24 weeks (Difede, 2007), 12 weeks (Foa, 2005), 9 weeks (Foa, 1991 and Foa 1999), 6 weeks (Resick, 2002), 4.5 weeks (Rothbaum, 2005), 6 months (Feske, 2008), 9 to 15 weeks (Nacasch, 2011), 10 sessions (Ready, 2010), 10 weeks (Schnurr 2007).

Figure F-26 is titled “Change in BDI for exposure therapy compared with control, by type of comparator: Sensitivity analysis including present centered therapy and high risk of bias studies.” This figure displays a forest plot reporting the weighted mean difference in BDI scores stratified by exposure therapy compared to waitlist, exposure therapy compared to usual care, and exposure therapy compared to present centered therapy. The plot depicts a greater reduction in BDI scores for patients treated with exposure therapy than waitlist (7 trials, weighted mean difference −8.03, 95% CI −10.14 to −5.93, I2 =0.0%), usual care (2 trials, weighted mean difference −6.70, 95% CI −11.95 to −1.44, I2 0.0%), or present centered therapy (2 trials, weighted mean difference −3.68, 95% CI −6.22 to −1.15, I2= 0.0%). The overall analysis favored exposure therapy (weighted mean difference −6.29, 95% CI −7.84 to −4.75, I2=0.0%).

Figure F-27 Change in CAPS for exposure therapy compared with cognitive therapy, by type of cognitive therapy

Timing of outcome assessment: mean 16 weeks (Marks, 1998), following 16 sessions (Tarrier, 1999), 6 weeks (Resick, 2002).

Figure F-27 is titled “Change in CAPS for exposure therapy compared with cognitive therapy, by type of cognitive therapy.” This figure displays a forest plot reporting the weighted mean difference in CAPS scores stratified by exposure therapy compared to cognitive therapy and exposure therapy compared to cognitive processing therapy. The plot depicts a greater reduction in CAPS scores for patients treated with cognitive therapy (2 trials, weighted mean difference 4.81, 95% CI −4.54 to 14.16, I2 = 0.0%) and cognitive processing therapy (1 trial, weighted mean difference 3.97, 95% CI −5.95 to 13.89) than exposure therapy.

Figure F-28 Loss of PTSD diagnosis for exposure therapy compared with cognitive therapy, by type of cognitive therapy

Timing of outcome assessment: mean 16 weeks (Marks, 1998), following 16 sessions (Tarrier, 1999), 6 weeks (Resick, 2002).

Figure F-28 is titled “Loss of PTSD for exposure therapy compared with cognitive therapy, by type of cognitive therapy.” This figure displays a forest plot reporting the risk difference of loss of PTSD diagnosis stratified by exposure therapy compared to cognitive therapy and exposure therapy compared to cognitive processing therapy. The plot depicts that PTSD diagnosis was lost among 13% more patients treated with exposure therapy than cognitive therapy (2 trials, risk difference 0.13, 95% CI −0.06 to 0.32, I2 =0.0%). No difference was found between patients treated with exposure therapy and cognitive processing therapy (1 trial, risk difference 0.0, 95% CI −0.18 to 0.18).

Figure F-29 Change in BDI for exposure therapy compared with cognitive therapy, by type of cognitive therapy

Timing of outcome assessment: mean 16 weeks (Marks, 1998), following 16 sessions (Tarrier, 1999), 6 weeks (Resick, 2002).

Figure F-29 is titled “Change in BDI for exposure therapy compared with cognitive therapy, by type of cognitive therapy.” This figure displays a forest plot reporting the weighted mean difference in BDI scores stratified by exposure therapy compared to cognitive therapy and exposure therapy compared to cognitive processing therapy. The plot depicts a greater reduction in BDI scores in patients treated with cognitive therapy (2 trials, weighted mean difference 2.75, 95% CI −1.94 to 7.43, I2 =0.0%) and cognitive processing therapy (1 trial, weighted mean difference 2.94, 95% CI −0.75 to 6.63) than exposure therapy.

Figure F-30 PTSD symptom reduction for exposure therapy compared with stress inoculation therapy, by instrument

Timing of outcome assessment: 9 weeks

Figure F-30 is titled “PTSD symptom reduction for exposure therapy compared with stress inoculation therapy, by instrument.” This figure displays a forest plot reporting the standardized mean difference in PSS-I for exposure therapy compared to stress inoculation therapy. The overall analysis favors exposure therapy (1 trial, standardized mean difference −0.14, 95% CI −0.69 to 0.41).

Figure F-31 PTSD symptom reduction for exposure therapy compared with stress inoculation therapy, by instrument: sensitivity analysis including studies with high risk of bias

Note: Foa et al., 1991 was rated as having a high risk of bias.

Timing of outcome assessment: 9 weeks for both studies

Figure F-31 is titled “PTSD symptom reduction for exposure therapy compared with stress inoculation therapy, by instrument: Sensitivity analysis studies with high risk of bias.” This figure displays a forest plot reporting the standardized mean difference in PTSD symptom scores, as measured by the PSS-I and other instruments, for exposure therapy compared to stress inoculation therapy. The plot depicts greater PTSD symptom reduction for patients treated with exposure therapy compared to stress inoculation therapy, as measured by the PSS-I (1 trial, standardized mean difference −0.14, 95% CI −0.69 to 0.41). Conversely, the plot depicts a greater reduction in PTSD symptoms for patients treated with stress inoculation therapy than exposure therapy, as measured by other instruments (1 trial, standardized mean difference 0.40, 95% CI −0.42 to 1.22). The overall analysis favors stress inoculation therapy (standardized mean difference 0.04, 95% CI −0.46 to 0.54, I2 = 13.1%).

Figure F-32 Loss of PTSD diagnosis for exposure therapy compared with stress inoculation therapy

Figure-F-32 is titled “Loss of PTSD diagnosis for exposure therapy compared with stress inoculation therapy, by instrument.” This figure displays a forest plot reporting the risk difference of loss of PTSD diagnosis for exposure therapy compared to stress inoculation. The plot depicts that 18% more patients treated with exposure therapy than stress inoculation therapy achieved loss of PTSD diagnosis (1 trial, risk difference 0.18, 95% CI −0.09 to 0.45, I2 =100.0%).

Figure F-33 Loss of PTSD diagnosis for exposure therapy compared with stress inoculation therapy: sensitivity analysis including studies with high risk of bias

Note: Foa et al., 1991 was rated as having a high risk of bias.

Figure F-33 is titled “Loss of PTSD diagnosis for exposure therapy compared with stress inoculation therapy, by instrument: Sensitivity analysis including studies with high risk of bias.” This figure displays a forest plot reporting the risk difference of loss of PTSD diagnosis for exposure compared to stress inoculation therapy when high risk of bias studies are included. The plot depicts that 26% more patients treated with exposure therapy than stress inoculation therapy achieved loss of PTSD diagnosis (2 trials, risk difference 0.26, 95% CI 0.04 to 0.48, I2 = 3.2%).

Figure F-34 Change in BDI for exposure therapy compared with stress inoculation therapy

Timing of outcome assessment: 9 weeks

Figure F-34 is titled “Change in BDI for exposure therapy compared with stress inoculation therapy, by instrument.” This figure displays a forest plot reporting the weighted mean difference in BDI scores, exposure therapy compared to stress inoculation therapy. The forest plot depicted a weighted mean difference of −0.15 (1 trial, 95% CI −5.75 to 5.45, I2 =100.0%).

Figure F-35 Change in BDI for exposure therapy compared with stress inoculation therapy: Sensitivity analysis including studies with high risk of bias

Note: Foa et al., 1991 was rated as having a high risk of bias.

Timing of outcome assessment: 9 weeks for both studies.

Figure F-35 is titled “Change in BDI for exposure therapy compared with stress inoculation therapy, by instrument: Sensitivity analysis including studies with high risk of bias.” This figure displays a forest plot reporting the weighted mean difference in BDI scores, exposure therapy compared to stress inoculation therapy. The forest plot depicts a greater reduction in BDI scores for patients treated with stress inoculation therapy than exposure (2 trials, weighted mean difference 0.79, 95% CI −4.00 to 5.58, I2 = 0.0%).

Figure F-36 Change in CAPS for exposure therapy compared with relaxation therapy

Timing of outcome assessment: 8 weeks (Taylor, 2003), mean 16 weeks (Marks, 1998).

Figure F-36 is titled “Change in CAPS for exposure therapy compared with relaxation therapy.” This figure displays a forest plot reporting the weighted mean difference in CAPS scores, exposure therapy compared to relaxation therapy. The overall analysis favored exposure therapy (2 trials, weighted mean difference −9.72, 95% CI −22.30 to 2.87, I2= 21.3%).

Figure F-37 Loss of PTSD diagnosis for exposure therapy compared with relaxation therapy

Figure F-37 is titled “Loss of PTSD diagnosis for exposure therapy compared with relaxation therapy.” This figure displays a forest plot reporting the risk difference of loss of PTSD diagnosis, exposure therapy compared to relaxation therapy. The plot depicts that 31% more patients treated with exposure therapy than relaxation therapy achieved loss of PTSD diagnosis (2 trials, risk difference 0.31, 95% CI 0.04 to 0.58, I2 = 49.4%).

Figure F-38 Change in BDI for exposure therapy compared with relaxation therapy

Timing of outcome assessment: 8 weeks (Taylor, 2003), mean 16 weeks (Marks, 1998).

Figure F-38 is titled “Change in BDI for exposure therapy compared with relaxation therapy.” This figure displays a forest plot reporting the weighted mean difference in BDI scores, exposure therapy compared to relaxation therapy. The overall analysis favored exposure therapy (2 trials, weighted mean difference −5.49, 95% CI −10.20 to −0.79, I2 = 0.0%).

Figure F-39 Loss of PTSD diagnosis for exposure therapy compared with EMDR

Timing of outcome assessment: 6 months (Taylor, 2003), 4.5 weeks (Rothbaum, 2005).

Figure F-39 is titled “Loss of PTSD diagnosis for exposure therapy compared with EMDR.” This figure displays a forest plot reporting the risk difference of loss of PTSD diagnosis, exposure therapy compared to EMDR. The plot depicts that 14% more patients treated with exposure therapy than EMDR achieved loss of PTSD diagnosis (2 trials, risk difference 0.14, 95% CI −0.01 to 0.29, I2 = 0.0%).

Figure F-40 PTSD symptom reduction for exposure therapy compared with exposure plus cognitive restructuring

Timing of outcome assessment: 8 weeks (Bryant, 2008), mean 16 weeks (Marks, 1998), 12 weeks (Foa, 2005).

Figure F-40 is titled “PTSD symptom reduction for exposure compared with exposure plus cognitive restructuring.” This figure displays a forest plot reporting the standardized mean difference in PTSD symptoms for exposure therapy compared to exposure therapy plus cognitive restructuring, stratified by CAPS and PSS-I scores. The plot depicts greater reductions in CAPS scores for exposure therapy plus cognitive restructuring than exposure therapy (2 trials, standardized mean difference 0.52, 95% CI 0.07 to 0.96, I2 =22.2%). Conversely, the plot depicts greater reduction in PSS-I scores for exposure therapy than exposure therapy plus cognitive restructuring (1 trial, standardized mean difference −0.15, 95% CI −0.47 to 0.17). The overall analysis favors exposure therapy plus cognitive restructuring (standardized mean difference 0.25, 95% CI −0.29 to 0.80, I2 = 75.3%)

Figure F-41 Loss of PTSD diagnosis for exposure therapy compared with exposure plus cognitive restructuring

Timing of outcome assessment: 8 weeks (Bryant, 2008 and Bryant, 2003), mean 16 weeks (Marks, 1998).

Figure F-41 i titled “Loss of PTSD diagnosis for exposure therapy compared with exposure plus cognitive restructuring therapy.” This figure displays a forest plot reporting the risk difference of loss of PTSD diagnosis, exposure therapy compared to exposure therapy plus cognitive restructuring therapy. The overall analysis indicates a small difference between exposure therapy plus cognitive restructuring and exposure therapy (3 trials, risk difference −0.01, 95% CI −0.17 to 0.14, I2 = 0.0%).

Table F-19 Loss of PTSD diagnosis for exposure therapy compared with exposure plus cognitive restructuring: Statistics with one study removed

Study Omitted | Overall Estimate | 95% Confidence Interval
Bryant, 2008 | −0.01 | (−0.27 to 0.25)
Bryant, 2003 | 0.04 | (−0.14 to 0.22)
Marks, 1998 | −0.08 | (−0.27 to 0.11)
Combined | −0.01 | (−0.17 to 0.14)

Figure F-42 Change in BDI for exposure therapy compared with exposure plus cognitive restructuring therapy

Timing of outcome assessment: 8 weeks (Bryant, 2008 and Bryant, 2003), 12 weeks (Foa, 2005), mean 16 weeks (Marks, 1998),

Figure F-42 is titled “Change in BDI for exposure therapy compared with exposure plus cognitive restructuring therapy.” This figure displays a forest plot reporting the weighted mean difference in BDI scores, exposure therapy compared to exposure therapy plus cognitive restructuring therapy. The overall analysis favors exposure therapy plus cognitive restructuring therapy (4 trials, weighted mean difference 2.78, 95% CI −1.68 to 7.25, I2 = 54.4%).

Table F-20 Change in BDI for exposure therapy compared with exposure plus cognitive restructuring: Statistics with one study removed

Study Omitted | Overall Estimate | 95% Confidence Interval
Bryant, 2008 | 1.88 | (−3.33 to 7.10)
Foa, 2005 | 5.33 | (1.29 to 9.37)
Bryant, 2003 | 2.35 | (−3.12 to 7.82)
Marks, 1998 | 2.32 | (−3.24 to 7.88)
Combined | 2.78 | (−1.68 to 7.25)

### CBT-Mixed: Meta-Analysis Results

Figure F-43 Change in CAPS for CBT-mixed compared with control, by comparator

Timing of outcome assessment: 7 weeks (Johnson, 2011), 8 to 12 weeks (Blanchard, 2003), 12 weeks (Cloitre, 2002), 4 weeks (Fecteau, 1999), 12 weeks (Hinton, 2005), 4 to 5.5weeks (Kubany, 2004), 4.5 months (Kubany, 2003), 14 weeks (McDonagh, 2005).

Figure F-43 is titled “Change in CAPS for CBT-mixed compared with control, by comparator.” This figure displays a forest plot reporting the weighted mean difference in CAPS scores stratified by CBT-mixed compared to usual care and CBT-mixed compared to waitlist. The plot depicts a greater reduction in CAPS scores for patients treated with CBT-mixed than usual care (1 trial, weighted mean difference −8.22, 95% CI −19.90 to 3.46) or waitlist (7 trials, weighted mean difference −34.36, 95% CI −45.54 to −23.19, I2 =84.3%). The overall analysis favored CBT-mixed (weighted mean difference −31.10, 95% CI −42.57 to −19.63, I2 = 87.0%).

Table F-21 Change in CAPS for CBT-mixed compared with control, by comparator: Statistics with one study removed

Study Omitted | Overall Estimate | 95% Confidence Interval
Johnson, 2011 | −34.36 | (−45.54 to −23.19)
Blanchard, 2003 | −30.91 | (−43.84 to −17.98)
Cloitre, 2002 | −31.16 | (−44.54 to −17.78)
Fecteau, 1999 | −31.18 | (−44.02 to −18.33)
Hinton, 2005 | −30.91 | (−44.67 to −17.14)
Kubany, 2004 | −30.22 | (−43.60 to −16.85)
Kubany, 2003 | −26.21 | (−35.02 to −17.40)
McDonagh, 2005 | −34.08 | (−45.67 to −22.48)
Combined | −31.10 | (−42.57 to −19.63)

Table F-22 Change in CAPS for CBT-mixed compared with control, by comparator: Statistics with one study removed, by type of comparator

Study Omitted | Overall Estimate | 95% Confidence Interval
Waitlist
Blanchard, 2003 | −34.66 | (−47.54 to −21.79)
Cloitre, 2002 | −35.00 | (−48.36 to −21.64)
Fecteau, 1999 | −34.96 | (−47.70 to −22.22)
Hinton, 2005 | −34.73 | (−48.61 to −20.84)
Kubany, 2004 | −33.92 | (−47.54 to −20.31)
Kubany, 2003 | −29.30 | (−36.96 to −21.63)
McDonagh, 2005 | −38.29 | (−48.14 to −28.44)
Combined | −34.36 | (−45.54 to −23.19)
Usual Care
NA | NA | NA

Figure F-44 Change in CAPS for CBT-mixed compared with control, by comparator: Sensitivity analysis including studies with high risk of bias

Note: Difede et al., 2007, and Beck et al, 2009 were rated as having a high risk of bias.

Timing of outcome assessment: 12 weeks (Difede, 2007), 7 weeks (Johnson, 2011), 14 weeks (Beck, 2009), 8 to 12 weeks (Blanchard, 2003), 12 weeks (Cloitre, 2002), 4 weeks (Fecteau, 1999), 12 weeks (Hinton, 2005), 4 to 5.5 weeks (Kubany, 2004), 4.5 months (Kubany, 2003), 14 weeks (McDonagh, 2005).

Figure F-44 is titled “Change in CAPS for CBT-mixed compared with control, by comparator: Sensitivity analysis including studies with high risk of bias.” This figure displays a forest plot reporting the weighted mean difference in CAPS scores stratified by CBT-mixed compared to usual care and CBT-mixed compared to waitlist. The plot depicts greater reductions in CAPS scores for patients treated with CBT-mixed than usual care (2 trials, weighted mean difference −8.71, 95% CI −17.84 to 0.42, I2 =0.0%) or waitlist (8 trials, weighted mean difference −32.66, 95% CI −42.95 to −22.37, I2 =83.1%). The overall analysis favored CBT-mixed (weighted mean difference −27.98, 95% CI −38.10 to −17.86, I2 =85.6%).

Figure F-45 Change in CAPS at 3 to 6 months for CBT-mixed compared with control

Figure F-45 is titled “Change in CAPS at 3 to 6 months for CBT-mixed compared with control.” This figure displays a forest plot reporting the weighted mean difference in CAPS at 3 to 6 months stratified by CBT-mixed compared to usual care and CBT-mixed compared to waitlist. The plot depicts greater reductions in CAPS scores for patients treated with CBT-mixed than waitlist (1 trial, weighted mean difference −22.00, 95% CI −36.42 to −7.58), and greater reductions in CAPS scores for patients treated with usual care than CBT-mixed (1 trial, weighted mean difference 1.41, 95% CI −9.79 to 12.61). The overall analysis favored CBT-mixed (weighted mean difference −9.84, 95% CI −32.76 to 13.09, I2 = 84.2%).

Figure F-46 PTSD symptom reduction for CBT-mixed compared with control

Timing of outcome assessment: 7 weeks (Johnson, 2011), 8 to 12 weeks (Blanchard, 2003), 12 weeks (Cloitre, 2002), 4 weeks (Fecteau, 1999), 12 weeks (Foa, 2005), 9 weeks (Foa, 1999), 12 weeks (Hinton, 2005), 12 weeks (Hollifield, 2007) 4 to 5.5 weeks (Kubany, 2004), 4.5 months (Kubany, 2003), 4.8 months (Liedl, 2011), 14 weeks (McDonagh, 2005), 8 weeks (Spence, 2011), 5 sessions (van Emmerik, 2008).

Figure F-46 is titled “PTSD symptom reduction for CBT-mixed compared with control.” This figure displays a forest plot reporting the standardized mean difference of PTSD symptom reduction stratified by CBT-mixed compared to usual care and CBT-mixed compared to waitlist. The plot depicts greater reductions in PTSD symptoms for patients treated with CBT-mixed than usual care (1 trial, standardized mean difference −0.33, 95% CI −0.80 to 0.14) or waitlist (13 trials, standardized mean difference −1.16, 95% CI −1.47 to −0.84, I2 = 72.7%). The overall analysis favored CBT-mixed (standardized mean difference −1.09, 95% CI −1.40 to −0.78, I2 =75.3%).

Figure F-47 PTSD symptom reduction for CBT-mixed compared with control: Sensitivity analysis including studies with high risk of bias

Note: Difede et al., 2007, Power et al., 2002, and Beck et al, 2009 were rated as having a high risk of bias.

Timing of outcome assessment: 12 weeks (Difede, 2007), 7 weeks (Johnson, 2011), 14 weeks (Beck, 2009), 8 to 12 weeks (Blanchard, 2003), 12 weeks (Cloitre, 2002), 4 weeks (Fecteau, 1999), 12 weeks (Foa, 2005), 9 weeks (Foa, 1999), 12 weeks (Hinton, 2005), 12 weeks (Hollifield, 2007), 4 to 5.5 weeks (Kubany, 2004), 4.5 months (Kubany, 2003), 4.8 months (Liedl, 2011), 14 weeks (McDonagh, 2005), 10 weeks (Power, 2002), 8 weeks (Spence, 2011), 5 sessions (van Emmerik, 2008)

Figure F-47 is titled “PTSD symptom reduction for CBT-mixed compared with control: Sensitivity analysis including studies with high risk of bias.” This figure displays a forest plot reporting the standardized mean difference in PTSD symptom reduction stratified by CBT-mixed compared to usual care and CBT-mixed compared to waitlist. The plot depicts greater reductions in PTSD symptoms for patients treated with CBT-mixed than usual care (2 trials, standardized mean difference −0.37, 95% CI −0.76 to 0.02, I2 = 0.0%) or waitlist (15 trials, standardized mean difference −1.14, 95% CI −1.41 to −0.87, I2 = 68.2%). The overall analysis favored CBT-mixed (standardized mean difference −1.05, 95% CI −1.31 to −0.79, I2= 71.0%).

Figure F-48 PTSD symptom reduction for CBT-mixed compared with control: Sensitivity analysis including other comparators

Timing of outcome assessment: 7 weeks (Johnson, 2011), 8 to 12 weeks (Blanchard, 2003), 12 weeks (Cloitre, 2002), 4 weeks (Fecteau, 1999), 12 weeks (Foa, 2005), 9 weeks (Foa, 1999), 12 weeks (Hinton, 2005), 12 weeks (Hollifield, 2007), 4 to 5.5 weeks (Kubany, 2004), 4.5 months (Kubany, 2003), 4.8 months (Liedl, 2011), 14 weeks (McDonagh, 2005), 8 weeks (Spence, 2011), 5 sessions (van Emmerik, 2008), 16 weeks (Cottraux, 2008), 8 weeks (Litz, 2007).

Figure F-48 is titled “PTSD symptom reduction for CBT-mixed compared with control: Sensitivity analysis including other comparators.” This figure displays a forest plot reporting the standardized mean difference in PTSD symptom reduction stratified by CBT-mixed compared to usual care, CBT-mixed compared to waitlist, and CBT-mixed compared to supportive counseling. The plot depicts greater reductions in PTSD symptoms for patients treated with CBT-mixed than usual care (1 trial, standardized mean difference −0.33, 95% CI −0.80 to 0.14), waitlist (13 trials, standardized mean difference −1.16, 95% CI −1.47 to −0.84, I2 = 72.7%), or supportive counseling (2 trials, standardized mean difference −0.23, 95% CI −0.62 to 0.15, I2 =0.0%). The overall analysis favored CBT-mixed (standardized mean difference −0.98, 95% CI −1.28 to −0.68, I2= 77.3%).

Figure F-49 PTSD symptom reduction for CBT-mixed compared with control: Sensitivity analysis including other comparators and studies with high risk of bias

Note: Difede et al., 2007, Power et al., 2002, and Beck et al, 2009 were rated as having a high risk of bias.

Timing of outcome assessment: 12 weeks (Difede, 2007), 7 weeks (Johnson, 2011), 14 weeks (Beck, 2009), 8 to 12 weeks (Blanchard, 2003), 12 weeks (Cloitre, 2002), 4 weeks (Fecteau, 1999), 12 weeks (Foa, 2005), 9 weeks (Foa, 1999), 12 weeks (Hinton, 2005), 12 weeks (Hollifield, 2007), 4 to 5.5 weeks (Kubany, 2004), 4.5 months (Kubany, 2003), 4.8 months (Liedl, 2011), 14 weeks (McDonagh, 2005), 10 weeks (Power, 2002), 8 weeks (Spence, 2011), 5 sessions (van Emmerik, 2008), 16 weeks (Cottraux, 2008), 8 weeks (Litz, 2007).

Figure F-49 is titled “PTSD symptom reduction for CBT-mixed compared with control: Sensitivity analysis including other comparators and studies with high risk of bias.” This figure displays a forest plot reporting the standardized mean difference in PTSD symptom reduction stratified by CBT-mixed compared to usual care, CBT-mixed compared to waitlist, and CBT-mixed compared to supportive counseling. The plot depicts greater reductions in PTSD symptoms for patients treated with CBT-mixed than usual care (2 trials, standardized mean difference −0.37, 95% CI −0.76 to 0.02, I2 =0.0%), waitlist (15 trials, standardized mean difference −1.14, 95% CI −1.41 to −0.87, I2 = 68.2%) or supportive counseling (2 trials, standardized mean difference −0.23, 95% CI −0.62 to 0.15, I2 =0.0%). The overall analysis favored CBT-mixed (standardized mean difference −0.96, 95% CI −1.22 to −0.70, I2= 73.7%).

Figure F-50 PTSD symptom reduction at 3 to 6 months for CBT-mixed compared with control, by type of comparator

Figure F-50 is titled “PTSD symptom reduction at 3 to 6 months for CBT-mixed compared with an inactive control.” The figure displays a forest plot reporting the standard mean difference in PTSD symptom reduction stratified by CBT-mixed compared to waitlist, CBT-mixed compared to usual care, and CBT-mixed compared to supportive counseling. The plot depicts greater reductions in PTSD symptoms at 3 to 6 months for patients treated with CBT-mixed than waitlist (2 trials, standardized mean difference −1.02, 95% CI −1.43 to −0.61, I2 = 0.0%) or supportive counseling (1 trial, standardized mean difference −0.68, 95% CI −1.29 to −0.08). Conversely, patients treated with usual care compared to CBT-mixed experienced greater reductions in PTSD symptoms at 3 to 6 months (1 trial, standardized mean difference −0.68, 95% CI −1.29 to −0.08). The overall analysis favored CBT-mixed (standardized mean difference −0.65, 95% CI −1.21 to −0.09, I2= 75.8%).

Figure F-51 Loss of PTSD diagnosis for CBT-mixed compared with control, by type of comparator

Figure F-51 is titled “Loss of PTSD diagnosis for CBT-mixed compared with control, by type of comparator.” The figure displays a forest plot reporting the risk difference of loss of PTSD diagnosis stratified by CBT-mixed compared to waitlist and CBT-mixed compared to supportive counseling. The plot depicts that loss of PTSD diagnosis was achieved by 29% more patients treated with CBT-mixed than waitlist (3 trials, risk difference 0.29, 95% CI −0.01 to 0.60, I2 = 82.5%) and 22% more patients treated by CBT-mixed than supportive counseling (3 trials, risk difference 0.22, 95% CI 0.09 to 0.34, I2 = 0.0%). The overall analysis favored CBT-mixed (risk difference 0.26, 95% CI 0.11 to 0.41, I2= 60.5%).

Table F-23 Loss of PTSD diagnosis for CBT-mixed compared with control, by type of comparator: Statistics with one study removed

Study Omitted | Overall Estimate | 95% Confidence Interval
Waitlist
Hinton, 2005 | 0.18 | (0.09 to 0.28)
Hollifield, 2007 | 0.28 | (0.10 to 0.45)
McDonagh, 2005 | 0.29 | (0.13 to 0.45)
Bryant, 2003 | 0.25 | (0.08 to 0.42)
Cottraux, 2008 | 0.28 | (0.10 to 0.45)
Litz, 2007 | 0.27 | (0.09 to 0.45)
Combined | −1.23 | (−1.60 to −0.87)

Table F-24 Loss of PTSD diagnosis for CBT-mixed compared with control, by type of comparator: Statistics with one study removed, by type of comparator

Study Omitted | Overall Estimate | 95% Confidence Interval
Waitlist
Hinton, 2005 | 0.14 | (−0.02 to 0.29)
Hollifield, 2007 | 0.35 | (−0.14 to 0.84)
McDonagh, 2005 | 0.39 | (−0.03 to 0.80)
Combined | 0.29 | (−0.01 to 0.60)
Supportive Counseling
Bryant, 2003 | 0.19 | (0.05 to 0.34)
Cottraux, 2008 | 0.24 | (0.07 to 0.40)
Litz, 2007 | 0.23 | (0.06 to 0.40)
Combined | 0.22 | (0.09 to 0.34)

Figure F-52 Loss of PTSD diagnosis at 3 to 6 months for CBT-mixed compared with supportive counseling

Figure F-52 is titled “Loss of PTSD diagnosis at 3 to 6 months for CBT-mixed compared with supportive counseling.” The figure displays a forest plot reporting the risk difference of loss of PTSD diagnosis at 3 to 6 months, CBT-mixed compared to supportive counseling. The plot depicts that 24% more patients treated with CBT-mixed than supportive counseling achieved loss of PTSD diagnosis (2 trials, risk difference 0.24, 95% CI 0.04 to 0.43, I2 = 36.0%).Figure-44 is titled “Change in STAI for CBT-mixed compared with control, by type of comparator.” The figure displays a forest plot reporting weighted mean difference of STAI stratified by CBT-mixed compared to waitlist and CBT-mixed compared to supportive counseling. The plot depicts a greater reduction in STAI scores for patients treated with CBT-mixed than waitlist (3 trials, weighted mean difference −12.12, 95% CI −24.11 to −0.12, I2= 88.6%) or supportive counseling (1 trial, weighted mean difference −8.37, 95% CI −16.13 to −0.61). The overall analysis favored CBT-mixed (weighted mean difference −11.21, 95% CI −20.04 to −2.37, I2 =83.5%).

Figure F-53 Change in STAI for CBT-mixed compared with control, by type of comparator

Timing of outcome assessment: 12 weeks (Cloitre, 2002), 9 weeks (Foa, 1999), 14 weeks (McDonagh, 2005), 8 weeks (Bryant, 2003).

Figure F-53 is titled “Change in STAI for CBT-mixed compared with control, by type of comparator.” The figure displays a forest plot reporting weighted mean difference of STAI stratified by CBT-mixed compared to waitlist and CBT-mixed compared to supportive counseling. The plot depicts a greater reduction in STAI scores for patients treated with CBT-mixed than waitlist (3 trials, weighted mean difference −12.12, 95% CI −24.11 to −0.12, I2 = 88.6%) or supportive counseling (1 trial, weighted mean difference −8.37, 95% CI −16.13 to −0.61). The overall analysis favored CBT-mixed (weighted mean difference −11.21, 95% CI −20.04 to −2.37, I2 =83.5%).

Table F-25 Change in STAI for CBT-mixed compared with control, by type of comparator: Statistics with one study removed

Study Omitted | Overall Estimate | 95% Confidence Interval
Cloitre, 2002 | −6.53 | (−10.71 to −2.36)
Foa, 1999 | −11.86 | (−23.54 to −0.17)
McDonagh, 2005 | −13.74 | (−23.72 to −3.74)
Bryant, 2003 | −12.11 | (−24.11 to −0.12)
Combined | −11.20 | (−20.04 to −2.37)

Table F-26 Change in STAI for CBT-mixed compared with control, by type of comparator: Statistics with one study removed, by type of comparator

Study Omitted | Overall Estimate | 95% Confidence Interval
Waitlist
Cloitre, 2002 | −5.79 | (−10.73 to −0.84)
Foa, 1999 | −13.55 | (−31.97 to 4.87)
McDonagh, 2005 | −16.33 | (−29.97 to −2.69)
Combined | −12.11 | (−24.11 to −0.12)
Supportive Counseling
NA | NA | NA

Figure F-54 Change in STAI for CBT-mixed compared with control, by type of comparator: Sensitivity analysis including studies with high risk of bias

Timing of outcome assessment: 14 weeks (Beck, 2009), 12 weeks (Cloitre, 2002), 9 weeks (Foa, 1999), 14 weeks (McDonagh, 2005), 8 weeks (Bryant, 2003).

Figure F-54 is titled “Change in STAI for CBT-mixed compared with control, by type of comparator: Sensitivity analysis including studies with high risk of bias.” The figure displays a forest plot reporting weighted mean difference of STAI stratified by CBT-mixed compared to waitlist and CBT-mixed compared to supportive counseling. The plot depicts a greater reduction in STAI scores for patients treated with CBT-mixed than waitlist (4 trials, weighted mean difference −10.61, 95% CI −20.13 to −1.09, I2 = 84.2%) or supportive counseling (1 trial, weighted mean difference −8.37, 95% CI −16.13 to −0.61). The overall analysis favored CBT-mixed (weighted mean difference −10.20, 95% CI −17.66 to −2.73, I2 =79.4%).

Figure F-55 Change in BDI for CBT-mixed compared with control, by type of comparator

Timing of outcome assessment: 8 to 12 weeks (Blanchard, 2003), 12 weeks (Cloitre, 2002), 4 weeks (Fecteau, 1999), 12 weeks (Foa, 2005), 9 weeks (Foa, 1999), 4.5 months (Kubany, 2003), 14 weeks (McDonagh, 2005), 5 sessions (van Emmerik, 2008), 4 to 5.5 weeks (Kubany, 2004), 7 weeks (Johnson, 2011).

Figure F-55 is titled “Change in BDI for CBT-mixed compared with control, by type of comparator.” The figure displays a forest plot reporting weighted mean difference of BDI stratified by CBT-mixed compared to waitlist and CBT-mixed compared to usual care. The plot depicts greater reductions in BDI scores for patients treated with CBT-mixed than waitlist (9 trials, weighted mean difference −10.40, 95% CI −14.91 to −5.89, I2= 83.4%) or usual care (1 trial, weighted mean difference −10.13, 95% CI −15.05 to −5.21). The overall analysis favored CBT-mixed (weighted mean difference −10.38, 95% CI −14.37 to −6.40, I2 =81.3%).

Figure F-56 Change in BDI for CBT-mixed compared with control, by type of comparator: Sensitivity analysis including studies with high risk of bias

Note: Difede et al., 2007, and Beck et al., 2009 were rated as having high risk of bias.

Timing of outcome assessment: 14 weeks (Beck, 2009), 8 to 12 weeks (Blanchard, 2003), 12 weeks (Cloitre, 2002), 4 weeks (Fecteau, 1999), 12 weeks (Foa, 2005), 9 weeks (Foa, 1999), 4.5 months (Kubany, 2003), 14 weeks (McDonagh, 2005), 5 sessions (van Emmerik, 2008), 4 to 5.5 weeks (Kubany, 2004), 12 weeks (Difede, 2007), 7 weeks (Johnson, 2011).

Figure F-56 is titled “Change in BDI for CBT-mixed compared with control, by type of comparator: Sensitivity analysis including studies with high risk of bias.” The figure displays a forest plot reporting weighted mean difference of BDI stratified by CBT-mixed compared to waitlist and CBT-mixed compared to usual care. The plot depicts greater reductions in BDI scores for patients treated with CBT-mixed than waitlist (10 trials, weighted mean difference −9.97, 95% CI −14.23 to −5.70, I2 = 81.9%) or usual care (2 trials, weighted mean difference −6.85, 95% CI −13.64 to −0.05, I2 = 68.5%). The overall analysis favors CBT-mixed (weighted mean difference −9.42, 95% CI −13.08 to −5.77, I2 = 80.0%).

Figure F-57 Change in BDI for CBT-mixed compared with control, by type of comparator: Sensitivity analysis including other comparators

Timing of outcome assessment: 8 to 12 weeks (Blanchard, 2003), 12 weeks (Cloitre, 2002), 4 weeks (Fecteau, 1999), 12 weeks (Foa, 2005), 9 weeks (Foa, 1999), 4.5 months (Kubany, 2003), 14 weeks (McDonagh, 2005), 5 sessions (van Emmerik, 2008), 4 to 5.5 weeks (Kubany, 2004), 7 weeks (Johnson, 2011), 8 weeks (Bryant, 2003), 8 weeks (Litz).

Figure F-57 is titled “Change in BDI for CBT-mixed compared with control, by type of comparator: Sensitivity analysis including other comparators.” The figure displays a forest plot reporting weighted mean differences of BDI stratified by CBT-mixed compared to waitlist, CBT-mixed compared to usual care, and CBT-mixed compared to supportive counseling. The plot depicts greater reductions in BDI scores for patients treated with CBT-mixed than waitlist (9 trials, weighted mean difference −10.40, 95% CI −14.91 to −5.89, I2 =83.4%), usual care (1 trial, weighted mean difference −10.13, 95% CI −15.05 to −5.21), or supportive counseling (2 trials, weighted mean difference −2.75, 95% CI −9.32 to 3.82, I2 =43.1%). The overall analysis favors CBT-mixed (weighted mean difference −9.23, 95% CI −13.01 to −5.45, I2 = 81.5%).

Figure F-58 Change in BDI for CBT-mixed compared with control, by type of comparator: Sensitivity analysis including other comparators and studies with high risk of bias

Note: Difede et al., 2007, and Beck et al., 2009 were rated as having high risk of bias.

Timing of outcome assessment: 14 weeks (Beck, 2009), 8 to 12 weeks (Blanchard, 2003), 12 weeks (Cloitre, 2002), 4 weeks (Fecteau, 1999), 12 weeks (Foa, 2005), 9 weeks (Foa, 1999), 4.5 months (Kubany, 2003), 14 weeks (McDonagh, 2005), 5 sessions (van Emmerik, 2008), 4 to 5.5 weeks (Kubany, 2004), 12 weeks (Difede, 2007), 7 weeks (Johnson, 2011), 8 weeks (Bryant, 2003), 8 weeks (Litz).

Figure F-58 is titled “Change in BDI for CBT-mixed compared with control, by type of comparator: Sensitivity analysis including other comparators and studies with high risk of bias.” The figure displays a forest plot reporting weighted mean differences of BDI stratified by CBT-mixed compared to waitlist, CBT-mixed compared to usual care, and CBT-mixed compared to supportive counseling. The plot depicts greater reductions in BDI scores for patients treated with CBT-mixed than waitlist (10 trials, weighted mean difference −9.97, 95% CI −14.23 to − 5.70, I2 = 81.9%), usual care (2 trials, weighted mean difference −6.85, 95% CI −13.64 to − 0.05, I2 = 68.5%), or supportive counseling (2 trials weighted mean difference −2.75, 95% CI −9.32 to 3.82, I2 = 43.1%). The overall analysis favors CBT-mixed (weighted mean difference −8.55, 95% CI −12.02 to −5.09, I2 = 79.9%).

Figure F-59 Change in BDI at 3 to 6 months for CBT-mixed compared with control, by type of comparator

Figure F-59 is titled “Change in BDI at 3 to 6 months for CBT-mixed compared with control, by type of comparator.” The figure displays a forest plot reporting the weighted mean difference of BDI stratified by CBT-mixed compared to waitlist and CBT-mixed compared to usual care. The plot depicts greater reductions in BDI scores at 3 to 6 months for patients treated with CBT-mixed than waitlist (1 trial, weighted mean difference −3.30, 95% CI −10.14 to 3.54) or usual care (1 trial, weighted mean difference −6.97, 95% CI −11.84 to −2.10). The overall analysis favored CBT-mixed (weighted mean difference −5.74 95% CI −9.70 to −1.77, I2 =0.0%).

Figure F-60 Change in BDI at 3 to 6 months for CBT-mixed compared with control, by type of comparator: Sensitivity analysis including other comparators

Figure F-60 is titled “Change in BDI at 3 to 6 months for CBT-mixed compared with control, by type of comparator: Sensitivity analysis including other comparators.” The figure displays a forest plot reporting weighted mean differences of BDI scores stratified by CBT-mixed compared to waitlist, CBT-mixed compared to usual care, and CBT-mixed compared to supportive counseling. The plot depicts greater reductions in BDI scores for patients treated with CBT-mixed than waitlist (1 trial, weighted mean difference −3.30, 95% CI −10.14 to 3.54), usual care (1 trial, weighted mean difference −6.97, 95% CI −11.84 to −2.10), or supportive counseling (2 trials, weighted mean difference −4.30, 95% CI −8.91 to 0.32, I2 0.0%). The overall analysis favors CBT-mixed (weighted mean difference −5.12, 95% CI −8.13 to −2.12, I2 = 0.0%).

Figure F-61 PTSD symptom reduction for CBT-mixed compared with exposure

Timing of outcome assessment: 8 weeks (Bryant, 2008), mean 16 weeks (Marks, 1998), 12 weeks (9 to 12 weekly sessions; Foa, 2005), 9 weeks (Foa, 1999).

Figure F-61 is titled “PTSD symptom reduction for CBT-mixed compared with exposure.” The figure displays a forest plot reporting standardized mean differences of PTSD symptom reduction, as measured by CAPS or PSS-I scores, for CBT-mixed compared to exposure therapy. The plot depicts greater reductions in CAPS scores for patients treated with CBT-mixed than exposure therapy (2 trials, standardized mean difference −0.52, 95% CI −0.96 to −0.07, I2 =22.2%). The plot also depicts greater reductions in PSS-I scores for patients treated with exposure therapy than CBT-mixed (2 trials, standardized mean difference 0.15, 95% CI −0.12 to 0.42, I2 = 66.5%). The overall analysis favors CBT-mixed (weighted mean difference −0.15, 95% CI −0.56 to 0.26, I2 = 66.5%).

Figure F-62 PTSD symptom reduction for CBT-mixed compared with exposure: Sensitivity analysis including studies with high risk of bias

Note: Beidel et al., 2011 was rated as having high risk of bias.

Timing of outcome assessment: 17 weeks (Biedel, 2011), 8 weeks (Bryant, 2008), mean 16 weeks (Marks, 1998), 12 weeks (9 to 12 weekly sessions; Foa, 2005), 9 weeks (Foa, 1999).

Figure F-62 is titled “PTSD symptom reduction for CBT-mixed compared with exposure: Sensitivity analysis including studies with high risk of bias.” The figure displays a forest plot reporting standardized mean differences of PTSD symptom reduction, as measured by CAPS or PSS-I scores, for CBT-mixed compared to exposure therapy. The plot depicts greater reductions in CAPS scores for patients treated with CBT-mixed than exposure therapy (3 trials, standardized mean difference −0.20, 95% CI −0.86 to 0.46, I2 =73.4%). The plot also depicts greater reductions in PSS-I scores for patients treated with exposure therapy than CBT-mixed (2 trials, standardized mean difference 0.15, 95% CI −0.12 to 0.42, I2 = 0.0%). The overall analysis favored CBT-mixed (standardized mean difference −0.05, 95% CI −0.43 to 0.33, I2 =64.3%).

Figure F-63 Change in BDI for CBT-mixed compared with exposure

Timing of outcome assessment: 8 weeks (Bryant, 2008), 12 weeks (9 to 12 weekly sessions; Foa, 2005), 8 weeks (Bryant, 2003) 9 weeks (Foa, 1999), mean 16 weeks (Marks, 1998).

Figure F-63 is titled “Change in BDI for CBT-mixed compared with exposure.” The figure displays a forest plot reporting weighted mean differences of BDI scores for CBT-mixed compared to exposure therapy. The overall analysis favors CBT-mixed (5 trials, weighted mean difference −1.77, 95% CI −5.25 to 1.71, I2 =44.6%).

Table F-27 Change in BDI for CBT-mixed compared with exposure: Statistics with one study removed

Study Omitted | Overall Estimate | 95% Confidence Interval
Bryant, 2008 | −0.75 | (−4.28 to 2.78)
Foa, 2005 | −3.13 | (−6.60 to 0.34)
Bryant, 2003 | −1.26 | (−5.11 to 2.60)
Foa, 1999 | −2.78 | (−7.25 to 1.68)
Marks, 1998 | −1.19 | (−5.05 to 2.67)
Combined | −1.77 | (−5.25 to 1.71)

Figure F-64 Change in STAI for CBT-mixed compared with exposure

Timing of outcome assessment: 8 weeks (Bryant, 2008 and Bryant 2003), 8 weeks (Bryant, 2003) 9 weeks (Foa, 1999).

Figure F-64 is titled “Change in STAI for CBT-mixed compared with exposure.” The figure displays a forest plot reporting weighted mean differences of STAI scores for CBT-mixed compared to exposure therapy. The overall analysis favors exposure therapy (3 trials, weighted mean difference 2.76, 95% CI −1.98 to 7.49, I2 =11.0%).

Table F-28 Change in STAI for CBT-mixed compared with exposure: Statistics with one study removed

Study Omitted | Overall Estimate | 95% Confidence Interval
Bryant, 2008 | 4.07 | (−2.65 to 10.79)
Bryant, 2003 | 3.77 | (−3.51 to 11.05)
Foa, 1999 | 0.26 | (−5.28 to 5.81)
Combined | 2.76 | (−1.98 to 7.49)

Figure F-65 Loss of PTSD diagnosis for CBT-mixed compared with exposure

Timing of outcome assessment: 8 weeks (Bryant, 2008), 8 weeks (Bryant, 2003), mean 16 weeks (Marks, 1998), 9 weeks (Foa, 1999).

Figure F-65 is titled “Loss of PTSD Diagnosis for CBT-mixed compared with exposure.” The figure displays a forest plot reporting the risk difference of loss of PTSD diagnosis for CBT-mixed compared to exposure therapy. The plot depicts that loss of PTSD diagnosis was achieved by 4% more patients treated with exposure therapy than CBT-mixed (risk difference −0.04, 95% CI −0.19 to 0.10, I2 = 16.1%).

Table F-29 Loss of PTSD diagnosis for CBT-mixed compared with exposure: Statistics with one study removed

Study Omitted | Overall Estimate | 95% Confidence Interval
Bryant, 2008 | −0.68 | (−0.26 to 0.13)
Bryant, 2003 | −0.09 | (−0.24 to 0.06)
Marks, 1998 | −0.02 | (−0.21 to 0.18)
Foa, 1999 | 0.01 | (−0.14 to 0.17)
Combined | −0.04 | (−0.19 to 0.10)

### EMDR: Meta-Analysis Results

Figure F-66 PTSD symptom reduction for EMDR compared with control, by type of comparator

Timing of outcome assessment: 2 months (Hogberg, 2007), 4.5 weeks (Rothbaum, 2005), 4 weeks (Rothbaum, 1997), 6 weeks (Carlson, 1998).

Figure F-66 is titled “PTSD symptom reduction for EMDR compared with control, by type of comparator.” The figure displays a forest plot reporting the standardized mean difference of PTSD symptom reduction stratified by EMDR compared to waitlist and EMDR compared to usual care. The plot depicts greater reductions in PTSD symptoms for patients treated with EMDR than waitlist (3 trials, standardized mean difference −1.37, 95% CI −2.05 to −0.69, I2 = 51.3%) or usual care (1 trial, standardized mean difference −0.19, 95% CI −1.03 to 0.65). The overall analysis favored EMDR (standardized mean difference −1.08, 95% CI −1.83 to −0.33, I2 70.0%).

Table F-30 PTSD symptom reduction for EMDR compared with control, by type of comparator: Statistics with one study removed

Study Omitted | Overall Estimate | 95% Confidence Interval
Hogberg, 2007 | −1.21 | (−2.21 to −0.22)
Rothbaum, 2005 | −0.87 | (−1.78 to 0.04)
Rothbaum, 1997 | −0.86 | (−1.72 to −0.00)
Carlson, 1998 | −1.37 | (−2.05 to −0.69)
Combined | −1.08 | (−1.83 to −0.33)

Table F-31 PTSD symptom reduction for EMDR compared with control, by type of comparator: Statistics with one study removed, by type of comparator

Study Omitted | Overall Estimate | 95% Confidence Interval
Waitlist
Hogberg, 2007 | −1.68 | (−2.23 to −1.13)
Rothbaum, 2005 | −1.23 | (−2.40 to −0.06)
Rothbaum, 1997 | −1.18 | (−2.09 to −0.28)
Combined | −1.37 | (−2.05 to −0.69)
Usual Care
NA | NA | NA

Figure F-67 PTSD symptom reduction for EMDR compared with control, by type of comparator: Sensitivity analysis including placebo

Timing of outcome assessment: 8 weeks (van der Kolk, 2007), 2 months (Hogberg, 2007), 4.5 weeks (Rothbaum, 2005), 4 weeks (Rothbaum, 1997), 6 weeks (Carlson, 1998).

Figure F-67 is titled “PTSD symptom reduction for EMDR compared with control, by type of comparator: Sensitivity analysis including placebo.” The figure displays a forest plot reporting standardized mean difference of PTSD symptom reduction stratified by EMDR compared to placebo, EMDR compared to waitlist, and EMDR compared to usual care. The plot depicts greater reductions in PTSD symptoms for patients treated with EMDR than placebo (1 trial, standardized mean difference −0.42, 95% CI −0.94 to 0.10), waitlist (3 trials, standardized mean difference −1.37, 95% CI −2.05 to −0.69, I2= 51.3%) or usual care (1 trial, standardized mean difference −0.19, 95% CI −1.03 to 0.65). The overall analysis favored EMDR (standardized mean difference −0.92, 95% CI −1.55 to −0.29, I2= 71.8%).

Figure F-68 PTSD symptom reduction for EMDR compared with control, by type of comparator: Sensitivity analysis including high risk of bias studies

Note: Johnson et al., 2006, Power et al., 2002, and Marcus et al., 1997 were rated as having high risk of bias.

Timing of outcome assessment: 8 weeks (van der Kolk, 2007), 2 months (Hogberg, 2007), mean number of weekly sessions = 6.33 (Johnson, 2006), 10 weeks (Power, 2002), 4.5 weeks (Rothbaum, 2005), 4 weeks (Rothbaum, 1997), 6 weeks (Carlson, 1998), variable number of sessions (Marcus, 1997).

Figure F-68 is titled “PTSD symptom reduction for EMDR compared with control, by type of comparator: Sensitivity analysis including high risk of bias studies.” The figure displays a forest plot reporting standardized mean difference of PTSD symptom reduction stratified by EMDR compared to placebo, EMDR compared to waitlist, and EMDR compared to usual care. The plot depicts greater reductions in PTSD symptoms for patients enrolled in EMDR than placebo (1 trial, standardized mean difference −0.42, 95% CI −0.94 to −0.10), waitlist (5 trials, standardized mean difference −1.55, 95% CI −2.04 to −1.07, I2 = 54.3%) or usual care (2 trials, standardized mean difference −0.61, 95% CI −1.22 to 0.00, I2= 40.6%). The overall analysis favored EMDR (standardized mean difference −1.13, 95% CI −1.62 to −0.64, I2 76.6%).

Figure F-69 Loss of PTSD diagnosis for EMDR compared with waitlist

Figure F-69 is titled “Loss of PTSD diagnosis for EMDR compared with waitlist.” The figure displays a forest plot reporting the risk difference of loss of PTSD diagnosis for EMDR compared to waitlist. The plot depicts that 64% more patients treated with EMDR than waitlist achieved loss of PTSD diagnosis (3 trials, risk difference 0.64, 95% CI 0.64 to 0.81, I2= 27.0%).

Table F-32 Loss of PTSD diagnosis for EMDR compared with waitlist: Statistics with one study removed

Study Omitted | Overall Estimate | 95% Confidence Interval
Waitlist
Hogberg, 2007 | 0.68 | (0.43 to 0.92)
Rothbaum, 2005 | 0.68 | (0.41 to 0.96)
Rothbaum, 1997 | 0.55 | (0.36 to 0.73)
Combined | 0.64 | (0.46 to 0.81)

Figure F-70 Loss of PTSD diagnosis for EMDR compared with control, by type of comparator: Sensitivity analysis including placebo

Figure F-70 is titled “Loss of PTSD diagnosis for EMDR compared with control, by type of comparator: Sensitivity analysis including placebo.” The figure displays a forest plot reporting the risk difference of loss of PTSD diagnosis stratified by EMDR compared to waitlist and EMDR compared to placebo. The plot depicts loss of PTSD diagnosis is achieved by 64% more patients treated with EMDR than waitlist (3 trials, risk difference 0.64, 95% CI 0.46 to 0.81, I2= 27.0%) and 17% more patients treated with EMDR than placebo (1 trial, risk difference 0.17, 95% CI −0.07 to 0.41). The overall analysis favored EMDR (risk difference 0.51, 95% CI 0.24 to 0.78, I2 = 77.5%).

Figure F-71 Loss of PTSD diagnosis for EMDR compared with control, by type of comparator: Sensitivity analysis including high risk of bias studies

Note: Marcus et al, 1997 was rated as having high risk of bias.

Timing of outcome assessment: 2 months (Hogberg, 2007), 4.5 weeks (Rothbaum, 2005), 4 weeks (Rothbaum, 1997), 8 weeks (van der Kolk, 2007), variable number of sessions (Marcus, 1997).

Figure F-71 is titled “Loss of PTSD diagnosis for EMDR compared with control, by type of comparator: Sensitivity analysis including high risk of bias studies.” The figure displays a forest plot reporting the risk difference of loss of PTSD diagnosis stratified by EMDR compared to waitlist, EMDR compared to placebo, and EMDR compared to usual care. The plot depicts loss of PTSD diagnosis was achieved by 64% more patients treated with EMDR than waitlist (3 trials, risk difference 0.64, 95% CI 0.46 to 0.81, I2= 27.0%), 17% more patients treated with EMDR than placebo (1 trial, risk difference 0.17, 95% CI −0.07 to 0.41), and 28% more patients treated with EMDR than usual care (1 trial, risk difference 0.28, 95% CI 0.06 to 0.50). The overall analysis favored EMDR (risk difference 0.46, 95% CI 0.24 to 0.69, I2= 75.7%).

Figure F-72 Depression symptom reduction for EMDR compared with inactive control

Timing of outcome assessment: 2 months (Hogberg, 2007), 4.5 weeks (Rothbaum, 2005), 4 weeks (Rothbaum, 1997), 6 weeks (Carlson, 1998).

Figure F-72 is titled “Depression symptom reduction for EMDR compared with inactive control.” The figure displays a forest plot reporting the standardized mean difference in depression symptoms stratified by EMDR versus waitlist and EMDR versus usual care. The plot depicts greater reductions in depression symptom scores for patients treated with EMDR than waitlist (3 trials, standardized mean difference −1.09, 95% CI −1.53 to −0.66, I2=0.0%) or usual care (1 trial, standardized mean difference −1.30, 95% CI −2.23 to −0.37). The overall analysis favored EMDR (standardized mean difference −1.13, 95% CI −1.52 to −0.74, I2=0.0%).

Table F-33 Depression symptom reduction for EMDR compared with control, by type of comparator: Statistics with one study removed

Study Omitted | Overall Estimate | 95% Confidence Interval
Hogberg, 2007 | −1.18 | (−1.63 to −0.74)
Rothbaum, 2005 | −1.01 | (−1.52 to −0.49)
Rothbaum, 1997 | −1.09 | (−1.53 to −0.66)
Carlson, 1998 | −1.21 | (−1.64 to −0.77)
Combined | −1.13 | (−1.52 to −0.74)

Table F-34 Depression symptom reduction for EMDR compared with control, by type of comparator: Statistics with one study removed, by type of comparator

Study Omitted | Overall Estimate | 95% Confidence Interval
Waitlist
Hogberg, 2007 | −1.15 | (−1.66 to −0.64)
Rothbaum, 2005 | −0.88 | (−1.50 to −0.26)
Rothbaum, 1997 | −1.18 | (−1.68 to −0.68)
Combined | −1.09 | (−1.53 to −0.66)
Usual Care
NA | NA | NA

Figure F-73 Depression symptom reduction for EMDR compared with inactive control: Sensitivity analysis including placebo

Timing of outcome assessment: 8 weeks (van der Kolk, 2007), 2 months (Hogberg, 2007), 4.5 weeks (Rothbaum, 2005), 4 weeks (Rothbaum, 1997), 6 weeks (Carlson, 1998).

Figure F-73 is titled “Depression symptom reduction for EMDR compared with inactive control: Sensitivity analysis including placebo.” The figure displays a forest plot reporting the standardized mean difference in depression symptom scores stratified by EMDR versus placebo, EMDR versus waitlist, and EMDR versus usual care. The plot depicts greater reductions in depression symptom scores for patients treated with EMDR than placebo (1 trial, standardized mean difference −0.09, 95% CI −0.60 to 0.43), waitlist (3 trials, standardized mean difference −1.09, 95% CI −1.53 to −0.66, I2=0.0%), or usual care (1 trial, standardized mean difference −1.30, 95% CI −2.23 to −0.37). The overall analysis favored EMDR (standardized mean difference −0.85, 95% CI −1.39 to −0.30, I2=63.9%).

Figure F-74 Depression symptom reduction for EMDR compared with inactive control: Sensitivity analysis including studies with high risk of bias

Note: Marcus et al., 1997, and Power et al., 2002 were rated as having high risk of bias.

Timing of outcome assessment: 8 weeks (van der Kolk, 2007), 2 months (Hogberg, 2007), 10 weeks (Power, 2002), 4.5 weeks (Rothbaum, 2005), 4 weeks (Rothbaum, 1997), 6 weeks (Carlson, 1998), variable number of sessions (Marcus, 1997).

Figure F-74 is titled “Depression symptom reduction for EMDR compared with inactive control: Sensitivity analysis including studies with high risk of bias.” The figure displays a forest plot reporting the standardized mean difference in depression symptom scores stratified by EMDR versus placebo, EMDR versus waitlist, and EMDR versus usual care. The plot depicts greater reductions in depression symptom scores for patients treated with EMDR than placebo (1 trial, standardized mean difference −0.09, 95% CI −0.60 to 0.43), waitlist (4 trials, standardized mean difference −1.27, 95% CI −1.61 to −0.93, I2=0.0%), or usual care (2 trials, standardized mean difference −0.72, 95% CI −1.69 to 0.25, I2=71.6%). The overall analysis favored EMDR (standardized mean difference −0.87, 95% CI −1.34 to −0.39, I2=73.2%).

Figure F-75 Change in BDI for EMDR compared with an inactive control, by type of comparator

Timing of outcome assessment: 4.5 weeks (Rothbaum, 2005), 4 weeks (Rothbaum, 1997), 6 weeks (Carlson, 1998).

Figure F-75 is titled “Change in BDI for EMDR compared with an inactive control, by type of comparator.” The figure displays a forest plot reporting the standardized mean difference in BDI scores stratified by EMDR versus waitlist and EMDR versus usual care. The plot depicts greater reductions in BDI scores for patients treated with EMDR than waitlist (2 trials, standardized mean difference −1.15, 95% CI −1.66 to −0.64, I2=0.0%) or usual care (1 trial, standardized mean difference −1.30, 95% CI −2.23 to −0.37). The overall analysis favored EMDR (standardized mean difference −1.18, 95% CI −1.63 to −0.74, I2=0.0%).

Figure F-76 Change in BDI for EMDR compared with an inactive control: Sensitivity analysis including placebo

Timing of outcome assessment: 8 weeks (van der Kolk, 2007), 4.5 weeks (Rothbaum, 2005), 4 weeks (Rothbaum, 1997), 6 weeks (Carlson, 1998).

Figure F-76 is titled “Change in BDI for EMDR compared with an inactive control: Sensitivity analysis including placebo.” The figure displays a forest plot reporting the standardized mean difference in BDI scores stratified by EMDR versus placebo, EMDR versus waitlist, and EMDR versus usual care. The plot depicts greater reductions in BDI scores for patients treated with EMDR than placebo (1 trial, standardized mean difference −0.09, 95% CI −0.60 to 0.43), waitlist (2 trials, standardized mean difference −1.15, 95% CI −1.66 to −0.64, I2=0.0%), or usual care (1 trial, standardized mean difference −1.30, 95% CI −2.23 to −0.37). The overall analysis favored EMDR (standardized mean difference −0.84, 95% CI −1.52 to −0.16, I2=72.4%).

Figure F-77 Change in BDI for EMDR compared with an inactive control: Sensitivity analysis including studies with high risk of bias

Note: Marcus et al, 1997 was rated as having high risk of bias.

Timing of outcome assessment: 8 weeks (van der Kolk, 2007), 4.5 weeks (Rothbaum, 2005), 4 weeks (Rothbaum, 1997), 6 weeks (Carlson, 1998), variable number of sessions (Marcus, 1997).

Figure F-77 is titled “Change in BDI for EMDR compared with an inactive control: Sensitivity analysis including high studies with risk of bias.” The figure displays a forest plot reporting the standardized mean difference in BDI scores stratified by EMDR versus placebo, EMDR versus waitlist, and EMDR versus usual care. The plot depicts greater reductions in BDI scores for patients treated with EMDR than placebo (1 trial, standardized mean difference −0.09, 95% CI −0.60 to 0.43), waitlist (2 trials, standardized mean difference −1.15, 95% CI −1.66 to −0.64, I2=0.0%), or usual care (2 trials, standardized mean difference −0.72, 95% CI −1.69 to 0.25, I2=71.6%). The overall analysis favored EMDR (standardized mean difference −0.70, 95% CI −1.22 to −0.18, I2=68.8%).

Figure F-78 Change in STAI for EMDR compared with an inactive control, by type of comparator

Timing of outcome assessment: 4.5 weeks (Rothbaum, 2005), 4 weeks (Rothbaum, 1997), 6 weeks (Carlson, 1998).

Figure F-78 is titled “Change in STAI for EMDR compared with an inactive control, by type of comparator.” The figure displays a forest plot reporting the weighted mean difference in STAI scores stratified by EMDR versus waitlist and EMDR versus usual care. The plot depicts greater reductions in STAI scores for patients treated with EMDR than waitlist (2 trials, weighted mean difference −13.60, 95% CI −30.03 to 2.83, I2=77.7%) or usual care (1 trial, weighted mean difference −5.50, 95% CI −15.96 to 4.96). The overall analysis favored EMDR (weighted mean difference −11.08, 95% CI −23.06 to 0.90, I2=75.7%).

Figure F-79 PTSD symptom reduction for EMDR compared with relaxation

Note: This analysis uses the IES instrument data from Carlson et al., 1998.

Timing of outcome assessment: 8 weeks (Taylor, 2003), 6 weeks (Carlson, 1998).

Figure F-79 is titled “PTSD symptom reduction for EMDR compared with relaxation.” The figure displays a forest plot reporting the standardized mean difference in PTSD symptoms stratified by CAPS scores and IES scores. The plot depicts greater reductions in PTSD symptom scores for patients treated with EMDR than relaxation as measured by CAPS scores (1 trial, standardized mean difference −0.18, 95% CI −0.82 to 0.45) and IES scores (1 trial, standardized mean difference −0.53, 95% CI −1.36 to 0.31). The overall analysis favored EMDR (standardized mean difference −0.31, 95% CI −0.82 to 0.20, I2=0.0%).

Figure F-80 PTSD symptom reduction for EMDR compared with relaxation

Note: This analysis uses the MISS instrument data from Carlson et al., 1998.

Timing of outcome assessment: 8 weeks (Taylor, 2003), 6 weeks (Carlson, 1998).

Figure F-80 is titled “PTSD symptom reduction for EMDR compared with relaxation.” The figure displays a forest plot reporting the standardized mean difference in PTSD symptoms stratified by CAPS scores and MISS scores. The plot depicts greater reductions in PTSD symptom scores for patients treated with EMDR than relaxation as measured by CAPS scores (1 trial, standardized mean difference −0.18, 95% CI −0.82 to 0.45) and MISS scores (1 trial, standardized mean difference −1.08, 95% CI −1.96 to −0.19). The overall analysis favored EMDR (standardized mean difference −0.57, 95% CI −1.44 to 0.29, I2=61.1%).

Figure F-81 Loss of PTSD diagnosis at 3 month follow-up for EMDR compared with relaxation

Figure F-81 is titled “Loss of PTSD diagnosis at 3 month follow-up for EMDR compared with relaxation.” The figure displays a forest plot reporting the risk difference of PTSD diagnosis for EMDR versus relaxation. The plot depicts that 34% more patients treated with EMDR achieved loss of PTSD diagnosis at 3 month follow-up than relaxation (2 trials, risk difference 0.34, 95% CI −0.04 to 0.72, I2=62.6%).

### Other Psychological Interventions: Meta-Analysis Results

Figure F-82 Change in CAPS for seeking safety therapy compared with an active control

Timing of outcome assessment: 12 weeks (Hien, 2004), 6 to 8 weeks (Zlotnik, 2009), 6 weeks (Hien, 2009).

Figure F-82 is titled “Change in CAPS for seeking safety therapy compared with an active control.” The figure displays a forest plot reporting the weighted mean difference in CAPS scores for seeking safety therapy versus an active control. The plot depicts greater reductions in CAPS scores for patients treated with an active control than seeking safety therapy (3 trials, weighted mean difference 1.45, 95% CI −2.50 to 5.40, I2 = 0.0%).

Table F-35 Change in CAPS for seeking safety therapy compared with an active control: Statistics with one study removed

Study Omitted | Overall Estimate | 95% Confidence Interval
Hein, 2004 | 0.94 | (−3.37 to 5.25)
Zlotnik, 2009 | 2.04 | (−2.07 to 6.15)
Hein, 2009 | 0.68 | (−8.47 to 9.83)
Combined | 1.45 | (−2.50 to 5.40)

Figure F-83 PTSD symptom reduction for seeking safety therapy compared with control, by type of comparator

Timing of outcome assessment: 12 weeks (Hien, 2004), 6 to 8 weeks (Zlotnik, 2009), 6 weeks (Hien, 2009), 12 weeks (Boden, 2012).

Figure F-83 is titled “PTSD symptom reduction for seeking safety therapy compared with control, by type of comparator.” The figure displays a forest plot reporting the standardized mean difference in PTSD symptom scores stratified by seeking safety therapy versus RPC, seeking safety therapy versus psychoeducation, and seeking safety therapy versus usual care. The plot depicts greater reductions in PTSD symptom scores for patients treated with RPC than seeking safety therapy (2 trials, standardized mean difference 0.02, 95% CI −0.37 to 0.42, I2=18.1%) and patients treated with psychoeducation than seeking safety therapy (1 trial, standardized mean difference 0.07, 95% CI −0.13 to 0.28). On the other hand, the plot also depicts greater reductions in PTSD symptom scores for patients treated with seeking safety therapy than usual care (1 trial, standardized mean difference −0.04, 95% CI −0.40 to 0.33). The overall analysis favored control (standardized mean difference 0.04, 95% CI −0.12 to 0.20, I2=0.0%).

Figure F-84 Change in PDS for narrative exposure therapy compared with an inactive control

Timing of outcome assessment: 5 to 17 sessions (Neuner, 2010), 3 weeks (Neuner, 2008), 3 to 4 weeks (Neuner, 2004).

Figure F-84 is titled “Change in PDS for narrative exposure therapy compared with an inactive control.” The figure displays a forest plot reporting the weighted mean difference of PDS scores for narrative exposure therapy versus an inactive control. The plot depicts greater reductions in PDS scores for patients treated with narrative exposure therapy than an inactive control (3 trials, weighted mean difference −10.20, 95% CI −13.05 to −7.35, I2=19.0%).

Table F-36 Change in PDS for narrative exposure therapy compared with an inactive control: Statistics with one study removed

Study Omitted | Overall Estimate | 95% Confidence Interval
Neuner, 2010 | −10.66 | (−15.48 to −5.83)
Neuner, 2008 | −11.87 | (−15.63 to −8.11)
Neuner, 2004 | −9.02 | (−11.83 to −6.20)
Combined | −10.20 | (−13.05 to −7.35)

Figure F-85 Loss of PTSD diagnosis for narrative exposure therapy compared with an inactive control

Figure F-85 is titled “Loss of PTSD diagnosis for narrative exposure therapy compared with an inactive control.” The figure displays a forest plot reporting the risk difference of PTSD diagnosis for narrative exposure therapy versus an inactive control. The plot depicts that 15% more patients treated with narrative exposure therapy achieved loss of PTSD diagnosis than an inactive control (3 trials, risk difference 0.15, 95% CI 0.01 to 0.30, I2=48.1%).

Table F-37 Loss of PTSD diagnosis for narrative exposure therapy compared with an inactive control: Statistics with one study removed

Study Omitted | Overall Estimate | 95% Confidence Interval
Neuner, 2010 | 0.24 | (−0.03 to 0.51)
Neuner, 2008 | 0.22 | (−0.14 to 0.57)
Neuner, 2004 | 0.11 | (0.02 to 0.21)
Combined | 0.15 | (0.01 to 0.30)

Figure F-86 PTSD symptom reduction (any measure) for psychological treatments compared with waitlist controls only

Abbreviations: CBT = cognitive behavioral therapy; CI = confidence interval; EMDR = eye movement desensitization and reprocessing; N = trial arm sample size; SMD = standardized mean difference (Cohen’s d). A small effect size is d=0.20, medium effect size is d=0.50, and large effect size is d=0.80.^25^

Timing of outcome assessment: 17 weeks (Chard, 2005), 10 weeks (Monson, 2006), 6 weeks (Resick, 2002), 3 months (Ehlers 2005 and Ehlers 2003), 8 weeks (Basoglu, 2007), 12 weeks (Foa, 2005), 9 weeks (Foa, 1999), 4.5 weeks (Rothbaum, 2005), 8 to 12 weeks (Blanchard, 2003), 12 weeks (Cloitre, 2002), 4 weeks (Fecteau, 1999), 12 weeks (Hinton, 2005), 12 weeks (Hollifield, 2007) 4 to 5.5 weeks (Kubany, 2004), 4.5 months (Kubany, 2003), 4.8 months (Liedl, 2011), 14 weeks (McDonagh, 2005), 8 weeks (Spence, 2011), 5 sessions (van Emmerik, 2008), 2 months (Hogberg, 2007), 4 weeks (Rothbaum, 1997).

Figure F-86 is titled “PTSD symptom reduction (any measure) for psychological treatments compared with waitlist controls only.” The figure displays a forest plot reporting the standardized mean difference of PTSD symptom reduction scores stratified by cognitive processing therapy compared to waitlist, CBT-exposure compared to waitlist, CBT-mixed compared to waitlist, and EMDR compared to waitlist. The plot depicts greater reductions in PTSD symptoms for patients treated with the psychological treatments of cognitive processing therapy (3 trials, standardized mean difference −1.56, 95% CI −2.24 to −0.87, I2= 80.9%), CBT-exposure (5 trials, standardized mean difference −1.16, 95% CI −1.40 to −0.91, I2= 0.0%), CBT-mixed (14 trials, standardized mean difference −1.24, 95% CI −1.56 to −0.91, I2= 75.3%), and EMDR (3 trials, standardized mean difference −1.37, 95% CI −2.05 to −0.69, I2= 51.3%) compared to waitlist.

Figure F-87 PTSD symptom reduction (any measure) for psychological treatments compared with control: including waitlist and usual care

Timing of outcome assessment: 17 weeks (Chard, 2005), 12 weeks (Forbes, 2012), 10 weeks (Monson, 2006), 6 weeks (Resick, 2002), 3 months (Ehlers 2005, Ehlers 2003, and Mueser 2008), 8 weeks (Basoglu, 2007), 12 weeks (Foa, 2005), 9 weeks (Foa, 1999), 4.5 weeks (Rothbaum, 2005), 8 to 15 weekly sessions (Asukai, 2010), 9 to 15 weeks (Nacasch, 2011), 7 weeks (Johnson, 2011), 8 to 12 weeks (Blanchard, 2003), 12 weeks (Cloitre, 2002), 4 weeks (Fecteau, 1999), 12 weeks (Foa, 2005), 9 weeks (Foa, 1999), 12 weeks (Hinton, 2005), 12 weeks (Hollifield, 2007), 4 to 5.5 weeks (Kubany, 2004), 4.5 months (Kubany, 2003), 4.8 months (Liedl, 2011), 14 weeks (McDonagh, 2005), 8 weeks (Spence, 2011), 5 sessions (van Emmerik, 2008), 2 months (Hogberg, 2007), 4 weeks (Rothbaum, 1997), 6 weeks (Carlson, 1998), 5 to 17 sessions (Neuner, 2010), 3 weeks (Neuner, 2008), 3 to 4 weeks (Neuner, 2004).

Note: A couple of the comparison groups were not defined as usual care or treatment as usual by the authors, but we determined that they were minimal interventions and approximated usual care. These included (1) one comparison group for Ehlers 2003 was a self-help booklet, and (2) the included comparison group for Neuner 2004 was a form of psychoeducation.

Abbreviations: CBT = cognitive behavioral therapy; CI = confidence interval; EMDR = eye movement desensitization and reprocessing; N = trial arm sample size; SMD = standardized mean difference (Cohen’s d). A small effect size is d=0.20, medium effect size is d=0.50, and large effect size is d=0.80.25

Figure F-87 is titled “PTSD symptom reduction (any measure) for psychological treatments compared with control: Including waitlist and usual care.” The figure displays a forest plot reporting the standardized mean difference of PTSD symptom reduction scores stratified by cognitive processing therapy compared to waitlist and usual care, CBT-exposure compared to waitlist and usual care, CBT-mixed compared to waitlist and usual care, EMDR compared to waitlist and usual care, and narrative exposure therapy compared to waitlist and usual care. The plot depicts greater reductions in PTSD symptoms for patients treated with the psychological treatments of cognitive processing therapy (4 trials, standardized mean difference −1.40, 95% CI −1.95 to −0.85, I2= 77.8%), CBT-exposure (7 trials, standardized mean difference −1.27, 95% CI −1.54 to −1.00, I2= 23.3%), CBT-mixed (15 trials, standardized mean difference −1.17, 95% CI −1.50 to −0.85, I2= 77.5%), EMDR (5 trials, standardized mean difference −1.08, 95% CI −1.83 to −0.33, I2= 70.0%), and narrative exposure therapy (3 trials, standardized mean difference −1.25, 95% CI −1.92 to −0.58, I2= 68.4%) compared to waitlist.

Figure F-88 PTSD symptom reduction (any measure) for psychological treatments compared with control: including waitlist, usual care, and other comparators

Timing of outcome assessment: 17 weeks (Chard, 2005), 12 weeks (Forbes, 2012), 10 weeks (Monson, 2006), 6 weeks (Resick, 2002), 3 months (Ehlers 2005, Ehlers 2003, and Mueser 2008), 8 weeks (Basoglu, 2007), 12 weeks (Foa, 2005), 9 weeks (Foa, 1999), 4.5 weeks (Rothbaum, 2005), 8 to 15 weekly sessions (Asukai, 2010), 9 to 15 weeks (Nacasch, 2011), 10 weeks (Schnurr, 2007), 7 weeks (Johnson, 2011), 8 to 12 weeks (Blanchard, 2003), 12 weeks (Cloitre, 2002), 4 weeks (Fecteau, 1999), 12 weeks (Foa, 2005), 9 weeks (Foa, 1999), 12 weeks (Hinton, 2005), 12 weeks (Hollifield, 2007), 4 to 5.5 weeks (Kubany, 2004), 4.5 months (Kubany, 2003), 4.8 months (Liedl, 2011), 14 weeks (McDonagh, 2005), 8 weeks (Spence, 2011), 5 sessions (van Emmerik, 2008), 16 weeks (Cottraux, 2008), 8 weeks (Litz, 2007), 8 weeks (van der Kolk, 2007), 2 months (Hogberg, 2007), 4 weeks (Rothbaum, 1997), 6 weeks (Carlson, 1998), 5 to 17 sessions (Neuner, 2010), 3 weeks (Neuner, 2008), 3 to 4 weeks (Neuner, 2004).

Abbreviations: CBT = cognitive behavioral therapy; CI = confidence interval; EMDR = eye movement desensitization and reprocessing; N = trial arm sample size; SMD = standardized mean difference (Cohen’s d). A small effect size is d=0.20, medium effect size is d=0.50, and large effect size is d=0.80.^25^

Figure F-88 is titled “PTSD symptom reduction (any measure) for psychological treatments compared with control: Including waitlist, usual care, and other comparators.” The figure displays a forest plot reporting the standardized mean difference of PTSD symptom reduction scores stratified by cognitive processing therapy compared to waitlist, usual care, and other comparators; CBT-exposure compared to waitlist, usual care, and other comparators; CBT-mixed compared to waitlist, usual care, and other comparators; EMDR compared to waitlist, usual care, and other comparators; and narrative exposure therapy compared to waitlist, usual care, and other comparators. The plot depicts greater reductions in PTSD symptoms for patients treated with the psychological treatments of cognitive processing therapy (4 trials, standardized mean difference −1.40, 95% CI −1.95 to −0.85, I2= 77.8%), CBT-exposure (8 trials, standardized mean difference −1.17, 95% CI −1.63 to −0.71, I2= 83.3%), CBT-mixed (17 trials, standardized mean difference −1.06, 95% CI −1.37 to −0.75, I2= 79.2%), EMDR (5 trials, standardized mean difference −0.92, 95% CI −1.55 to −0.29, I2= 71.8%), and narrative exposure therapy (3 trials, standardized mean difference −1.25, 95% CI −1.92 to −0.58, I2= 68.4%) compared to control.

## Key Question 2

### Alpha-Blockers: Meta-Analysis Results

Figure F-89 Change in CAPS for prazosin compared with placebo

Timing of outcome assessment: 20 weeks (Raskind, 2003), 8 weeks (Raskind).

Figure F-89 is titled “Change in CAPS for prazosin compared with placebo.” The figure displays a forest plot reporting the weighted mean difference in CAPS scores for prazosin versus placebo. The plot depicts greater reductions in CAPS scores for patients treated with prazosin than placebo (2 trials, weighted mean difference −8.86 (95% CI −22.06 to 4.33, I2=1.8%).

### Anticonvulsants/Mood Stabilizers: Meta-Analysis Results

Figure F-90 Change in CAPS for anticonvulsants compared with placebo

Timing of outcome assessment: 8 weeks (Davis, 2008), 12 weeks (Davidson, 2007; Akuchekian, 2004; Tucker, 2007; Yeh, 2011).

Figure F-90 is titled “Change in CAPS for anticonvulsants compared with placebo.” The figure displays a forest plot reporting the weighted mean difference in CAPS scores stratified by divalproex versus placebo, tiagabine versus placebo, and topiramate versus placebo. The plot depicts a greater reduction in CAPS scores for patients treated with placebo than divalproex (1 trial, weighted mean difference 1.40, 95% CI −8.22 to 11.02). On the other hand, the plot also depicts greater reductions in CAPS scores for patients treated with tiagabine (1 trial, weighted mean difference −0.50, 95% CI −7.12 to 6.12) or topiramate (3 trials, weighted mean difference −15.53, 95% CI −19.40 to −11.65, I2=0.0%) than placebo. The overall analysis favored anticonvulsants (weighted mean difference −7.85, 95% CI −17.13 to 1.42, I2=81.4%).

Table F-38 Change in CAPS for anticonvulsants compared with placebo: Statistics with one study removed for topiramate

Study Omitted | Overall Estimate | 95% Confidence Interval
Akuchekian, 2004 | −14.09 | (−26.92 to −1.27)
Tucker, 2007 | −15.77 | (−19.75 to −11.80)
Yeh, 2011 | −15.42 | (−19.38 to −11.46)
Combined | −15.53 | (−19.40 to −11.65)

Figure F-91 Change in CAPS for anticonvulsants compared with placebo: Sensitivity analysis including studies with high risk of bias

Note: Hamner et al., 2009 and Lindley et al., 2007 were rated as high risk of bias.

Timing of outcome assessment: 8 weeks (Davis, 2008), 10 weeks (Hamner, 2009), 7 weeks (Lindley, 2007); 12 weeks (Davidson, 2007; Akuchekian, 2004; Tucker, 2007; Yeh, 2011).

Figure F-91 is titled “Change in CAPS for anticonvulsants compared with placebo: Sensitivity analysis including studies with high risk of bias.” The figure displays a forest plot reporting the weighted mean difference in CAPS scores stratified by divalproex versus placebo, tiagabine versus placebo, and topiramate versus placebo. The plot depicts greater reductions in CAPS scores for patients treated with placebo than divalproex (2 trials, weighted mean difference 4.90, 95% CI −4.75 to 14.54, I2=22.8%). On the other hand, there were greater reductions in CAPS scores for patients treated with tiagabine (1 trial, weighted mean difference −0.50, 95% CI −7.12 to 6.12) or topiramate (4 trials, weighted mean difference −15.29, 95% CI −19.00 to −11.57, I2=0.0%) than placebo. The overall analysis favored anticonvulsants (weighted mean difference −6.12, 95% CI −14.37 to 2.14, I2=79.7%).

### Atypical Antipsychotics: Meta-Analysis Results

Figure F-92 Change in CAPS for atypical antipsychotics compared with placebo

Timing of outcome assessment: 5 weeks (Hamner, 2003), 16 weeks (Bartzokis, 2003), 8 weeks (Reich, 2004), 24 weeks (Krystal, 2011), 8 weeks (Stein, 2002).

Figure F-92 is titled “Change in CAPS for atypical antipsychotics compared with placebo.” The figure displays a forest plot reporting the weighted mean difference in CAPS scores for atypical antipsychotics versus placebo stratified by risperidone versus placebo and olanzapine versus placebo. The plot depicts greater reductions in CAPS scores for patients treated with risperidone (4 trials, weighted mean difference −4.60, 95% CI −9.01 to −0.20, I2=22.3%) or olanzapine (1 trial, weighted mean difference −12.13, 95% CI −23.29 to −0.97) than placebo. The overall analysis favored atypical antipsychotics (weighted mean difference −5.76, 95% CI −10.35 to −1.17, I2=30.7%).

Table F-39 Change in CAPS for atypical antipsychotics compared with placebo: Statistics with one study removed for risperidone

Study Omitted | Overall Estimate | 95% Confidence Interval
Hamner, 2003 | −5.62 | (−11.10 to −0.15)
Bartzokis, 2004 | −2.74 | (−6.13 to 0.65)
Reich, 2004 | −4.39 | (−9.59 to 0.80)
Krystal, 2011 | −7.62 | (−13.77 to −1.46)
Combined | −4.60 | (−9.01 to −0.20)

Figure F-93 Change in CAPS for atypical antipsychotics compared with placebo: Sensitivity analysis including studies with high risk of bias

Note: Rothbaum et al., 2008 was rated as high risk of bias.

Timing of outcome assessment: 5 weeks (Hamner, 2003), 16 weeks (Bartzokis, 2003), 8 weeks (Reich, 2004), 16 weeks (Rothbaum, 2008), 24 weeks (Krystal, 2011), 8 weeks (Stein, 2002).

Figure F-93 is titled “Change in CAPS for atypical antipsychotics compared with placebo: Sensitivity analysis including studies with high risk of bias.” The figure displays a forest plot reporting the weighted mean difference in CAPS scores stratified by risperidone versus placebo and olanzapine versus placebo. The plot depicts greater reductions in CAPS scores for patients treated with risperidone (5 trials, weighted mean difference −4.00, 95% CI −8.48 to 0.49, I2=23.1%) or olanzapine (1 trial, weighted mean difference −12.13, 95% CI −23.29 to −0.97) than placebo. The overall analysis favored atypical antipsychotics (weighted mean difference −5.08, 95% CI −9.70 to −0.45, I2=31.2%).

Figure F-94 PTSD symptom reduction (any measure) for atypical antipsychotics compared with placebo

Timing of outcome assessment: 10 weeks (Butterfield, 2001), 8 weeks (Stein, 2002), 16 weeks (Bartzokis, 2003), 5 weeks (Hamner, 2003), 24 weeks (Krystal, 2011), 8 weeks (Reich, 2004).

Figure F-94 is titled “PTSD symptom reduction (any measure) for atypical antipsychotics compared with placebo.” The figure displays a forest plot reporting the standardized mean difference in PTSD symptom scores for atypical antipsychotics versus placebo stratified by olanzapine versus placebo and risperidone versus placebo. The plot depicts greater reductions in PTSD symptom scores for patients treated with olanzapine (2 trials, standardized mean difference −0.14, 95% CI −1.80 to 1.53, I2=80.7%) or risperidone (4 trials, standardized mean difference −0.26, 95% CI −0.52 to −0.00, I2=22.4%) than placebo. The overall analysis favored atypical antipsychotics (standardized mean difference −0.27, 95% CI −0.60 to 0.06, I2=44.7%).

Table F-40 PTSD symptom reduction (any measure) for atypical antipsychotics compared with placebo: Statistics with one study removed

Study Omitted | Overall Estimate | 95% Confidence Interval
Butterfield, 2001 | −0.33 | (−0.62 to −0.04)
Stein, 2002 | −0.20 | (−0.53 to 0.12)
Bartzokis, 2005 | −0.17 | (−0.52 to 0.18)
Hamner, 2003 | −0.33 | (−0.73 to 0.05)
Krystal, 2011 | −0.30 | (−0.80 to 0.19)
Reich, 2004 | −0.25 | (−0.63 to 0.13)
Combined | −0.27 | (−0.60 to 0.06)

Table F-41 PTSD symptom reduction (any measure) for atypical antipsychotics compared with placebo: Statistics with one study removed, by drug

Study Omitted | Overall Estimate | 95% Confidence Interval
Olanzapine
Butterfield, 2001 | −0.96 | (−1.92 to −0.01)
Stein, 2002 | 0.74 | (−0.37 to 1.85)
Combined | −0.14 | (−1.80 to 1.53)
Risperidone
Bartzokis, 2005 | −0.16 | (−0.37 to 0.04)
Hamner, 2003 | −0.33 | (−0.65 to −0.02)
Krystal, 2011 | −0.36 | (−0.81 to 0.09)
Reich, 2004 | −0.26 | (−0.59 to 0.08)
Combined | −0.26 | (−0.52 to −0.00)

Figure F-95 PTSD symptom reduction (any measure) for atypical antipsychotics compared with placebo: Sensitivity analysis including studies with high risk of bias

Note: Rothbaum et al., 2008 was rated as high risk of bias.

Timing of outcome assessment: 10 weeks (Butterfield, 2001), 8 weeks (Stein, 2002), 16 weeks (Bartzokis, 2003), 5 weeks (Hamner, 2003), 24 weeks (Krystal, 2011), 8 weeks (Reich, 2004), 16 weeks (Rothbaum, 2008).

Figure F-95 is titled “PTSD symptom reduction (any measure) for atypical antipsychotics compared with placebo: Sensitivity analysis including studies with high risk of bias.” The figure displays a forest plot reporting the standardized mean difference in PTSD symptom scores for atypical antipsychotics versus placebo stratified by olanzapine versus placebo and risperidone versus placebo. The plot depicts greater reductions in PTSD symptom scores for patients treated with olanzapine (2 trials, standardized mean difference −0.14, 95% CI −1.80 to 1.53, I2=80.7%) or risperidone (5 trials, standardized mean difference −0.21, 95% CI −0.48 to 0.05, I2=26.6%) than placebo. The overall analysis favored atypical antipsychotics (standardized mean difference −0.21, 95% CI −0.52 to 0.10, I2=43.5%).

### Benzodiazepines: Meta-Analysis Results

None

### SNRIs: Meta-Analysis Results

Figure F-96 Change in CAPS for venlafaxine compared with placebo

Timing of outcome assessment: 24 weeks (Davidson, 2006a), 12 weeks (Davidson, 2006b).

Figure F-96 is titled “Change in CAPS for venlafaxine compared with placebo.” The figure displays a forest plot reporting the weighted mean difference in CAPS scores for venlafaxine versus placebo. The plot depicts greater reductions in CAPS scores for patients treated with venlafaxine than placebo (2 trials, weighted mean difference −7.15, 95% CI −11.02 to −3.28, I2=0.0%).

Figure F-97 PTSD remission for venlafaxine compared with placebo

Timing of outcome assessment: 24 weeks (Davidson, 2006a), 12 weeks (Davidson, 2006b).

Figure F-97 is titled “PTSD remission for venlafaxine compared with placebo.” The figure displays a forest plot reporting the risk difference of PTSD remission for patients treated with venlafaxine versus placebo. The plot depicts that 12% more patients treated with venlafaxine achieved PTSD remission than placebo (2 trials, risk difference 0.12, 95% CI 0.05 to 0.19, I2=0.0%).

Figure F-98 Change in HAMD for venlafaxine compared with placebo

Figure F-98 is titled “Change in HAMD for venlafaxine compared with placebo.” The figure displays a forest plot reporting the weighted mean difference in HAMD scores for patients treated with venlafaxine versus placebo. The plot depicts greater reductions in HAMD scores for patients treated with venlafaxine than placebo (2 trials, weighted mean difference −2.08, 95% CI −3.12 to −1.04, I2=0.0%).

Figure F-99 Change in Q-LES-Q-SF for venlafaxine compared with placebo

Timing of outcome assessment: 24 weeks (Davidson, 2006a), 12 weeks (Davidson, 2006b).

Figure F-99 is titled “Change in Q-LES-Q-SF for venlafaxine compared with placebo.” The figure displays a forest plot reporting the weighted mean difference in Q-LES-Q-SF scores for patients treated with venlafaxine versus placebo. The plot depicts greater reductions in Q-LES-Q-SF scores for patients treated with venlafaxine than placebo (2 trials, weighted mean difference 3.42, 95% CI 1.58 to 5.26, I2=0.0%).

Figure F-100 Change in SDS for venlafaxine compared with placebo

Timing of outcome assessment: 24 weeks (Davidson, 2006a), 12 weeks (Davidson, 2006b).

Figure F-100 is titled “Change in SDS for venlafaxine compared with placebo.” The figure displays a forest plot reporting the weighted mean difference in SDS scores for patients treated with venlafaxine versus placebo. The plot depicts greater reductions in SDS scores for patients treated with venlafaxine than placebo (2 trials, weighted mean difference −2.06, 95% CI −3.28 to −0.84, I2=0.0%).

Figure F-101 Change in GAF for venlafaxine compared with placebo

Timing of outcome assessment: 24 weeks (Davidson, 2006a), 12 weeks (Davidson, 2006b).

Figure F-101 is titled “Change in GAF for venlafaxine compared with placebo.” The figure displays a forest plot reporting the weighted mean difference in GAF scores for patients treated with venlafaxine versus placebo. The plot depicts greater reductions in GAF scores for patients treated with venlafaxine than placebo (2 trials, weighted mean difference 3.41, 95% CI 1.41 to 5.40, I2 = 0.0%).

### SSRIs: Meta-Analysis Results

Figure F-102 PTSD symptom reduction (any measure) for SSRIs compared with placebo

Timing of outcome assessment: 10 weeks (Tucker, 2003; Panahi, 2011; Tucker, 2004; Zohar, 2002), 12 weeks (Connor, 1999; Martenyi, 2007; Marshall, 2001; Tucker, 2001; Brady, 2005; Brady, 2000; Davidson, 2001; Friedman, 2007), 8 weeks (van der Kolk, 2007), 5 weeks (van der Kolk, 1994), 24 weeks (Davidson, 2006).

Figure F-102 is titled “PTSD symptom reduction (any measure) for SSRIs compared with placebo.” The figure displays a forest plot reporting the standardized mean difference in PTSD symptom scores stratified by citalopram versus placebo, fluoxetine versus placebo, paroxetine versus placebo, and sertraline versus placebo. The plot depicts greater reductions in PTSD symptom scores for patients treated with placebo than citalopram (1 trial, standardized mean difference 0.34, 95% CI −0.40 to 1.08). On the other hand, the plot also depicts greater reductions in PTSD symptom scores for patients treated with fluoxetine (6 trials, standardized mean difference −0.31, 95% CI −0.44 to −0.17, I2=0.0%), paroxetine (3 trials, standardized mean difference −0.49, 95% CI −0.61 to −0.37, I2=0.0%), or sertraline (8 trials, standardized mean difference −0.25, 95% CI −0.42 to −0.07, I2=46.3%) than placebo. The overall analysis favored SSRIs (standardized mean difference −0.33, 95% CI −0.43 to −0.22, I2=45.8%).

Table F-42 PTSD symptom reduction (any measure) for SSRIs compared with placebo: Statistics with one study removed

Study Omitted | Overall Estimate | 95% Confidence Interval
Tucker, 2003 | −0.34 | (−0.44 to −0.24)
Connor, 1999 | −0.31 | (−0.41 to −0.21)
Martenyi, 2007 (20mg) | −0.33 | (−0.44 to −0.22)
Martenyi, 2007 (40mg) | −0.33 | (−0.44 to −0.22)
Martenyi, 2002 | −0.33 | (−0.44 to −0.22)
van der Kolk, 2007 | −0.33 | (−0.44 to −0.22)
van der Kolk, 1994 | −0.32 | (−0.43 to −0.21)
Marshall, 2001 (20mg) | −0.30 | (−0.41 to −0.20)
Marshall, 2001 (40mg) | −0.31 | (−0.42 to −0.20)
Tucker, 2001 | −0.32 | (−0.43 to −0.20)
Brady, 2005 | −0.34 | (−0.44 to −0.24)
Brady, 2000 | −0.32 | (−0.43 to −0.21)
Davidson, 2006 | −0.34 | (−0.45 to −0.23)
Davidson, 2001 | −0.33 | (−0.44 to −0.22)
Freidman, 2007 | −0.35 | (−0.45 to −0.26)
Panahi, 2011 | −0.31 | (−0.42 to −0.21)
Tucker, 2004 | −0.33 | (−0.44 to −0.22)
Zohar, 2002 | −0.32 | (−0.42 to −0.21)
Combined | −0.33 | (−0.43 to −0.22)

Table F-43 PTSD symptom reduction (any measure) for SSRIs compared with placebo: Statistics with one study removed, by drug

Study Omitted | Overall Estimate | 95% Confidence Interval
Fluoxetine
Connor, 1999 | −0.28 | (−0.42 to −0.14)
Martenyi, 2007 (20mg) | −0.34 | (−0.52 to −0.16)
Martenyi, 2007 (40mg) | −0.35 | (−0.52 to −0.18)
Martenyi, 2002 | −0.33 | (−0.52 to −0.15)
van der Kolk, 2007 | −0.33 | (−0.48 to −0.17)
van der Kolk, 1994 | −0.29 | (−0.43 to −0.15)
Combined | −0.31 | (−0.44 to −0.17)
Paroxetine
Marshall, 2001 (20mg) | −0.45 | (−0.60 to −0.30)
Marshall, 2001 (40mg) | −0.50 | (−0.65 to −0.35)
Tucker, 2001 | −0.51 | (−0.65 to −0.36)
Combined | −0.49 | (−0.61 to −0.37)
Sertraline
Brady, 2005 | −0.28 | (−0.47 to −0.09)
Brady, 2000 | −0.23 | (−0.43 to −0.03)
Davidson, 2006 | −0.27 | (−0.49 to −0.05)
Davidson, 2001 | −0.25 | (−0.46 to −0.04)
Friedman, 2007 | −0.30 | (−0.46 to −0.14)
Panahi, 2011 | −0.20 | (−0.36 to −0.04)
Tucker, 2004 | −0.26 | (−0.44 to −0.07)
Zohar, 2002 | −0.21 | (−0.37 to −0.05)
Combined | −0.25 | (−0.42 to −0.07)

Figure F-103 PTSD symptom reduction (any measure) for SSRIs compared with placebo: Sensitivity analysis including studies with high risk of bias

Note: Hertzberg et al., 2000, and Marshall et al., 2007, were rated as having a high risk of bias.

Timing of outcome assessment: 10 weeks (Tucker, 2003; Marshall, 2007; Panahi, 2011; Tucker, 2004; Zohar, 2002), 12 weeks (Connor, 1999; Hertzberg, 2000; Martenyi, 2007; Marshall, 2001; Tucker, 2001; Brady, 2005; Brady, 2000; Davidson, 2001; Friedman, 2007), 8 weeks (van der Kolk, 2007), 5 weeks (van der Kolk, 1994), 24 weeks (Davidson, 2006).

Figure F-103 is titled “PTSD symptom reduction (any measure) for SSRIs compared with placebo: Sensitivity analysis including studies with high risk of bias.” The figure displays a forest plot reporting standardized mean difference in PTSD symptoms stratified by citalopram versus placebo, fluoxetine versus placebo, paroxetine versus placebo, and sertraline versus placebo. The plot depicts greater reductions in PTSD symptom scores for patients treated with placebo than citalopram (1 trial, standardized mean difference 0.34, 95% CI −0.40 to 1.08). On the other hand, the plot also depicts greater reductions in PTSD symptom scores for patients treated with fluoxetine (7 trials, standardized mean difference −0.3, 95% CI −0.44 to −0.17, I2=0.0%), paroxetine (4 trials, standardized mean difference −0.47, 95% CI −0.59 to −0.35, I2=0.0%), or sertraline (8 trials, standardized mean difference −0.25, 95% CI −0.42 to −0.07, I2=46.3%) than placebo. The overall analysis continued to favor SSRIs (standardized mean difference −0.32, 95% CI −0.42 to −0.22, I2=41.8%).

Figure F-104 Change in CAPS for SSRIs compared with placebo

Timing of outcome assessment: 10 weeks (Tucker, 2003; Zohar, 2002), 12 weeks (Martenyi, 2007; Martenyi, 2002; Marshall, 2001; Tucker, 2001; Brady, 2005; Brady, 2000; Davidson, 2001; Friedman, 2007; Davidson, 2006), 8 weeks (van der Kolk, 2007), 5 weeks (van der Kolk, 1994).

Figure F-104 is titled “Change in CAPS for SSRIs compared with placebo.” The figure displays a forest plot reporting the weighted mean difference in CAPS scores stratified by fluoxetine compared with placebo, paroxetine compared with placebo, and sertraline compared with placebo. This figure is described further in the “PTSD symptom reduction” section as follows: “Our meta-analyses found fluoxetine, paroxetine, and sertraline to improve PTSD symptoms, as measured by improvement in CAPS, more than placebo. We found no statistically significant difference between citalopram and placebo, and results trended in favor of placebo (1 trial). Magnitude of benefit ranged from a difference of −4.9 for sertraline to −12.6 for paroxetine compared with placebo. The meta-analyses for change in CAPS did not have significant statistical heterogeneity for any of the individual medications compared with placebo (I2=0% for each).”

Table F-44 Change in CAPS for SSRIs compared with placebo: Statistics with one study removed, by drug

Study Omitted | Overall Estimate | 95% Confidence Interval
Fluoxetine
Martenyi, 2007 (20mg) | −7.25 | (−11.35, −3.15)
Martenyi, 2007 (40mg) | −7.23 | (−11.23, −3.24)
van der Kolk, 2007 | −7.34 | (−11.03, −3.66)
Martenyi, 2002 | −6.70 | (−10.69, −2.71)
van der Kolk, 1994 | −6.41 | (−10.04, −2.78)
Combined | −6.97 | (−10.43, −2.78)
Paroxetine
Marshall, 2001 (20mg) | −11.68 | (−15.54, −7.82)
Marshall, 2001 (40mg) | −12.62 | (−16.37, −8.87)
Tucker, 2001 | −13.50 | (−17.29, −9.71)
Combined | −12.61 | (−15.71, −9.51)
Sertraline
Friedman, 2007 | −5.56 | (−8.20, −2.93)
Davidson, 2006 | −4.68 | (−7.77, −1.59)
Brady, 2005 | −5.22 | (−7.83, −2.61)
Tucker, 2003 | −4.84 | (−7.60, −2.08)
Zohar, 2002 | −4.57 | (−8.03, −1.11)
Davidson, 2001 | −4.47 | (−7.33, −1.62)
Brady, 2000 | −4.31 | (−6.96, −1.65)
Combined | −4.87 | (−7.38, −2.35)

Figure F-105 Change in CAPS for SSRIs compared with placebo: Sensitivity analysis including studies with high risk of bias

Note: Marshall et al., 2007 was rated as high risk of bias.

Timing of outcome assessment: 10 weeks (Tucker, 2003; Marshall, 2007; Zohar, 2002), 12 weeks (Martenyi, 2007; Martenyi, 2002; Marshall, 2001; Tucker, 2001; Brady, 2005; Brady, 2000; Davidson, 2001; Friedman, 2007; Davidson, 2006), 8 weeks (van der Kolk, 2007), 5 weeks (van der Kolk, 1994).

Figure F-105 is titled “Change in CAPS for SSRIs compared with placebo: Sensitivity analysis including studies with high risk of bias.” The figure displays a forest plot reporting the weighted mean difference CAPS scores stratified by fluoxetine compared with placebo, paroxetine compared with placebo, and sertraline compared with placebo. The plot depicts greater reductions in CAPS scores for patients treated with placebo than citalopram (1 trial, weighted mean difference 7.98, 95% CI −10.07 to 26.03). On the other hand, the plot also depicts greater reductions in CAPS scores for patients treated with fluoxetine (5 trials, weighted mean difference −6.97, 95% CI −10.43 to −3.51, I2=0.0%), paroxetine (3 trials, weighted mean difference −12.61, 95% CI −15.71 to −9.51, I2=0.0%), and sertraline (7 trials, weighted mean difference −4.87, 95% CI −7.38 to −2.35, I2=0.0%) than placebo. The overall analysis continued to favor SSRIs (weighted mean difference −7.24, 95% CI −9.57 to −4.90, I2=40.9%).

Figure F-106 Change in DTS for SSRIs compared with placebo

Timing of outcome assessment: 12 weeks for all included studies.

Figure F-106 is titled “Change in DTS for SSRIs compared with placebo.” The figure displays a forest plot reporting the weighted mean difference in DTS scores stratified by fluoxetine compared with placebo, paroxetine compared with placebo, and sertraline compared with placebo. This figure is described further in the “PTSD symptom reduction” section as follows: “Our meta-analyses of mean change from baseline in DTS found similar results as those for CAPS, with fluoxetine, paroxetine, and sertraline improving PTSD symptoms more than placebo. Magnitude of benefit ranged from −7.7 (95% CI −12.9, −2.4, 4 trials, N=916) for sertraline to −12.2 (95% CI −15.8, −8.7, 2 trials, N=886) for paroxetine compared with placebo.”

Figure F-107 Change in DTS for SSRIs compared with placebo: Sensitivity analysis including studies with high risk of bias

Note: Hertzberg et al., 2000 was rated as high risk of bias.

Timing of outcome assessment: 12 weeks for all included studies.

Figure F-107 is titled “Change in DTS for SSRIs compared with placebo: Sensitivity analysis including studies with high risk of bias.” The figure displays a forest plot reporting the weighted mean difference in DTS scores stratified by fluoxetine compared with placebo, paroxetine compared with placebo, and sertraline compared with placebo. The plot depicts greater reductions in DTS scores for patients treated with fluoxetine (5 trials, weighted mean difference −7.64, 95% CI −12.97 to −2.30, I2=25.0%), paroxetine (3 trials, standardized mean difference −12.22, 95% CI −15.76 to −8.67, I2=0.0%), and sertraline (4 trials, weighted mean difference −7.67, 95% CI −12.94 to −2.39, I2= 44.9%) than placebo. The overall analysis continued to favor SSRIs (weighted mean difference −9.30, 95% CI −12.0 to −6.60, I2=26.9%).

Figure F-108 Change in IES for SSRIs compared with placebo

Timing of outcome assessment: 10 weeks (Tucker, 2003; Panahi, 2011), 12 weeks (Brady, 2000; Davidson, 2001; Friedman, 2007).

Figure F-108 is titled “Change in IES for SSRIs compared with placebo.” The figure displays a forest plot reporting the weighted mean difference in IES scores stratified by citalopram compared with placebo and sertraline compared with placebo. This figure is described further in the “PTSD symptom reduction” section as follows: “One trial found no statistically significant difference between citalopram and placebo, with results trending in favor of placebo (weighted mean difference 7.8; 95% CI −4.8 to 20.5, N=35). Our meta-analysis found greater improvement in symptoms measured with the IES for patients treated with sertraline than for those who received placebo (weighted mean difference −3.96; 95% CI −6.0 to −1.9; I2=0%, 5 trials, N=667).”

Figure F-109 Change in TOPS/TOP-8 for SSRIs compared with placebo

Timing of outcome assessment: 12 weeks for all included studies.

Figure F-109 is titled “Change in TOPS/TOP-8 for SSRIs compared with placebo.” The figure displays a forest plot reporting the weighted mean difference in TOPS/TOP-8 scores stratified by fluoxetine compared with placebo and paroxetine compared with placebo. This figure is described further in the “PTSD symptom reduction” section as follows: “Using the TOP-8 as a measure of PTSD symptoms, one trial found greater improvement with fluoxetine compared with placebo (weighted mean difference −2.3; 95% CI, −3.5 to −1.1, N=301); our meta-analysis of trials comparing paroxetine with placebo found greater improvement with paroxetine (weighted mean differences −3.3; 95% CI −4.2 to −2.4; I2=0%, 2 trials contributing 3 comparisons, N=886).”

Figure F-110 Depression symptom reduction (any measure) for SSRIs compared with placebo

Timing of outcome assessment: 10 weeks (Tucker, 2003; Zohar, 2002), 12 weeks (Martenyi, 2007; Martenyi, 2002; Marshall, 2001; Tucker, 2001; Brady, 2005; Brady, 2000; Davidson, 2001; Friedman, 2007; Davidson, 2006), 8 weeks (van der Kolk, 2007).

Figure F-110 is titled “Depression symptom reduction (any measure) for SSRIs compared with placebo.” The figure displays a forest plot reporting the weighted mean difference in depression symptom scores stratified by citalopram compared with placebo, paroxetine compared with placebo, and sertraline compared with placebo. This figure is described further in the “Prevention or reduction of comorbid medical or psychiatric conditions” section as follows: “Our meta-analyses using any measure for depression symptom reduction found effect sizes (i.e., Cohen’s d; standardized mean difference) of −0.04 (95% CI −0.77 to 0.70), −0.20 (95% CI −0.40 to −0.00), −0.49 (95% CI −0.64 to −0.34), and −0.13 (95% CI −0.32 to 0.06) for citalopram, fluoxetine, paroxetine, and sertraline, respectively.”

Table F-45 Depression symptom reduction (any measure) for SSRIs compared with placebo: Statistics with one study removed

Study Omitted | Overall Estimate | 95% Confidence Interval
Tucker, 2003 | −0.25 | (−0.38 to −0.11)
Martenyi, 2007 (20mg) | −0.25 | (−0.39 to −0.11)
Martenyi, 2007 (40mg) | −0.25 | (−0.39 to −0.11)
Martenyi, 2002 | −0.22 | (−0.37 to −0.08)
van der Kolk, 2007 | −0.26 | (−0.39 to −0.13)
Marshall, 2001 (20mg) | −0.21 | (−0.34 to −0.08)
Marshall, 2001 (40mg) | −0.22 | (−0.35 to −0.08)
Tucker, 2001 | −0.23 | (−0.38 to −0.09)
Brady, 2005 | −0.26 | (−0.40 to −0.12)
Brady, 2000 | −0.24 | (−0.38 to −0.09)
Davidson, 2006 | −0.25 | (−0.40 to −0.11)
Davidson, 2001 | −0.25 | (−0.39 to −0.11)
Friedman, 2007 | −0.28 | (−0.40 to −0.15)
Tucker, 2004 | −0.25 | (−0.39 to −0.12)
Zohar, 2002 | −0.22 | (−0.35 to −0.09)
Combined | −0.24 | (−0.38 to −0.11)

Table F-46 Depression symptom reduction (any measure) for SSRIs compared with placebo: Statistics with one study removed, by drug

Study Omitted | Overall Estimate | 95% Confidence Interval
Fluoxetine
Martenyi, 2007 (20mg) | −0.21 | (−0.50 to −0.09)
Martenyi, 2007 (40mg) | −0.21 | (−0.50 to −0.09)
Martenyi, 2002 | −0.12 | (−0.29 to −0.06)
van der Kolk, 2007 | −0.25 | (−0.44 to −0.06)
Combined | −0.20 | (−0.40 to −0.00)
Paroxetine
Marshall, 2001 (20mg) | −0.43 | (−0.61 to −0.25)
Marshall, 2001 (40mg) | −0.47 | (−0.72 to −0.22)
Tucker, 2001 | −0.56 | (−0.70 to −0.41)
Combined | −0.49 | (−0.64 to −0.34)
Sertraline
Brady, 2005 | −0.16 | (−0.37 to 0.05)
Brady, 2000 | −0.10 | (−0.32 to 0.12)
Davidson, 2006 | −0.15 | (−0.40 to 0.11)
Davidson, 2001 | −0.14 | (−0.38 to 0.10)
Friedman, 2007 | −0.19 | (−0.38 to 0.00)
Tucker, 2004 | −0.15 | (−0.35 to 0.05)
Zohar, 2002 | −0.09 | (−0.22 to 0.04)
Combined | −0.13 | (−0.32 to 0.06)

Figure F-111 Depression symptom reduction (any measure) for SSRIs compared with placebo: Sensitivity analysis including studies with high risk of bias

Note: Marshall et al., 2007 was rated as high risk of bias.

Timing of outcome assessment: 10 weeks (Tucker, 2003; Marshall, 2007; Zohar, 2002), 12 weeks (Martenyi, 2007; Martenyi, 2002; Marshall, 2001; Tucker, 2001; Brady, 2005; Brady, 2000; Davidson, 2001; Friedman, 2007; Davidson, 2006), 8 weeks (van der Kolk, 2007).

Figure F-111 is titled “Depression symptom reduction (any measure) for SSRIs compared with placebo: Sensitivity analysis including studies with high risk of bias.” The figure displays a forest plot reporting the standardized mean difference in depression symptom scores stratified by citalopram compared with placebo, fluoxetine compared with placebo, paroxetine compared with placebo, and sertraline compared with placebo. The plot depicts greater reductions in depression scores for patients treated with citalopram (1 trial, standardized mean difference −0.04, 95% CI −0.77 to 0.70), fluoxetine (4 trials, standardized mean difference −0.20, 95% CI −0.40 to −0.00, I2=43.8%), paroxetine (4 trials, standardized mean difference −0.45, 95% CI −0.62 to −0.29, I2=43.0%), and sertraline (7 trials, standardized mean difference −0.13, 95% CI −0.32 to 0.06, I2=52.6%) than placebo. The overall analysis continued to favor SSRIs (standardized mean difference −0.24, 95% CI −0.37 to −0.11, I2=63.3%).

Figure F-112 Change in HAM-D for SSRIs compared with placebo

Timing of outcome assessment: 12 weeks for all included studies.

Figure F-112 is titled “Change in HAM-D for SSRIs compared with placebo.” The figure displays a forest plot reporting the weighted mean difference in HAM-D scores for sertraline compared with placebo. This figure is described further in the “Prevention or reduction of comorbid medical or psychiatric conditions” section as follows: “For sertraline, data was available for meta-analysis of five trials reporting the HAM-D. Our meta-analysis found no statistically significant difference between sertraline and placebo (HAM-D, mean change from baseline: weighted mean difference −0.77; 95% CI −2.1 to 0.55; I2=25%, 5 trials, N=1,010). Data trended in favor of sertraline for three of the individual trials; it favored placebo for the other two.”

Figure F-113 Change in HAM-D for SSRIs compared with placebo: Sensitivity analysis including studies with high risk of bias

Note: Marshall et al., 2007 was rated as high risk of bias.

Timing of outcome assessment: 10 weeks (Marshall, 2007), 12 weeks (Brady, 2005; Brady, 2000; Davidson, 2001; Friedman, 2007; Davidson, 2006).

Figure F-113 is titled “Change in HAM-D for SSRIs compared with placebo: Sensitivity analysis including studies with high risk of bias.” The figure displays a forest plot reporting the weighted mean difference in HAM-D scores stratified by paroxetine compared with placebo and sertraline compared with placebo including high risk of bias studies. The plot depicts greater reductions in HAM-D scores for patients treated with paroxetine (1 trial, weighted mean difference −0.48, 95% CI −4.92 to −3.96, I2=0.0%) and sertraline (5 trials, weighted mean difference −0.77, 95% CI −2.10 to 0.55, I2=25.0%) than placebo. The overall analysis favored SSRIs (weighted mean difference −0.76, 95% CI −1.87 to 0.34, I2=6.5%).

Figure F-114 Change in MADRS for SSRIs compared with placebo

Timing of outcome assessment: 10 weeks (Zohar, 2002), 12 weeks (Martenyi, 2007; Martenyi, 2002; Marshall, 2001; Tucker, 2001).

Figure F-114 is titled “Change in MADRS for SSRIs compared with placebo.” The figure displays a forest plot reporting the weighted mean difference in MADRS scores stratified by fluoxetine compared with placebo, paroxetine compared with placebo, and sertraline compared with placebo. This figure greater reductions in MADRS scores for patients treated with fluoxetine (3 trials, weighted mean difference −2.39, 95% CI −3.68 to −1.10, I2=0.0%), paroxetine (3 trials, weighted mean difference −5.70, 95% CI −7.07to −4.34, I2=0.0%), and sertraline (weighted mean difference −3.21, 95% CI −5.18 to −1.24. The overall analysis favored SSRIs (weighted mean difference −3.78, 95% CI −5.14 to −2.42, I2=59.1%).

Figure F-115 Change in BDI for SSRIs compared with placebo

Timing of outcome assessment: 10 weeks (Tucker, 2003), 12 weeks (van der Kolk, 2007).

Figure F-115 is titled “Change in BDI for SSRIs compared with placebo.” The figure displays a forest plot reporting the weighted mean difference in BDI scores stratified by citalopram compared with placebo, fluoxetine compared with placebo, and sertraline compared with placebo. The figure depicts greater reductions in BDI scores for patients treated with citalopram than placebo (1 trial, weighted mean difference −0.47, 95% CI −10.98 to −10.04). Patients treated with placebo had greater reductions in BDI scores than those treated with fluoxetine (1 trial, weighted mean differences 1.32, 95% CI −3.45 to 6.09) and sertraline (1 trial, weighted mean differences −2.18, 95% CI −8.60 to 12.96).

Figure F-116 Change in HAM-A for SSRIs compared with placebo

Timing of outcome assessment: 12 weeks for all included studies.

Figure F-116 is titled “Change in HAM-A for SSRIs compared with placebo.” The figure displays a forest plot reporting the weighted mean difference in HAM-A stratified by fluoxetine compared with placebo and sertraline compared with placebo. This figure is described further in the “Prevention or reduction of comorbid medical or psychiatric conditions” section as follows: “Our meta-analysis found greater improvement in anxiety symptoms for patients treated with fluoxetine than for those who received placebo (weighted mean difference −2.1; 95% CI −3.2 to −0.9; I2=0%, 3 trials, N=800, Appendix F). Evidence for fluoxetine was consistent, direct, and precise (moderate SOE). The two trials that compared sertraline with placebo reported mixed results; one trended in favor of sertraline and one in favor of placebo. Meta-analysis of the two trials had substantial heterogeneity (weighted mean difference 0.19; 95% CI −3.14 to 3.51; I2=68.3%, 2 trials, N=377).”

Table F-47 Change in HAM-A for SSRIs compared with placebo: Statistics with one study removed, by drug

Study Omitted | Overall Estimate | 95% Confidence Interval
Fluoxetine
Martenyi, 2007 (20mg) | −2.32 | (−3.79 to −0.85)
Martenyi, 2007 (40mg) | −2.30 | (−3.81 to −0.78)
Martenyi, 2002 | −1.47 | (−2.91 to −0.03)
Combined | −2.06 | (−3.19 to −0.93)
Sertraline
Friedman, 2007 | −1.40 | (−3.76 to 0.96)
Davidson, 2001 | 2.00 | (−0.91 to 4.91)
Combined | 0.19 | (−3.14 to 3.51)

Figure F-117 Change in Q-LES-Q-SF for SSRIs compared with placebo

Timing of outcome assessment: 12 weeks for all included studies.

Figure F-117 is titled “Change in Q-LES-Q-SF for SSRIs compared with placebo.” The figure displays a forest plot reporting the weighted mean difference in Q-LES-Q-SF for sertraline compared with placebo. This figure is described further in the “Quality of life” section as follows: “Results of our meta-analysis trended in favor of sertraline (over placebo) but did not reach statistical significance (mean change in Q-LES-Q: weighted mean difference 4.9; 95% CI −0.88 to 10.7, 2 trials, N=539). The analysis found substantial statistical heterogeneity (I2=72.6%).”

Figure F-118 Change in SDS for SSRIs compared with placebo

Timing of outcome assessment: 12 weeks for all included studies.

Figure F-118 is titled “Change in SDS for SSRIs compared with placebo.” The figure displays a forest plot reporting the weighted mean difference in SDS stratified by fluoxetine compared with placebo, paroxetine compared with placebo, and sertraline compared with placebo. The plot depicts greater reductions in SDS scores for patients treated with fluoxetine (1 trial, weighted mean difference −5.80, 95% CI −9.80 to −1.80), paroxetine (3 trials, weighted mean difference −2.32, 95% CI −3.28 to −1.36, I2=0.0%), and sertraline (1 trial, weighted mean difference −1.65, 95% CI −3.42 to 0.12) than placebo. The overall analysis favored SSRIs over placebo (weighted mean difference −2.32, 95% CI −3.15 to −1.50, I2=0.0%).

Figure F-119 Change in SDS for SSRIs compared with placebo: Sensitivity analysis including studies with high risk of bias

Note: Hertzberg et al., 2000 was rated as high risk of bias.

Timing of outcome assessment: 12 weeks for all included studies.

Figure F-119 is titled “Change in SDS for SSRIs compared with placebo: Sensitivity analysis including studies with high risk of bias.” The figure displays a forest plot reporting the weighted mean difference in SDS stratified by fluoxetine compared with placebo, paroxetine compared with placebo, and sertraline compared with placebo. The plot depicts greater reductions in SDS scores for patients treated with fluoxetine (2 trials, weighted mean difference −2.32, 95% CI −9.92 to 5.28), paroxetine (3 trials, weighted mean difference −2.32, 95% CI −3.28 to −1.36, I2=0.0%), and sertraline (1 trial, weighted mean difference −1.65, 95% CI −3.42 to 0.12) than placebo. The overall analysis continued to favor SSRIs over placebo (weighted mean difference −2.26, 95% CI −3.15 to −1.38, I2=10.05%) with the inclusion of high risk of bias of studies.

### Tricyclic Antidepressants: Meta-Analysis Results

None

### Other Second-Generation Antidepressants: Meta-Analysis Results

Figure F-120 Change in DTS for other second-generation antidepressants compared with placebo

Timing of outcome assessment: 8 weeks for all included studies.

Figure F-120 is titled “Change in DTS for other second-generation antidepressants compared with placebo.” The figure displays a forest plot reporting the weighted mean difference in DTS stratified by buproprion compared with placebo and mirtazapine compared with placebo. The plot depicts greater reductions in DTS scores for patients treated with buproprion (1 trial, weighted mean difference −2.62, 95% CI −23.29 to 18.05) and mirtazapine (1 trial, weighted mean difference −9.50, 95% CI −35.45 to 16.45) than placebo. The overall analysis favored other second-generation antidepressants over placebo (weighted mean difference −5.29, 95% CI −21.46 to 10.88, I2=0.0%).

Figure F-121 PTSD symptom reduction (any measure) for pharmacological treatments compared with placebo

Timing of outcome assessment: 8 weeks (Becker, 2007; Davis, 2008; van der Kolk, 2007; Davidson, 2003; Stein, 2002; Raskind, 2007; Reich, 2004), 10 weeks (Tucker, 2003; Butterfield, 2001; Panahi, 2011; Zohar, 2002), 12 weeks (Connor, 1999; Martenyi, 2007; Martenyi, 2002; Marshall, 2001; Tucker, 2001; Brady, 2005; Brady, 2000; Davidson, 2001; Friedman, 2007; Davidson, 2006b; Davidson, 2007; Akuchekian, 2004; Tucker, 2007; Yeh, 2011), 5 weeks (van der Kolk, 1994; Hamner, 2003), 20 weeks (Raskind, 2003), 16 weeks (Bartzokis, 2004); 24 weeks (Davidson, 2006a).

Figure F-121 is titled “PTSD symptom reduction (any measure) pharmacological treatments compared with placebo. The figure displays a forest plot reporting the standardized mean difference in PTSD symptom reduction stratified by all 13 included pharmacological treatments. This forest plot depicts that patients treated with buproprion (1 trial, standardized mean difference 0.23, 95% CI −0.55 to 1.00), citalopram (1 trial, standardized mean difference 0.34, 95% CI −0.40 to 1.08), and divalproex (1 trial, standardized mean difference 0.06, 95% CI −0.36 to 0.49) did not significantly improve over those treated with placebo. The pharmacological treatments that had greater improvements in PTSD symptom reduction compared with placebo were fluoxetine (6 trials, standardized mean difference −0.31, 95% CI −0.44 to −0.17, I2 = 0.0), mirtazapine (1 trial, standardized mean difference −0.27, 95% CI −1.08 to 0.54), olanzapine (2 trials, standardized mean difference −0.14, 95% CI −1.80 to 1.53, I2 = 80.7), paroxetine (3 trials, standardized mean difference −0.49, 95% CI −0.61 to −0.37, I2 = 0.0%), prazosin (2 trials, standardized mean difference −0.40, 95% CI −0.97 to 0.16, I2= 0.0%), risperidone (4 trials, standardized mean difference −0.26, 95% CI −0.52 to −0.00, I2 = 22.4%), sertraline (8 trials, standardized mean difference −0.25, 95% CI −0.42 to −0.07, I2 =46.3%), tiagabine (1 trial, standardized mean difference −0.02, 95% CI −0.28 to 0.24), topiramate (3 trials, standardized mean difference −0.96, 95% CI −1.89 to −0.03, I2 = 84.9%), and venlafaxine (2 trials, standardized mean difference −0.28, 95% CI −0.43 to −0.13).

### Network Meta-Analysis of Pharmacotherapy Trials

Figure F-122 Change in CAPS total score

Figure F-122 is titled “Change in CAPS total score”. The figure displays a forest plot reporting the weighted mean difference in CAPS total score stratified by head to head comparisons of pharmacotherapies. This figure is described further in the “Network Meta-Analysis of Pharmacotherapy Trials” section as follows: “Our network meta-analysis found paroxetine and topiramate to be statistically significantly more effective for reducing PTSD symptoms than most other medications included in the analysis. When compared with other medications with moderate strength of evidence of efficacy for improving PTSD symptoms (based on our findings in previous sections of this Key Question), paroxetine was more effective than sertraline (weighted mean difference −7.6, 95% CI −12 to −2.8), but was not statistically significantly different from fluoxetine, topiramate, or venlafaxine. When compared with other medications with moderate strength of evidence of efficacy, topiramate was more effective than fluoxetine (weighted mean difference 8.6, 95% CI 2.4 to 14.9), sertraline (weighted mean difference 11, 95% CI 5.7 to 16.6), and venlafaxine (weighted mean difference −8.8, 95% CI −15 to −2.5), but was not statistically significantly different from paroxetine.

Figure F-123 Change in CAPS total score: Sensitivity analysis

Figure F-123 is titled “Change in CAPS total score: Sensitivity analysis”. The figure displays a forest plot reporting the weighted mean difference in CAPS total score stratified by head to head comparisons of pharmacotherapies, with the inclusion of high risk of bias studies. The addition of high risk of bias trials to this sensitivity analysis did not significantly change the results from those reported in Figure F-120.

## Key Question 5

### CBT Exposure-Based Therapy: Meta-Analysis Results

Figure F-124 PTSD symptom reduction for exposure compared with control, by trauma population

Timing of outcome assessment: 1 session (Basoglu, 2007), 8 to 15 sessions (Asukai, 2010), 12 weeks (Foa, 2005), 9 weeks (Foa, 1999), 6 weeks (Resick, 2002), 4.5 weeks (Rothbaum), 9 to 15 weeks (Nacasch, 2011).

Figure F-124 is titled “PTSD symptom reduction for exposure compared with control, by trauma population”. The figure displays a forest plot reporting the standardized mean difference in PTSD symptoms stratified by other type of trauma, sexual abuse/assault, and combat. Results from the overall analysis found similar benefits of exposure-based therapy for victims of different trauma types (standardized mean difference −1.27, 95% CI −1.54 to −1.00, I2 = 23.3%).

Figure F-125 PTSD symptom reduction for exposure compared with control, by trauma population: Sensitivity analysis including other comparators

Note: Schnurr et al., 2007 was rated as high risk of bias.

Timing of outcome assessment: 1 session (Basoglu, 2007), 8 to 15 sessions (Asukai, 2010), 10 weeks (Schnurr, 2007), 12 weeks (Foa, 2005), 9 weeks (Foa, 1999), 6 weeks (Resick, 2002), 4.5 weeks (Rothbaum), 9 to 15 weeks (Nacasch, 2011).

Figure F-125 is titled “PTSD symptom reduction for exposure compared with control, by trauma population: Sensitivity analysis including other comparators”. The figure displays a forest plot reporting the standardized mean difference in PTSD symptoms stratified by other type of trauma, sexual abuse/assault, and combat, including other comparators. The addition of other comparators to this sensitivity analysis elicited results (standardized mean difference −1.17, 95% CI −1.63 to −0.71, I2 = 83.3%) similar to those reported in Figure F-122.

Figure F-126 PTSD symptom reduction for exposure compared with control, by trauma population: Sensitivity analysis including other comparators and studies with high risk of bias

Note: Ready et al., 2010, Difede et al., 2007, Johnson et al., 2006, and Foa et al., 1991 were rated as high risk of bias.

Timing of outcome assessment: 1 session (Basoglu, 2007), 24 weeks (Difede, 2007), mean number of sessions for PE = 9.66 (Johnson, 2006), 8 to 15 sessions (Asukai, 2010), 10 sessions (Ready, 2010), 10 weeks (Schnurr, 2007), 12 weeks (Foa, 2005), 9 weeks (Foa, 1999), 9 weeks (Foa, 1991), 6 weeks (Resick, 2002), 4.5 weeks (Rothbaum), 9 to 15 weeks (Nacasch, 2011).

Figure F-126 is titled “PTSD symptom reduction for exposure compared with control, by trauma population: Sensitivity analysis including other comparators and studies with high risk of bias”. The figure displays a forest plot reporting the standardized mean difference in PTSD symptoms stratified by other type of trauma, sexual abuse/assault, and combat including high risk of bias studies. The addition of other comparators and high risk of bias trials to this sensitivity analysis elicited results (13 trials, standardized mean difference −1.09, 95% CI −1.43 to −0.75, I2 = 73.7%) similar to those reported in Figures F-122 and F-123.

### EMDR: Meta-Analysis Results

Figure F-127 PTSD symptom reduction for EMDR compared with control, by trauma population

Timing of outcome assessment: 4 months (Hogberg, 2007), 6 weeks (Carlson, 1988), 4.5 weeks (Rothbaum, 2005), 4 weeks (Rothbaum).

Figure F-127 is titled “PTSD symptom reduction for EMDR compared with control, by trauma population”. The figure displays a forest plot reporting the standardized mean difference in PTSD symptoms stratified by other type of trauma and sexual abuse. Results from the overall analysis found similar benefits of exposure-based therapy for victims of other types of trauma and sexual abuse (4 trials, standardized mean difference −1.08, 95% CI −1.83 to −0.33, I2 = 70.0%).

Figure F-128 PTSD symptom reduction for EMDR compared with control, by trauma population: Sensitivity analysis including other comparators

Timing of outcome assessment: 8 weeks (van der Kolk, 2007), 4 months (Hogberg, 2007), 6 weeks (Carlson, 1988), 4.5 weeks (Rothbaum, 2005), 4 weeks (Rothbaum).

Figure F-128 is titled “PTSD symptom reduction for EMDR compared with control, by trauma population: Sensitivity analysis including other comparators”. The figure displays a forest plot reporting the standardized mean difference in PTSD symptoms stratified by other types of trauma and sexual abuse. Results from the overall analysis found similar benefits of exposure-based therapy for victims of other types of trauma and sexual abuse (5 trials, standardized mean difference −0.92, 95% CI −1.55 to −0.29, I2 = 71.8%).

Figure F-129 PTSD symptom reduction for EMDR compared with control, by trauma population: Sensitivity analysis including other comparators and studies with high risk of bias

Note: Johnson et al., 2006, Power et al., 2002 and Marcus et al., 1997 were rated as high risk of bias.

Timing of outcome assessment: 8 weeks (van der Kolk, 2007), 4 months (Hogberg, 2007), mean number of sessions = 6.33 (Johnson, 2006), 10 weeks (Power, 2002), 6 weeks (Carlson, 1988), variable number of sessions (Marcus, 1997), 4.5 weeks (Rothbaum, 2005), 4 weeks (Rothbaum).

Figure F-129 is titled “PTSD symptom reduction for EMDR compared with control, by trauma population: Sensitivity analysis including other comparators and studies with high risk of bias”. The figure displays a forest plot reporting the standardized mean difference in PTSD symptoms stratified by other types of trauma and sexual abuse. The addition of other comparators and high risk of bias trials to this sensitivity analysis found benefits of exposure-based therapy for victims of other types of trauma and sexual abuse (8 trials, standardized mean difference −1.13, 95% CI −1.62 to −0.64, I2 = 76.6%) that were similar to those reported in Figures F-125 and F-126.

### CBT-Mixed Therapy: Meta-Analysis Results

Figure F-130 PTSD symptom reduction for CBT-mixed compared with an inactive control

Timing of outcome assessment: 7 weeks (Johnson, 2011), 12 weeks (Foa, 2005), 9 weeks (Foa 1999), 4.5 months (Kubany, 2003), 8 to 12 weeks (Blanchard, 2003), 4 weeks (Fecteau, 1999), 12 weeks (Cloitre, 2002), 14 weeks (McDonagh, 2005), 12 weeks (Hollifield, 2007), 8 weeks (Spence, 2011), 5 sessions (van Emmerik, 2008), 12 weeks (Hinton, 2005), 4.8 months (Liedl, 2011), 4 to 5.5 weeks (Kubany, 2004).

Figure F-130 is titled “PTSD symptom reduction for CBT-mixed compared with an inactive control”. The figure displays a forest plot reporting the standardized mean difference in PTSD symptoms stratified by female violence/assault, MVA, CSA/CPA, mixed trauma, refugee, and interpersonal violence. Results from the overall analysis found similar benefits of CBT-mixed for patients across trauma types (14 trials, standardized mean difference −1.09, 95% CI −1.40 to −0.78, I2 = 75.3%).

Figure F-131 PTSD symptom reduction for CBT-mixed compared with an inactive control: Sensitivity analysis including other comparators

Timing of outcome assessment: 7 weeks (Johnson, 2011), 12 weeks (Foa, 2005), 9 weeks (Foa 1999), 4.5 months (Kubany, 2003), 8 to 12 weeks (Blanchard, 2003), 4 weeks (Fecteau, 1999), 12 weeks (Cloitre, 2002), 14 weeks (McDonagh, 2005), 12 weeks (Hollifield, 2007), 8 weeks (Spence, 2011), 5 sessions (van Emmerik, 2008), 16 weeks (Cottraux, 2008), 12 weeks (Hinton, 2005), 4.8 months (Liedl, 2011), 4 to 5.5 weeks (Kubany, 2004), 8 weeks (Litz, 2007).

Figure F-131 is titled “PTSD symptom reduction for CBT-mixed compared with an inactive control: Sensitivity analysis including other comparators”. The figure displays a forest plot reporting the standardized mean difference in PTSD symptoms stratified by female violence/assault, MVA, CSA/CPA, mixed trauma, refugee, interpersonal violence, and combat. The addition of other comparators to this sensitivity analysis found benefits of CBT-mixed for patients across trauma types (16 trials, standardized mean difference −0.98, 95% CI −1.28 to −0.68, I2 = 77.3%) that were similar to those reported in Figure F-128.

Figure F-132 PTSD symptom reduction for CBT-mixed compared with an inactive control: Sensitivity analysis including other comparators and studies with a high risk of bias

Note: Power et al., 2002, Beck et al, 2009, and Difede et al., 2007 were rated as high risk of bias.

Timing of outcome assessment: 12 weeks (Difede, 2007), 7 weeks (Johnson, 2011), 12 weeks (Foa, 2005), 9 weeks (Foa 1999), 4.5 months (Kubany, 2003), 14 weeks (Beck, 2009), 8 to 12 weeks (Blanchard, 2003), 4 weeks (Fecteau, 1999), 12 weeks (Cloitre, 2002), 14 weeks (McDonagh, 2005), 12 weeks (Hollifield, 2007), 10 weeks (Power, 2002), 8 weeks (Spence, 2011), 5 sessions (van Emmerik, 2008), 16 weeks (Cottraux, 2008), 12 weeks (Hinton, 2005), 4.8 months (Liedl, 2011), 4 to 5.5 weeks (Kubany, 2004), 8 weeks (Litz, 2007).

Figure F-132 is titled “PTSD symptom reduction for CBT-mixed compared with an inactive control: Sensitivity analysis including other comparators”. The figure displays a forest plot reporting the standardized mean difference in PTSD symptoms stratified by disaster workers, female violence/assault, MVA, CSA/CPA, mixed trauma, refugee, interpersonal violence, and combat. The addition of other comparators and high risk of bias trials to this sensitivity analysis found benefits of CBT-mixed for patients across trauma types (19 trials, standardized mean difference −0.96, 95% CI −1.22 to −0.70, I2 = 73.7%) that were similar to those reported in Figures F-128 and F-129.

### SSRIs: Meta-Analysis Results

Figure F-133 Change in CAPS for SSRIs compared with placebo, stratified by mixed and combat study population

Timing of outcome assessment: 10 weeks (Tucker, 2003; Zohar, 2002), 12 weeks (Martenyi, 2007; Marshall, 2001; Tucker, 2001; Davidson, 2006; Brady, 2005; Davidson, 2001; Brady, 2000; Martenyi 2002; Friedman, 2007); 8 weeks (van der Kolk, 2007), 5 weeks (van der Kolk, 1994).

Figure F-133 is titled “Change in CAPS for SSRIs compared with placebo, stratified by mixed and combat study population”. The figure displays a forest plot reporting the weighted mean difference in CAPS stratified by MVA and combat. Results from the overall analysis found similar benefits of SSRIs for both mixed and combat related trauma (16 trials, weighted mean difference −7.24, 95% CI −9.57 to −4.90, I2 = 40.9%).

Figure F-134 Change in CAPS for SSRIs compared with placebo, stratified by mixed and combat study population: Sensitivity analysis including studies with high risk of bias

Note: Marshall et al., 2007 was rated high risk of bias.

Timing of outcome assessment: 10 weeks (Tucker, 2003; Marshall, 2007; Zohar, 2002), 12 weeks (Martenyi, 2007; Marshall, 2001; Tucker, 2001; Davidson, 2006; Brady, 2005; Davidson, 2001; Brady, 2000; Martenyi 2002; Friedman, 2007); 8 weeks (van der Kolk, 2007), 5 weeks (van der Kolk, 1994).

Figure F-134 is titled “Change in CAPS for SSRIs compared with placebo, stratified by mixed and combat study population: Sensitivity analysis including studies with high risk of bias”. The figure displays a forest plot reporting the weighted mean difference in CAPS stratified by MVA and combat including studies rated as high risk of bias. Results of the overall analysis found similar benefits of SSRIs with both mixed and combat related trauma (17 trials, weighted mean difference −7.24, 95% CI −9.51 to −4.98, I2 = 37.0%).

Figure F-135 Change in CAPS for SSRIs compared with placebo – mixed trauma population

Timing of outcome assessment: 10 weeks (Tucker, 2003), 12 weeks (Martenyi, 2007; Marshall, 2001; Tucker, 2001; Davidson, 2006; Brady, 2005; Davidson, 2001; Brady, 2000); 8 weeks (van der Kolk, 2007).

Figure F-135 is titled “Change in CAPS for SSRIs Compared with Placebo – Mixed Trauma Population.” The figure displays a forest plot reporting the weighted mean difference in CAPS stratified by citalopram compared with placebo, fluoxetine compared with placebo, paroxetine compared with placebo, and sertraline compared with placebo. Patients treated with citalopram did not significantly improve over those treated with placebo (1 trial, weighted mean difference 7.98, 95% CI −10.07 to 26.03). SSRIs that had greater reductions in CAPS than placebo included fluoxetine (3 trials, weighted mean difference −5.89, 95% CI −10.14 to −1.64, I2 = 0.0%), paroxetine (3 trials, weighted mean difference −12.61, 95% CI −15.71 to −9.51, I2 = 0.0%), and sertraline (5 trials, weighted mean difference −5.83, 95% CI −9.31 to −2.35, I2 0.0%). The overall analysis favored SSRIs (weighted mean difference −7.99, 95% CI −10.63 to −5.34, I2 = 35.9%).

Figure F-136 Change in CAPS for SSRIs compared with placebo – mixed trauma population: Sensitivity analysis including studies with high risk of bias

Note: Marshall et al., 2007 was rated high risk of bias.

Timing of outcome assessment: 10 weeks (Tucker, 2003; Marshall, 2007), 12 weeks (Martenyi, 2007; Marshall, 2001; Tucker, 2001; Davidson, 2006; Brady, 2005; Davidson, 2001; Brady, 2000); 8 weeks (van der Kolk, 2007).

Figure F-136 is titled “Change in CAPS for SSRIs Compared with Placebo – Mixed Trauma Population: Sensitivity analysis including studies with high risk of bias.” The figure displays a forest plot reporting the weighted mean difference in CAPS stratified by citalopram compared with placebo, fluoxetine compared with placebo, paroxetine compared with placebo, and sertraline compared with placebo. Patients treated with citalopram did not significantly improve over those treated with placebo (1 trial, weighted mean difference 7.98, 95% CI −10.07 to 26.03). SSRIs that had greater reductions in CAPS than placebo included fluoxetine (3 trials, weighted mean difference −5.89, 95% CI −10.04 to −1.64, I2 = 0.0%), paroxetine (4 trials, weighted mean difference −12.41, 95% CI −15.47 to −9.36, I2 = 0.0%), and sertraline 5 trials, (weighted mean difference −5.83, 95% CI −9.31 to −2.35, I2 = 0.0%). The overall analysis including high risk of bias studies continued to favor SSRIs (weighted mean difference −8.01, 95% CI −10.55 to −5.48, I2 = 30.4%).

Figure F-137 Change in CAPS for SSRIs compared with placebo – combat trauma population

Timing of outcome assessment: 12 weeks (Martenyi, 2002; Friedman, 2007), 5 weeks (van der Kolk, 1994), 10 weeks (Zohar, 2002).

Figure F-137 is titled “Change in CAPS for SSRIs Compared with Placebo – Combat trauma population.” The figure displays a forest plot reporting the weighted mean difference in CAPS stratified by fluoxetine compared with placebo and sertraline compared with placebo. Patients treated with fluoxetine had greater reductions in CAPS than those treated with placebo (2 trials, weighted mean difference −9.09, 95% CI −15.03 to −3.14, I2 0.0%). The findings from studies that examined sertraline compared to placebo were mixed with one trial favoring the SSRI and the other favoring placebo (2 trials, weighted mean difference −2.41, 95% CI −9.51 to 4.70, I2 = 59.4%). The overall analysis favored SSRIs (weighted mean difference −5.31, 95% CI −9.94 to −0.68, I2 = 41.8%).

## Key Question 6

### Withdrawals Due to Adverse Events: Meta-analysis Results

Figure F-138 Withdrawals due to adverse events for prazosin compared with placebo

Timing of outcome assessment: 20 weeks (Raskind, 2003), 8 weeks (Raskind, 2007).

Figure F-138 is titled “Withdrawals due to adverse events for prazosin compared with placebo.” The figure displays a forest plot reporting the risk difference of withdrawals due to adverse events, prazosin compared with placebo. The forest plot depicts that a higher rate of patients withdrew due to adverse events related to prazosin than placebo (2 trials, risk difference 0.08, 95% CI −0.10 to 0.26, I2 = 0.0%).

Figure F-139 Withdrawals due to adverse events for anticonvulsants compared with placebo

Timing of outcome assessment: 8 weeks (Davis, 2008), 12 weeks (Davidson, 2007; Yeh, 2011; Tucker, 2007; Akuchekian, 2004).

Figure F-139 is titled “Withdrawals due to adverse events for anticonvulsants compared with placebo.” The figure displays a forest plot reporting the risk difference of withdrawals due to adverse events, stratified by divalproex compared with placebo, tiagabine compared with placebo, and topiramate compared with placebo. The forest plot depicts that a higher rate of patients withdrew due to adverse events related to anticonvulsants than placebo (5 trials, risk difference 0.02, 95% CI −0.03 to 0.06, I2 = 0.0%).

Figure F-140 Withdrawals due to adverse events for anticonvulsants compared with placebo: Sensitivity analysis including studies with high risk of bias

Note: Hammer et al., 2009 and Lindley et al., 2007 were rated as high risk of bias.

Timing of outcome assessment: 10 weeks (Hamner, 2009), 8 weeks (Davis, 2008), 12 weeks (Davidson, 2007; Yeh, 2011; Tucker, 2007; Akuchekian, 2004, 7 weeks (Lindley, 2007).

Figure F-140 is titled “Withdrawals due to adverse events for anticonvulsants compared with placebo: Sensitivity analysis including studies with high risk of bias.” The figure displays a forest plot reporting the risk difference of withdrawals due to adverse events, stratified by divalproex compared with placebo, tiagabine compared with placebo, and topiramate compared with placebo. The forest plot depicts that a higher rate of patients withdrew due to adverse events related to anticonvulsants than placebo (7 trials, risk difference 0.03, 95% CI −0.02 to 0.07, I2 = 4.8%).

Figure F-141 Withdrawals due to adverse events for antipsychotics compared with placebo

Timing of outcome assessment: 8 weeks (Stein, 2002; Reich, 2005), 24 weeks (Krystal, 2011), 16 weeks (Bartzokis, 2005), 5 weeks (Hamner, 2003), 6 weeks (Monnelly, 2003).

Figure F-141 is titled “Withdrawals due to adverse events for antipsychotics compared with placebo.” The figure displays a forest plot reporting the risk difference of withdrawals due to adverse events, stratified by olanzapine compared with placebo and risperidone compared with placebo. The forest plot depicts that a higher rate of patients withdrew due to adverse events related to olanzapine than placebo (1 trial, risk difference 0.08, 95% CI −0.32 to 0.47) and similar rates when comparing risperidone and placebo (5 trials, risk difference 0.00, 95% CI −0.02 to 0.02, I2 =0.0%). No significant differences in withdrawals rates were found between antipsychotics and placebo overall (risk difference 0.00, 95% CI −0.02 to 0.02, I2 = 0.0%).

Figure F-142 Withdrawals due to adverse events for antipsychotics compared with placebo: Sensitivity analysis including studies with high risk of bias

Note: Rothbaum et al., 2008 and Padala et al., 2006 were rated as high risk of bias.

Timing of outcome assessment: 8 weeks (Stein, 2002; Reich, 2005), 24 weeks (Krystal, 2011), 16 weeks (Rothbaum, 2008; Bartzokis, 2005), 5 weeks (Hamner, 2003), 6 weeks (Monnelly, 2003), 12 weeks (Padala, 2006).

Figure F-142 is titled “Withdrawals due to adverse events for antipsychotics compared with placebo: Sensitivity analysis including studies with high risk of bias.” The figure displays a forest plot reporting the risk difference of withdrawals due to adverse events, stratified by olanzapine compared with placebo and risperidone compared with placebo. The forest plot depicts that a higher rate of patients withdrew due to adverse events related to olanzapine (1 trial, risk difference 0.08, 95% CI −0.32 to 0.47) and risperidone (7 trials, risk difference 0.01, 95% CI −0.02 to 0.05, I2 =9.4%) when high risk of bias studies were included. No significant differences in withdrawals rates were found between antipsychotics and placebo overall (risk difference 0.00, 95% CI −0.01 to 0.02, I2 = 0.0%).

Figure F-143 Withdrawals due to adverse events for SSRIs compared with placebo

Timing of outcome assessment: 10 weeks (Simon, 2008; Panahi, 2011, Zohar, 2002), 12 weeks (Connor, 1999; Martenyi, 2007; Martenyi 2002; Marshall, 2001; Tucker, 2001; Davidson, 2006; Brady, 2005; Davidson, 2001; Brady, 2000; Friedman, 2007); 8 weeks (van der Kolk, 2007), 5 weeks (van der Kolk, 1994).

Figure F-143 is titled “Withdrawals due to adverse events for SSRIs compared with placebo.” The figure displays a forest plot reporting the risk difference of withdrawals due to adverse events, stratified by fluoxetine compared with placebo, paroxetine compared with placebo, and sertraline compared with placebo. The forest plot depicts that a higher rate of patients withdrew due to adverse events related to placebo than fluoxetine (4 trials, risk difference −0.01, 95% CI −0.04 to 0.03, I2 = 4.3%). Higher rates of patients withdrew due to adverse events related to paroxetine (4 trials, risk difference 0.04, 95% CI 0.00 to 0.07, I2 =0.0%) and sertraline (7 trials, risk difference 0.01, 95% CI −0.01 to 0.04, I2 =0.0%) than placebo. Overall there were higher rates of withdrawals due to SSRIs compared to placebo (risk difference 0.01, 95% CI −0.00 to 0.03, I2 = 0.0%).

Figure F-144 Withdrawals due to adverse events for SSRIs compared with placebo: Sensitivity analysis including studies with high risk of bias

Note: Hertzberg et al., 2007, and Marshal et al., 2007 were rated as high risk of bias.

Timing of outcome assessment: 10 weeks (Marshall, 2007; Simon, 2008; Panahi, 2011, Zohar, 2002), 12 weeks (Connor, 1999; Hertzberg, 2000; Martenyi, 2007; Martenyi 2002; Marshall, 2001; Tucker, 2001; Davidson, 2006; Brady, 2005; Davidson, 2001; Brady, 2000; Friedman, 2007); 8 weeks (van der Kolk, 2007), 5 weeks (van der Kolk, 1994).

Figure F-144 is titled “Withdrawals due to adverse events for SSRIs compared with placebo: Sensitivity analysis including studies with high risk of bias.” The figure displays a forest plot reporting the risk difference of withdrawals due to adverse events, stratified by fluoxetine compared with placebo, paroxetine compared with placebo, and sertraline compared with placebo. The forest plot depicts that a higher rate of patients withdrew due to adverse events related to placebo than fluoxetine (5 trials, risk difference −0.00, 95% CI −0.04 to 0.03, I2 = 0.3%). Higher rates of patients withdrew due to adverse events related to paroxetine (5 trials, risk difference 0.03, 95% CI −0.00 to 0.06, I2 =0.0%) and sertraline (7 trials, risk difference 0.01, 95% CI −0.01 to 0.04, I2 =0.0%) than placebo. Overall there were higher rates of withdrawals due to SSRIs compared to placebo (risk difference 0.01, 95% CI −0.00 to 0.03, I2 = 0.0%).

Figure F-145 Withdrawals due to adverse events for venlafaxine compared with placebo

Timing of outcome assessment: 12 weeks (Davidson, 2006b), 24 weeks (Davidson, 2006a).

Figure F-145 is titled “Withdrawals due to adverse events for venlafaxine compared with placebo.” The figure displays a forest plot reporting the risk difference of withdrawals due to adverse events, venlafaxine compared with placebo. The forest plot depicts that a higher rate of patients withdrew due to adverse events related to venlafaxine than placebo (2 trials, risk difference 0.02, 95% CI −0.03 to 0.07, I2 = 28.7%).

Figure F-146 Withdrawals due to adverse events for other SGAs compared with placebo: Sensitivity analysis including studies with high risk of bias

Note: Davis et al, 2004 was rated high risk of bias.

Timing of outcome assessment: 8 weeks (Davidson, 2003), 12 weeks (Davis, 2004).

Figure F-146 is titled “Withdrawals due to adverse events for other SGAs compared with placebo: Sensitivity analysis including studies with high risk of bias.” The figure displays a forest plot reporting the risk difference of withdrawals due to adverse events stratified by mirtazapine compared with placebo and nefazodone compared with placebo. The forest plot depicts that a higher rate of patients withdrew due to adverse events related to nefazodone than placebo (1 trial, risk difference 0.12, 95% CI −0.07 to 0.31and that a higher rate of patients withdrew due to adverse related to placebo than mirtazapine (1 trial, risk difference −0.16, 95% CI −0.51 to 0.20). Overall there were higher rates of withdrawals due to other SGAs compared to placebo (risk difference 0.02, 95% CI −0.23 to 0.28, I2 = 43.3%)

### Adverse Events - Venlafaxine: Meta-analysis Results

Figure F-147 Rate of headache for venlafaxine compared with placebo

Timing of outcome assessment: 12 weeks (Davidson, 2006a), 24 weeks (Davidson, 2006b).

Figure F-147 is titled “Rate of headache for venlafaxine compared with placebo.” The figure displays a forest plot reporting the risk difference of headaches, venlafaxine compared with placebo. The forest plot depicts that a higher rate of headache occurred among patients treated with venlafaxine than placebo (2 trials, risk difference 0.01, 95% CI −0.06 to 0.07, I2 = 0.0%).

Figure F-148 Rate of nausea for venlafaxine compared with placebo

Timing of outcome assessment: 12 weeks (Davidson, 2006a), 24 weeks (Davidson, 2006b).

Figure F-148 is titled “Rate of nausea for venlafaxine compared with placebo.” The figure displays a forest plot reporting the risk difference of nausea, venlafaxine compared with placebo. The forest plot depicts that a higher rate of nausea occurred among patients treated with venlafaxine than placebo (2 trials, risk difference 0.10, 95% CI 0.05 to 0.16, I2 = 0.0%).

Figure F-149 Rate of insomnia for venlafaxine compared with placebo

Timing of outcome assessment: 12 weeks (Davidson, 2006a), 24 weeks (Davidson, 2006b).

Figure F-149 is titled “Rate of insomnia for venlafaxine compared with placebo.” The figure displays a forest plot reporting the risk difference of insomnia, venlafaxine compared with placebo. The forest plot depicts that a higher rate of insomnia occurred among patients treated with venlafaxine than placebo (2 trials, risk difference 0.01, 95% CI −0.06 to 0.08, I2 = 59.3%).

Figure F-150 Rate of dry mouth for venlafaxine compared with placebo

Timing of outcome assessment: 12 weeks (Davidson, 2006a), 24 weeks (Davidson, 2006b).

Figure F-150 is titled “Rate of dry mouth for venlafaxine compared with placebo.” The figure displays a forest plot reporting the risk difference of dry mouth, venlafaxine compared with placebo. The forest plot depicts that a higher rate of dry occurred among patients treated with venlafaxine than placebo (2 trials, risk difference 0.07, 95% CI 0.02 to 0.11, I2 = 0.0%).

Figure F-151 Rate of diarrhea for venlafaxine compared with placebo

Timing of outcome assessment: 12 weeks.

Figure F-151 is titled “Rate of diarrhea for venlafaxine compared with placebo.” The figure displays a forest plot reporting the risk difference of diarrhea, venlafaxine compared with placebo. The forest plot depicts that a higher rate of diarrhea occurred among patients treated with placebo than venlafaxine (1 trial, risk difference −0.02, 95% CI −0.09 to 0.05

Figure F-152 Rate of dizziness for venlafaxine compared with placebo

Timing of outcome assessment: 12 weeks (Davidson, 2006a), 24 weeks (Davidson, 2006b).

Figure F-152 is titled “Rate of dizziness for venlafaxine compared with placebo.” The figure displays a forest plot reporting the risk difference of dizziness, venlafaxine compared with placebo. The forest plot depicts that a higher rate of dizziness occurred among patients treated with venlafaxine than placebo (2 trials, risk difference 0.06, 95% CI 0.01 to 0.11, I2 = 0.0%).

Figure F-153 Rate of fatigue for venlafaxine compared with placebo

Timing of outcome assessment: 12 weeks (Davidson, 2006a), 24 weeks (Davidson, 2006b).

Figure F-153 is titled “Rate of fatigue for venlafaxine compared with placebo.” The figure displays a forest plot reporting the risk difference of fatigue, venlafaxine compared with placebo. The forest plot depicts that a higher rate of fatigue occurred among patients treated with venlafaxine than placebo (2 trials, risk difference 0.03, 95% CI −0.01 to 0.07, I2 = 0.0%).

Figure F-154 Rate of somnolence for venlafaxine compared with placebo

Timing of outcome assessment: 12 weeks (Davidson, 2006a), 24 weeks (Davidson, 2006b).

Figure F-154 is titled “Rate of somnolence for venlafaxine compared with placebo.” The figure displays a forest plot reporting the risk difference of somnolence, venlafaxine compared with placebo. The forest plot depicts no difference in the rate of somnolence when comparing patients treated with venlafaxine than placebo (2 trials, risk difference −0.00, 95% CI −0.04 to 0.04, I2 = 0.0%).

Figure F-155 Rate of decreased appetite for venlafaxine compared with placebo

Timing of outcome assessment: 12 weeks.

Figure F-155 is titled “Rate of decreased appetite for venlafaxine compared with placebo.” The figure displays a forest plot reporting the risk difference of decreased appetite, venlafaxine compared with placebo. The forest plot depicts that a higher rate of decreased appetite occurred among patients treated with venlafaxine than placebo (1 trial, risk difference 0.06, 95% CI −0.00 to 0.11).

Figure F-156 Rate of constipation for venlafaxine compared with placebo

Timing of outcome assessment: 12 weeks (Davidson, 2006a), 24 weeks (Davidson, 2006b).

Figure F-156 is titled “Rate of constipation for venlafaxine compared with placebo.” The figure displays a forest plot reporting the risk difference of constipation, venlafaxine compared with placebo. The forest plot depicts that a higher rate of constipation occurred among patients treated with venlafaxine than placebo (2 trials, risk difference 0.06, 95% CI −0.02 to 0.13, I2 = 68.0%).

### Adverse Events - SSRIs: Meta-analysis Results

Figure F-157 Rate of headache for SSRIs compared with placebo

Timing of outcome assessment: 10 weeks (Panahi, 2011, Zohar, 2002), 12 weeks (Martenyi, 2007; Martenyi 2006; Davidson, 2006; Davidson, 2001; Brady, 2000; Friedman, 2007), 5 weeks (van der Kolk, 1994).

Figure F-157 is titled “Rate of headache for SSRIs compared with placebo.” The figure displays a forest plot reporting the risk difference of headache stratified by fluoxetine compared with placebo and sertraline compared with placebo. The forest plot depicts that a higher rate of headaches occurred among patients treated with fluoxetine (4 trials, risk difference 0.03, 95% CI −0.04 to 0.09, I2 = 28.2%) and sertraline (6 trials, risk difference 0.03, 95% CI −0.03 to 0.08, I2 = 0.0%). Overall there was a 3% higher rate of headache related to SSRIs than placebo (risk difference 0.03, 95% CI −0.01 to 0.06, I2 = 1.7%).

Figure F-158 Rate of nausea for SSRIs compared with placebo

Timing of outcome assessment: 10 weeks (Panahi, 2001; Tucker, 2003; Zohar, 2002), 12 weeks (Martenyi, 2007; Martenyi 2006; Tucker, 2001; Davidson, 2006; Davidson, 2001; Brady, 2000; Friedman, 2007).

Figure F-158 is titled “Rate of nausea for SSRIs compared with placebo.” The figure displays a forest plot reporting the risk difference of nausea stratified by fluoxetine compared with placebo, paroxetine compared with placebo, and sertraline compared with placebo. The forest plot depicts that a higher rate of nausea occurred among patients treated with fluoxetine (3 trials, risk difference 0.05, 95% CI 0.00 to 0.09, I2 = 0.0%), paroxetine (1 trial, risk difference 0.11, 95% CI 0.04 to 0.18), and sertraline (7 trials, risk difference 0.09, 95% CI 0.04 to 0.13, I2 = 0.0%). Overall there was a 7% higher rate of nausea related to SSRIs than placebo (risk difference 0.07, 95% CI 0.05 to 0.10, I2 = 0.0%).

Figure F-159 Rate of insomnia for SSRIs compared with placebo

Timing of outcome assessment: 10 weeks (Panahi, 2001; Tucker, 2003), 12 weeks (Martenyi 2006; Davidson, 2006; Davidson, 2001; Brady, 2000; Friedman, 2007).

Figure F-159 is titled “Rate of insomnia for SSRIs compared with placebo.” The figure displays a forest plot reporting the risk difference of insomnia stratified by fluoxetine compared with placebo and sertraline compared with placebo. The forest plot depicts that a higher rate of insomnia occurred among patients treated with fluoxetine (1 trial, risk difference 0.03, 95% CI −0.06 to 0.11) and sertraline (6 trials, risk difference 0.05, 95% CI −0.02 to 0.11, I2 = 44.8%). Overall there was a 4% higher rate of insomnia related to SSRIs than placebo (risk difference 0.04, 95% CI −0.01 to 0.19, I2 = 34.4%).

Figure F-160 Rate of dry mouth for SSRIs compared with placebo

Timing of outcome assessment: 10 weeks (Panahi, 2001; Tucker, 2003; Zohar, 2002), 12 weeks (Davidson, 2006; Davidson, 2001; Brady, 2000).

Figure F-160 is titled “Rate of dry mouth for SSRIs compared with placebo.” The figure displays a forest plot reporting the risk difference of dry mouth stratified by paroxetine compared with placebo and sertraline compared with placebo. The forest plot depicts that a higher rate of dry mouth occurred among patients treated with paroxetine (1 trial, risk difference 0.10, 95% CI 0.04 to 0.16) and sertraline (5 trials, risk difference 0.03, 95% CI −0.01 to 0.07, I2 = 0.0%). Overall there was a 5% higher rate of dry mouth related to SSRIs than placebo (risk difference 0.05, 95% CI 0.02 to 0.09, I2 = 0.0%).

Figure F-161 Rate of diarrhea for SSRIs compared with placebo

Timing of outcome assessment: 5 weeks (van der Kolk, 1994); 10 weeks (Panahi, 2001), 12 weeks (Davidson, 2006; Davidson, 2001; Brady, 2000; Friedman, 2007).

Figure F-161 is titled “Rate of diarrhea for SSRIs compared with placebo.” The figure displays a forest plot reporting the risk difference of diarrhea stratified by fluoxetine compared with placebo and sertraline compared with placebo. The forest plot depicts that a higher rate of dry mouth occurred among patients treated with fluoxetine (1 trial, risk difference 0.24, 95% CI 0.01 to 0.47) and sertraline (5 trials, risk difference 0.12, 95% CI 0.07 to 0.17, I2 = 0.0%). Overall there was a 13% higher rate of diarrhea related to SSRIs than placebo (risk difference 0.13, 95% CI 0.08 to 0.17, I2 = 0.0%).

Figure F-162 Rate of dizziness for SSRIs compared with placebo

Timing of outcome assessment: 12 weeks (Davidson, 2006), 10 weeks (Tucker, 2003).

Figure F-162 is titled “Rate of dizziness for SSRIs compared with placebo.” The figure displays a forest plot reporting the risk difference of dizziness, sertraline compared with placebo. The forest plot depicts that a higher rate of dizziness occurred among patients treated with sertraline (2 trials, risk difference 0.04, 95% CI −0.02 to 0.10, I2=0.0%) than placebo.

Figure F-163 Rate of fatigue for SSRIs compared with placebo

Timing of outcome assessment: 12 weeks (Davidson, 2006; Davidson, 2001; Friedman, 2007), 10 weeks (Tucker, 2003).

Figure F-163 is titled “Rate of fatigue for SSRIs compared with placebo.” The figure displays a forest plot reporting the risk difference of fatigue, sertraline compared with placebo. The forest plot depicts that a higher rate of dizziness occurred among patients treated with sertraline (4 trials, risk difference 0.07, 95% CI 0.03 to 0.11, I2=0.0%) than placebo.

Figure F-164 Rate of somnolence for SSRIs compared with placebo

Timing of outcome assessment: 12 weeks for all included studies.

Figure F-164 is titled “Rate of somnolence for SSRIs compared with placebo.” The figure displays a forest plot reporting the risk difference of somnolence stratified by fluoxetine compared with placebo, paroxetine compared with placebo, and sertraline compared with placebo. The forest plot depicts that a higher rate of somnolence occurred among patients treated with fluoxetine (2 trials, risk difference 0.05, 95% CI 0.00 to 0.10, I2=0.0%) paroxetine (1 trial, risk difference 0.13, 95% CI 0.07 to 0.20), and sertraline (risk difference 0.01, 95% CI −0.08 to 0.09, I2 = 51.6%). Overall there was a 5% higher rate of somnolence related to SSRIs than placebo (risk difference 0.05, 95% CI −0.00 to 0.11, I2=67.1%).

Figure F-165 Rate of drowsiness for SSRIs compared with placebo

Timing of outcome assessment: 10 weeks (Simon, 2008; Panahi, 2011; Zohar, 2002), 12 weeks (Brady, 2000; Davidson, 2001).

Figure F-165 is titled “Rate of drowsiness for SSRIs compared with placebo.” The figure displays a forest plot reporting the risk difference of drowsiness for SSRIs compared with placebo stratified by paroxetine compared with placebo and sertraline compared with placebo. The forest plot depicts that a lower rate of drowsiness occurred among patients treated with paroxetine (1 trial, risk difference −0.15, 95% CI −0.51 to 0.21) compared with placebo and that a higher rate of drowsiness occurred in patients treated with sertraline (4 trials, risk difference 0.05, 95% CI −0.00 to 0.11, I2=0.0%) compared with placebo. Overall there was a 5% higher rate of drowsiness related to SSRIs than placebo (risk difference 0.05, 95% CI −0.01 to 0.11, I2=0.0%).

Figure F-166 Rate of decreased appetite for SSRIs compared with placebo

Timing of outcome assessment: 10 weeks (Panahi, 2011; Tucker, 2003; Zohar, 2002), 12 weeks (Davidson, 2006; Davidson, 2001).

Figure F-166 is titled “Rate of decreased appetite for SSRIs compared with placebo.” The figure displays a forest plot reporting the risk difference of decreased appetite for SSRIs compared with placebo, sertraline compared with placebo. The forest plot depicts that a higher rate of decreased appetite occurred among patients treated with sertraline (5 trials, risk difference 0.07, 95% CI 0.01 to 0.13, I2=43.7%) compared with placebo.

Figure F-167 Rate of increased appetite for SSRIs compared with placebo

Timing of outcome assessment: 10 weeks for all included studies.

Figure F-167 is titled “Rate of increased appetite for SSRIs compared with placebo.” The figure displays a forest plot reporting the risk difference of increased appetite for SSRIs compared with placebo, sertraline compared with placebo. The forest plot depicts no difference in rate of increased appetite among patients treated with sertraline (2 trials, risk difference −0.01, 95% CI −0.19 to 0.16, I2=0.0%) and patients treated with placebo.

Figure F-168 Rate of constipation for SSRIs compared with placebo

Timing of outcome assessment: 12 weeks (Davidson, 2006), 10 weeks (Panahi, 2011).

Figure F-168 is titled “Rate of constipation for SSRIs compared with placebo.” The figure displays a forest plot reporting the risk difference of constipation for SSRIs compared with placebo, sertraline compared with placebo. The forest plot depicts a higher rate of constipation among patients treated with sertraline (2 trials, risk difference 0.02, 95% CI −0.03 to 0.07, I2=0.0%) compared with placebo.

### Adverse Events - Topiramate: Meta-analysis Results

Figure F-169 Rate of headache for topiramate compared with placebo

Timing of outcome assessment: 12 weeks for all included studies.

Figure F-169 is titled “Rate of headache for topiramate compared with placebo.” The figure displays a forest plot reporting the risk difference of headache for topiramate compared with placebo. The forest plot depicts no difference in rate of headache among patients treated with topiramate (2 trials, risk difference −0.01, 95% CI −0.21 to 0.18, I2=12.9%) and patients treated with placebo.

Figure F-170 Rate of insomnia for topiramate compared with placebo

Timing of outcome assessment: 12 weeks for all included studies.

Figure F-170 is titled “Rate of insomnia topiramate compared with placebo.” The figure displays a forest plot reporting the risk difference of insomnia for topiramate compared with placebo, sertraline. The forest plot depicts a higher rate of insomnia among patients treated with topiramate (2 trials, risk difference 0.12, 95% CI −0.05 to 0.28, I2=0.0%) compared with placebo.

Figure F-171 Rate of somnolence for topiramate compared with placebo

Timing of outcome assessment: 12 weeks.

Figure F-171 is titled “Rate of somnolence for topiramate compared with placebo.” The figure displays a forest plot reporting the risk difference of somnolence for topiramate compared with placebo. The forest plot depicts a lower rate of somnolence among patients treated with topiramate (1 trial, risk difference −0.10, 95% CI −0.39 to 0.20) compared with placebo.

Figure F-172 Rate of reported taste perversion for topiramate compared with placebo

Timing of outcome assessment: 12 weeks.

Figure F-172 is titled “Rate of reported taste perversion for topiramate compared with placebo.” The figure displays a forest plot reporting the risk difference of reported taste perversion for topiramate compared with placebo. The forest plot depicts a higher rate of reported taste perversion among patients treated with topiramate (1 trial, risk difference 0.25, 95% CI 0.04 to 0.46) compared with placebo.

Figure F-173 Rate of dyspepsia for topiramate compared with placebo

Figure F-173 is titled “Rate of dyspepsia for topiramate compared with placebo.” The figure displays a forest plot reporting the risk difference of dyspepsia for topiramate compared with placebo. The forest plot depicts a higher rate of dyspepsia among patients treated with topiramate (1 trial, risk difference 0.10, 95% CI −0.12 to 0.32) compared with placebo.

Figure F-174 Rate of paresthesia for topiramate compared with placebo

Timing of outcome assessment: 12 weeks.

Figure F-174 is titled “Rate of paresthesia for topiramate compared with placebo.” The figure displays a forest plot reporting the risk difference of paresthesia for topiramate compared with placebo. The forest plot depicts a higher rate of paresthesia among patients treated with topiramate (1 trial, risk difference 0.15, 95% CI −0.05 to 0.35) compared with placebo.

Figure F-175 Rate of nervousness for topiramate compared with placebo

Timing of outcome assessment: 12 weeks.

Figure F-175 is titled “Rate of nervousness for topiramate compared with placebo.” The figure displays a forest plot reporting the risk difference of nervousness for topiramate compared with placebo. The forest plot depicts a higher rate of nervousness among patients treated with topiramate (1 trial, risk difference 0.15, 95% CI −0.05 to 0.35) compared with placebo.

Figure F-176 Rate of fatigue for topiramate compared with placebo

Timing of outcome assessment: 12 weeks.

Figure F-176 is titled “Rate of fatigue for topiramate compared with placebo.” The figure displays a forest plot reporting the risk difference of fatigue for topiramate compared with placebo. The forest plot depicts a higher rate of fatigue among patients treated with topiramate (1 trial, risk difference 0.20, 95% CI 0.00 to 0.40) compared with placebo.