# Search Strategy

MEDLINE®

Search | Most Recent Queries | Result
#1 | Search “Stress Disorders, Post-Traumatic”[Mesh] | 16684
#2 | Search “post-traumatic stress disorder”[All Fields] | 4090
#3 | Search “post-traumatic stress disorders”[All Fields] | 16739
#4 | Search disorder* AND “post-traumatic”[tiab] | 5983
#5 | Search “Stress Disorders, Traumatic”[Mesh:NOEXP] | 335
#6 | Search “Combat Disorders”[Mesh] | 2154
#7 | Search “PTSD” | 9226
#8 | Search #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 | 21449
#9 | Search #8 Limits: Humans, English, All Adult: 19+ years, Young Adult: 19–24 years, Adult: 19–44 years, Middle Aged: 45–64 years, Middle Aged + Aged: 45+ years, Aged: 65+ years, 80 and over: 80+ years, Publication Date from 1980/01/01 to 2011/10/01 | 10509
#10 | Search “implosive therapy”[MeSH Terms] OR “implosive therapy”[All Fields] OR (“exposure”[tiab] AND (“therapy”[tiab] OR “psychotherapy”[tiab])) OR “imaginal exposure” | 22902
#11 | Search “cognitive therapy”[MeSH] OR cognitive restructur*[tiab] OR cognitive processing therap*[tiab] | 12055
#12 | Search “Adaptation, Psychological”[Mesh] OR coping skill*[tiab] | 88750
#13 | Search “stress inoculation” | 113
#14 | Search “assertiveness training” | 164
#15 | Search psychodynamic[All Fields] AND (“therapy”[Subheading] OR “therapy”[All Fields] OR “therapeutics”[MeSH Terms] OR “therapeutics”[All Fields]) | 2221
#16 | Search psychodynamic[All Fields] AND (“psychotherapy”[MeSH Terms] OR “psychotherapy”[All Fields]) | 2068
#17 | Search (“psychoanalytic”[All Fields] AND “psychotherapy”[All Fields]) OR “psychoanalytic psychotherapy”[All Fields] | 5012
#18 | Search (“psycho-analytic”[All Fields] AND “psychotherapy”[All Fields]) OR “psycho-analytic psychotherapy”[All Fields] | 14
#19 | Search “psychoanalytic therapy” | 13664
#20 | Search “psycho-analytic therapy” | 3
#21 | Search “Eye Movement Desensitization Reprocessing”[MeSH] OR “EMDR”[tiab] | 214
#22 | Search “Psychotherapy”[Mesh] | 134066
#23 | Search “interpersonal therapy” OR “interpersonal psychotherapy” | 626
#24 | Search “family therapy”[tiab] OR “marital therapy”[tiab] | 2591
#25 | Search “group therapy” OR “group psychotherapy” OR “group psychological therapy” | 12172
#26 | Search “Hypnosis”[Mesh] | 10183
#27 | Search #10 OR #11 OR #12 OR #13 OR #14 OR #15 OR #16 OR #17 OR #18 OR #19 OR #20 OR #21 OR #22 OR #23 OR #24 OR #25 OR #26 | 237601
#28 | Search #9 AND #27 | 2601
#29 | Search “Benzodiazepines”[Mesh] | 54507
#30 | Search “Antidepressive Agents, Tricyclic”[Pharmacological Action] | 28037
#31 | Search “Anticonvulsants”[Pharmacological Action] | 120174
#32 | Search “Adrenergic alpha-Antagonists”[Pharmacological Action] | 47582
#33 | Search “Antipsychotic Agents”[Pharmacological Action] | 114583
#34 | Search “Antidepressive Agents”[Pharmacological Action] | 109682
#35 | Search “citalopram” OR “escitalopram” OR “fluoxetine” OR “fluvoxamine” OR “paroxetine” OR “sertraline” OR “desvenlafaxine” OR “venlafaxine” OR “duloxetine” OR “imipramine” OR “amitriptyline” OR “desipramine” OR “bupropion” OR “mirtazapine” OR “nefazodone” OR “trazodone” OR “prazosin” OR “olanzapine” OR “risperidone” OR “benzodiazepines” [MeSH] OR “alprazolam” OR “diazepam” OR “lorazepam” OR “clonazepam” OR “topiramate” OR “tiagabine” OR “lamotrigine” OR “carbamazepine” OR “divalproex” | 136015
#36 | Search #29 OR #30 OR #31 OR #32 OR #33 OR #34 OR #35 | 400958
#37 | Search #9 AND #36 | 510
#38 | Search #28 OR #37 | 3023
#39 | Search “Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials as Topic”[Mesh] OR “Single-Blind Method”[Mesh] OR “Double-Blind Method”[Mesh] OR “Random Allocation”[Mesh] | 455950
#40 | Search “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields] | 50159
#41 | Search “Comparative Study”[Publication Type] OR “comparative study” OR case control stud* OR “Case-Control Studies”[Mesh] | 1978917
#42 | Search (“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH AND “systematic”[tiab]) | 42848
#43 | Search “Cohort Studies”[Mesh] OR “cohort effect”[MeSH Term] OR cohort*[tiab] | 1186051
#44 | Search “trial”[tiab] | 287417
#45 | Search “Treatment Outcome”[Mesh] | 500945
#46 | Search #38 AND (#39 OR #40 OR #41 OR #42 OR #43 OR #44 OR #45) | 1406

Cochrane

ID | Search | Hits
#1 | “Stress Disorders, Post-Traumatic”[Mesh] | 708
#2 | “post-traumatic stress disorder”[All Fields] | 357
#3 | “post-traumatic stress disorders”[All Fields] | 22
#4 | disorder* AND “post-traumatic”[tiab] | 987
#5 | “Stress Disorders, Traumatic”[Mesh:NOEXP] | 33
#6 | “Combat Disorders”[Mesh] | 58
#7 | “PTSD” | 826
#8 | (#1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7) | 1278
#9 | “Adult”[Mesh] | 266836
#10 | “Humans”[Mesh] | 412719
#11 | (#8 AND #9 AND #10), from 1980 to 2011 | 593
#12 | “implosive therapy”[MeSH Terms] OR “implosive therapy”[All Fields] OR (“exposure”[tiab] AND (“therapy”[tiab] OR “psychotherapy”[tiab])) OR “imaginal exposure” | 6045
#13 | “cognitive therapy”[MeSH] OR cognitive restructur*[tiab] OR cognitive processing therap*[tiab] | 6525
#14 | “Adaptation, Psychological”[Mesh] OR coping skill*[tiab] | 3207
#15 | “stress inoculation” | 109
#16 | “assertiveness training” | 82
#17 | psychodynamic[All Fields] AND (“therapy”[Subheading] OR “therapy”[All Fields] OR “therapeutics”[MeSH Terms] OR “therapeutics”[All Fields]) | 347
#18 | psychodynamic[All Fields] AND (“psychotherapy”[MeSH Terms] OR “psychotherapy”[All Fields]) | 318
#19 | (“psychoanalytic”[All Fields] AND “psychotherapy”[All Fields]) OR “psychoanalytic psychotherapy”[All Fields] | 181
#20 | (“psycho-analytic”[All Fields] AND “psychotherapy”[All Fields]) OR “psycho-analytic psychotherapy”[All Fields] | 0
#21 | “psychoanalytic therapy” | 138
#22 | “psycho-analytic therapy” | 0
#23 | “Eye Movement Desensitization Reprocessing”[MeSH] OR “EMDR”[tiab] | 87
#24 | “Psychotherapy”[Mesh] | 6282
#25 | “interpersonal therapy” OR “interpersonal psychotherapy” | 434
#26 | “family therapy”[tiab] OR “marital therapy”[tiab] | 1137
#27 | “group therapy” OR “group psychotherapy” OR “group psychological therapy” | 1269
#28 | “Hypnosis”[Mesh] | 939
#29 | (#12 OR #13 OR #14 OR #15 OR #16 OR #17 OR #18 OR #19 OR #20 OR #21 OR #22 OR #23 OR #24 OR #25 OR #26 OR #27 OR #28) | 20386
#30 | (#11 AND #29) | 308
#31 | “Benzodiazepines”[Mesh] | 2830
#32 | “Antidepressive Agents, Tricyclic”[Pharmacological Action] | 999
#33 | “Anticonvulsants”[Pharmacological Action] | 2055
#34 | “Adrenergic alpha-Antagonists”[Pharmacological Action] | 948
#35 | “Antipsychotic Agents”[Pharmacological Action] | 3254
#36 | “Antidepressive Agents”[Pharmacological Action] | 4378
#37 | “citalopram”[All Fields] OR “escitalopram”[All Fields] OR “fluoxetine”[All Fields] OR “fluvoxamine”[All Fields] OR “paroxetine”[All Fields] OR “sertraline”[All Fields] OR “desvenlafaxine”[All Fields] OR “venlafaxine”[All Fields] OR “duloxetine”[All Fields] OR “imipramine”[All Fields] OR “amitriptyline”[All Fields] OR “desipramine”[All Fields] OR “bupropion”[All Fields] OR “mirtazapine”[All Fields] OR “nefazodone”[All Fields] OR “trazodone”[All Fields] OR “prazosin”[All Fields] OR “olanzapine”[All Fields] OR “risperidone”[All Fields] OR “benzodiazepines”[MeSH] OR “alprazolam”[All Fields] OR “diazepam”[All Fields] OR “lorazepam”[All Fields] OR “clonazepam”[All Fields] OR “topiramate”[All Fields] OR “tiagabine”[All Fields] OR “lamotrigine”[All Fields] OR “carbamazepine”[All Fields] OR “divalproex”[All Fields] | 23631
#38 | (#31 OR #32 OR #33 OR #34 OR #35 OR #36 OR #37) | 28306
#39 | (#11 AND #38) | 107
#40 | (#30 OR #39) | 382

IPA, CINAHL, PsycINFO

# | Query | Results
S30 | S13 or S15 or S17 or S19 or S21 or S23 or S25 or S27 or S29 | 423
S29 | S11 and S28 | 30
S28 | DE “Best Practices” OR DE “Clinical Trials” OR DE “Evidence Based Practice” | 84889
S27 | S11 and S26 | 31
S26 | Cohort | 67610
S25 | S11 and S24 | 1
S24 | Case-Control | 32466
S23 | S11 and S22 | 16
S22 | Comparative | 151221
S21 | S11 and S20 | 155
S20 | review | 546021
S19 | S11 and S18 | 5
S18 | meta-analysis | 28744
S17 | S11 and S16 | 2
S16 | “Single Blind” | 7068
S15 | S11 and S14 | 73
S14 | “double blind” | 50926
S13 | S11 and S12 | 205
S12 | trial | 185981
S11 | S8 or S10 | 1433
S10 | S6 and S9 | 482
S9 | DE “Drug Therapy” | 94759
S8 | S6 and S7 | 1004
S7 | DE “Treatment” OR DE “Adjunctive Treatment” OR DE “Aftercare” OR DE “Alternative Medicine” OR DE “Behavior Modification” OR DE “Bibliotherapy” OR DE “Cognitive Techniques” OR DE “Computer Assisted Therapy” OR DE “Creative Arts Therapy” OR DE “Crisis Intervention Services” OR DE “Cross Cultural Treatment” OR DE “Disease Management” OR DE “Health Care Services” OR DE “Interdisciplinary Treatment Approach” OR DE “Involuntary Treatment” OR DE “Language Therapy” OR DE “Life Sustaining Treatment” OR DE “Medical Treatment (General)” OR DE “Milieu Therapy” OR DE “Movement Therapy” OR DE “Multimodal Treatment Approach” OR DE “Online Therapy” OR DE “Outpatient Treatment” OR DE “Pain Management” OR DE “Partial Hospitalization” OR DE “Personal Therapy” OR DE “Physical Treatment Methods” OR DE “Preventive Medicine” OR DE “Psychotherapeutic Techniques” OR DE “Psychotherapy” OR DE “Rehabilitation” OR DE “Relaxation Therapy” OR DE “Sex Therapy” OR DE “Social Casework” OR DE “Sociotherapy” OR DE “Speech Therapy” OR DE “Treatment Guidelines” | 214922
S6 | S5 Limiters - Published Date from: 19800101–20111031; Language: English; Articles about Human Studies; English Language; Exclude MEDLINE records; Human; Language: English; Age Groups: Adult: 19–44 years, Middle Aged: 45–64 years, Aged: 65+ years, Aged, 80 and over, All Adult; Publication Year from: 1980–2011; English; Language: English; Age Groups: Adulthood (18 yrs & older), Young Adulthood (18–29 yrs), Thirties (30–39 yrs), Middle Age (40–64 yrs), Aged (65 yrs & older), Very Old (85 yrs & older); Population Group: Human; Exclude Dissertations Search modes - Boolean/Phrase | 10945
S5 | S1 or S2 or S3 or S4 | 26246
S4 | “posttraumatic stress disorder” | 21566
S3 | “post-traumatic stress disorder” | 5973
S2 | PTSD | 18581
S1 | (DE “Posttraumatic Stress Disorder”) OR (DE “Combat Experience”) | 17649

Web of Science (ISI)

Set | Results | Query
# 1 | 11,499 | Topic=(PTSD) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 2 | 27,258 | Topic=(posttraumatic) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 3 | 12,587 | Topic=(“post trauma*”) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 4 | 38,773 | #3 OR #2 OR #1 Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 5 | 34,329 | (#4) AND Language=(English) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=1980–2011 Lemmatization=On
# 6 | 33,425 | Topic=(Psychotherapy) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=1980–2011 Lemmatization=On
# 7 | 14,558 | Topic=(pharmacotherapy) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=1980–2011 Lemmatization=On
# 8 | 46,463 | #7 OR #6 Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=1980–2011 Lemmatization=On
# 9 | 1,236 | #8 AND #5 Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=1980–2011 Lemmatization=On
# 10 | 1,164 | #8 AND #5 Refined by: Document Type=( ARTICLE OR REVIEW ) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=1980–2011 Lemmatization=On
# 11 | 772,785 | Topic=(child) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=1980–2011 Lemmatization=On
# 12 | 918 | (#10 NOT #11) AND Language=(English) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=1980–2011 Lemmatization=On

EMBASE

No. | Query | Results
#1 | ‘posttraumatic stress disorder’/exp | 25,872
#2 | ‘psychotherapy’/exp | 171,464
#3 | ‘drug therapy’/exp | 1,486,583
#4 | #2 OR #3 | 1,645,726
#5 | #1 AND #4 | 5,436
#6 | ‘randomized controlled trial’/exp OR ‘single blind procedure’/exp OR ‘double blind procedure’/exp OR ‘systematic review’/exp OR ‘cohort analysis’/exp OR ‘meta analysis’/exp OR ‘comparative study’/exp OR ‘case control study’/exp | 1,403,794
#7 | #5 AND #6 | 692
#8 | #7 AND (‘article’/it OR ‘review’/it) | 638
#9 | ‘human’/exp | 12,658,788
#10 | ‘adult’/exp OR ‘middle aged’/exp OR ‘aged’/exp | 4,693,068
#11 | #8 AND #9 AND #10 | 294

Total references identified by the main searches = 20649

Total references from main and handsearches, minus duplicates = 2609

The following update searches were conducted on May 24, 2012

MEDLINE®

Search | Most Recent Queries | Result
#1 | Search “Stress Disorders, Post-Traumatic”[Mesh] | 17659
#2 | Search “post-traumatic stress disorder”[All Fields] | 4402
#3 | Search “post-traumatic stress disorders”[All Fields] | 17716
#4 | Search disorder* AND “post-traumatic”[tiab] | 6442
#5 | Search “Stress Disorders, Traumatic”[Mesh:NOEXP] | 369
#6 | Search “Combat Disorders”[Mesh] | 2260
#7 | Search “PTSD” | 9934
#8 | Search #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 | 22798
#9 | Search #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 Filters: Humans | 20950
#10 | Search #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 Filters: Humans; English | 19014
#11 | Search #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 Filters: Humans; English; Adult: 19+ years | 11362
#12 | Search #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 Filters: Humans; English; Adult: 19+ years; Adult: 19–44 years | 11362
#13 | Search #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 Filters: Humans; English; Adult: 19+ years; Adult: 19–44 years; Aged: 65+ years | 11362
#14 | Search #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 Filters: Publication date from 2011/09/01 to 2012/12/31; Humans; English; Adult: 19+ years; Adult: 19–44 years; Aged: 65+ years | 412
#15 | Search “implosive therapy”[MeSH Terms] OR “implosive therapy”[All Fields] OR (“exposure”[tiab] AND (“therapy”[tiab] OR “psychotherapy”[tiab])) OR “imaginal exposure” | 24262
#16 | Search “cognitive therapy”[MeSH] OR cognitive restructur*[tiab] OR cognitive processing therap*[tiab] | 12901
#17 | Search “Adaptation, Psychological”[Mesh] OR coping skill*[tiab] | 91955
#18 | Search “stress inoculation” | 116
#19 | Search “assertiveness training” | 166
#20 | Search psychodynamic[All Fields] AND (“therapy”[Subheading] OR “therapy”[All Fields] OR “therapeutics”[MeSH Terms] OR “therapeutics”[All Fields]) | 2317
#21 | Search psychodynamic[All Fields] AND (“psychotherapy”[MeSH Terms] OR “psychotherapy”[All Fields]) | 2168
#22 | Search (“psychoanalytic”[All Fields] AND “psychotherapy”[All Fields]) OR “psychoanalytic psychotherapy”[All Fields] | 5088
#23 | Search (“psycho-analytic”[All Fields] AND “psychotherapy”[All Fields]) OR “psycho-analytic psychotherapy”[All Fields] | 15
#24 | Search “psychoanalytic therapy” | 13832
#25 | Search “psycho-analytic therapy” | 3
#26 | Search “Eye Movement Desensitization Reprocessing”[MeSH] OR “EMDR”[tiab] | 230
#27 | Search “Psychotherapy”[Mesh] | 137632
#28 | Search “interpersonal therapy” OR “interpersonal psychotherapy” | 684
#29 | Search “family therapy”[tiab] OR “marital therapy”[tiab] | 2676
#30 | Search “group therapy” OR “group psychotherapy” OR “group psychological therapy” | 12408
#31 | Search “Hypnosis”[Mesh] | 10301
#32 | Search #15 OR #16 OR #17 OR #18 OR #19 OR #20 OR #21 OR #22 OR #23 OR #24 OR #25 OR #26 OR #27 OR #28 OR #29 OR #30 OR #31 | 245448
#33 | Search #14 AND #32 | 77
#34 | Search “Benzodiazepines”[Mesh] | 55362
#35 | Search “Antidepressive Agents, Tricyclic”[Pharmacological Action] | 28334
#36 | Search “Anticonvulsants”[Pharmacological Action] | 122415
#37 | Search “Adrenergic alpha-Antagonists”[Pharmacological Action] | 47994
#38 | Search “Antipsychotic Agents”[Pharmacological Action] | 116441
#39 | Search “Antidepressive Agents”[Pharmacological Action] | 112131
#40 | Search “citalopram” OR “escitalopram” OR “fluoxetine” OR “fluvoxamine” OR “paroxetine” OR “sertraline” OR “desvenlafaxine” OR “venlafaxine” OR “duloxetine” OR “imipramine” OR “amitriptyline” OR “desipramine” OR “bupropion” OR “mirtazapine” OR “nefazodone” OR “trazodone” OR “prazosin” OR “olanzapine” OR “risperidone” OR “benzodiazepines” [MeSH] OR “alprazolam” OR “diazepam” OR “lorazepam” OR “clonazepam” OR “topiramate” OR “tiagabine” OR “lamotrigine” OR “carbamazepine” OR “divalproex” | 139350
#41 | Search #34 OR #35 OR #36 OR #37 OR #38 OR #39 OR #40 | 408702
#42 | Search #14 AND #41 | 8
#43 | Search #33 OR #42 | 82
#44 | Search “Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials as Topic”[Mesh] OR “Single-Blind Method”[Mesh] OR “Double-Blind Method”[Mesh] OR “Random Allocation”[Mesh] | 476623
#45 | Search “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields] | 55455
#46 | Search “Comparative Study”[Publication Type] OR “comparative study” OR case control stud* OR “Case-Control Studies”[Mesh] | 2043208
#47 | Search (“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH AND “systematic”[tiab]) | 48116
#48 | Search “Cohort Studies”[Mesh] OR “cohort effect”[MeSH Term] OR cohort*[tiab] | 1248320
#49 | Search “trial”[tiab] | 304105
#50 | Search “Treatment Outcome”[Mesh] | 535121
#51 | Search #43 AND (#44 OR #45 OR #46 OR #47 OR #48 OR #49 OR #50) | 40

Cochrane

ID | Search | Hits
#1 | “Stress Disorders, Post-Traumatic”[Mesh] | 791
#2 | “post-traumatic stress disorder”[All Fields] | 408
#3 | “post-traumatic stress disorders”[All Fields] | 29
#4 | disorder* AND “post-traumatic”[tiab] | 1153
#5 | “Stress Disorders, Traumatic”[Mesh:NOEXP] | 33
#6 | “Combat Disorders”[Mesh] | 66
#7 | “PTSD” | 912
#8 | (#1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7) | 1465
#9 | “Adult”[Mesh] | 279247
#10 | “Humans”[Mesh] | 433254
#11 | (#8 AND #9 AND #10), from 2011 to 2012 | 89
#12 | “implosive therapy”[MeSH Terms] OR “implosive therapy”[All Fields] OR (“exposure”[tiab] AND (“therapy”[tiab] OR “psychotherapy”[tiab])) OR “imaginal exposure” | 6877
#13 | “cognitive therapy”[MeSH] OR cognitive restructur*[tiab] OR cognitive processing therap*[tiab] | 7399
#14 | “Adaptation, Psychological”[Mesh] OR coping skill*[tiab] | 3550
#15 | “stress inoculation” | 122
#16 | “assertiveness training” | 101
#17 | psychodynamic[All Fields] AND (“therapy”[Subheading] OR “therapy”[All Fields] OR “therapeutics”[MeSH Terms] OR “therapeutics”[All Fields]) | 390
#18 | psychodynamic[All Fields] AND (“psychotherapy”[MeSH Terms] OR “psychotherapy”[All Fields]) | 360
#19 | (“psychoanalytic”[All Fields] AND “psychotherapy”[All Fields]) OR “psychoanalytic psychotherapy”[All Fields] | 198
#20 | (“psycho-analytic”[All Fields] AND “psychotherapy”[All Fields]) OR “psycho-analytic psychotherapy”[All Fields] | 0
#21 | “psychoanalytic therapy” | 155
#22 | “psycho-analytic therapy” | 0
#23 | “Eye Movement Desensitization Reprocessing”[MeSH] OR “EMDR”[tiab] | 97
#24 | “Psychotherapy”[Mesh] | 6781
#25 | “interpersonal therapy” OR “interpersonal psychotherapy” | 459
#26 | “family therapy”[tiab] OR “marital therapy”[tiab] | 1239
#27 | “group therapy” OR “group psychotherapy” OR “group psychological therapy” | 1453
#28 | “Hypnosis”[Mesh] | 1014
#29 | (#12 OR #13 OR #14 OR #15 OR #16 OR #17 OR #18 OR #19 OR #20 OR #21 OR #22 OR #23 OR #24 OR #25 OR #26 OR #27 OR #28) | 22285
#30 | (#11 AND #29) | 56
#31 | “Benzodiazepines”[Mesh] | 3019
#32 | “Antidepressive Agents, Tricyclic”[Pharmacological Action] | 1020
#33 | “Anticonvulsants”[Pharmacological Action] | 2197
#34 | “Adrenergic alpha-Antagonists”[Pharmacological Action] | 968
#35 | “Antipsychotic Agents”[Pharmacological Action] | 3442
#36 | “Antidepressive Agents”[Pharmacological Action] | 4600
#37 | “citalopram”[All Fields] OR “escitalopram”[All Fields] OR “fluoxetine”[All Fields] OR “fluvoxamine”[All Fields] OR “paroxetine”[All Fields] OR “sertraline”[All Fields] OR “desvenlafaxine”[All Fields] OR “venlafaxine”[All Fields] OR “duloxetine”[All Fields] OR “imipramine”[All Fields] OR “amitriptyline”[All Fields] OR “desipramine”[All Fields] OR “bupropion”[All Fields] OR “mirtazapine”[All Fields] OR “nefazodone”[All Fields] OR “trazodone”[All Fields] OR “prazosin”[All Fields] OR “olanzapine”[All Fields] OR “risperidone”[All Fields] OR “benzodiazepines”[MeSH] OR “alprazolam”[All Fields] OR “diazepam”[All Fields] OR “lorazepam”[All Fields] OR “clonazepam”[All Fields] OR “topiramate”[All Fields] OR “tiagabine”[All Fields] OR “lamotrigine”[All Fields] OR “carbamazepine”[All Fields] OR “divalproex”[All Fields] | 24418
#38 | (#31 OR #32 OR #33 OR #34 OR #35 OR #36 OR #37) | 29299
#39 | (#11 AND #38) | 14
#40 | (#30 OR #39) | 60

IPA, CINAHL, PsycINFO

# | Query | Results | #
S30 | S13 or S15 or S17 or S19 or S21 or S23 or S25 or S27 or S29 | Search modes - Boolean/Phrase | 20
S29 | S11 and S28 | Search modes - Boolean/Phrase | 3
S28 | DE “Best Practices” OR DE “Clinical Trials” OR DE “Evidence Based Practice” | Search modes - Boolean/Phrase | 89470
S27 | S11 and S26 | Search modes - Boolean/Phrase | 3
S26 | Cohort | Search modes - Boolean/Phrase | 74332
S25 | S11 and S24 | Search modes - Boolean/Phrase | 0
S24 | Case-Control | Search modes - Boolean/Phrase | 34711
S23 | S11 and S22 | Search modes - Boolean/Phrase | 1
S22 | Comparative | Search modes - Boolean/Phrase | 157644
S21 | S11 and S20 | Search modes - Boolean/Phrase | 10
S20 | review | Search modes - Boolean/Phrase | 576331
S19 | S11 and S18 | Search modes - Boolean/Phrase | 0
S18 | meta-analysis | Search modes - Boolean/Phrase | 31266
S17 | S11 and S16 | Search modes - Boolean/Phrase | 0
S16 | “Single Blind” | Search modes - Boolean/Phrase | 7534
S15 | S11 and S14 | Search modes - Boolean/Phrase | 3
S14 | “double blind” | Search modes - Boolean/Phrase | 53132
S13 | S11 and S12 | Search modes - Boolean/Phrase | 8
S12 | trial | Search modes - Boolean/Phrase | 197728
S11 | S8 or S10 | Search modes - Boolean/Phrase | 55
S10 | S6 and S9 | Search modes - Boolean/Phrase | 12
S9 | DE “Drug Therapy” | Search modes - Boolean/Phrase | 99342
S8 | S6 and S7 | Search modes - Boolean/Phrase | 46
S7 | DE “Treatment” OR DE “Adjunctive Treatment” OR DE “Aftercare” OR DE “Alternative Medicine” OR DE “Behavior Modification” OR DE “Bibliotherapy” OR DE “Cognitive Techniques” OR DE “Computer Assisted Therapy” OR DE “Creative Arts Therapy” OR DE “Crisis Intervention Services” OR DE “Cross Cultural Treatment” OR DE “Disease Management” OR DE “Health Care Services” OR DE “Interdisciplinary Treatment Approach” OR DE “Involuntary Treatment” OR DE “Language Therapy” OR DE “Life Sustaining Treatment” OR D ... | Limiters - Published Date from: 20110901–20121231; Language: English; Articles about Human Studies; English Language; Exclude MEDLINE records; Human; Language: English; Age Groups: Adult: 19–44 years, Middle Aged: 45–64 years, Aged: 65+ years, Aged, 80 and over, All Adult; Publication Year from: 2011–2012; English; Language: English; Age Groups: Adulthood (18 yrs & older), Young Adulthood (18–29 yrs), Thirties (30–39 yrs), Middle Age (40–64 yrs), Aged (65 yrs & older), Very Old (85 yrs & older); Population Group: Human; Exclude Dissertations Search modes - Boolean/Phrase | 2017
S6 | S1 or S2 or S3 or S4 | Limiters - Published Date from: 20110901–20121231; Language: English; Articles about Human Studies; English Language; Exclude MEDLINE records; Human; Language: English; Age Groups: Adult: 19–44 years, Middle Aged: 45–64 years, Aged: 65+ years, Aged, 80 and over, All Adult; Publication Year from: 2011–2012; English; Language: English; Age Groups: Adulthood (18 yrs & older), Young Adulthood (18–29 yrs), Thirties (30–39 yrs), Middle Age (40–64 yrs), Aged (65 yrs & older), Very Old (85 yrs & older); Population Group: Human; Exclude Dissertations Search modes - Boolean/Phrase | 632
S5 | S1 or S2 or S3 or S4 | Search modes - Boolean/Phrase | 28107
S4 | “posttraumatic stress disorder” | Search modes - Boolean/Phrase | 23052
S3 | “post-traumatic stress disorder” | Search modes - Boolean/Phrase | 6431
S2 | PTSD | Search modes - Boolean/Phrase | 19921
S1 | (DE “Posttraumatic Stress Disorder”) OR (DE “Combat Experience”) | Search modes - Boolean/Phrase | 18878

Web of Science (ISI)

Set | Results | Query
# 1 | [underlined: 12,501] | Topic=(PTSD) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 2 | [underlined: 29,122] | Topic=(posttraumatic) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 3 | [underlined: 13,375] | Topic=(“post trauma*”) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 4 | [underlined: 41,367] | #3 OR #2 OR #1 Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 5 | [underlined: 4,732] | ((#4)) AND Language=(English) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=2011–2012 Lemmatization=On
# 6 | [underlined: 2,529] | Topic=(Psychotherapy) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=2011–2012 Lemmatization=On
# 7 | [underlined: 1,760] | Topic=(pharmacotherapy) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=2011–2012 Lemmatization=On
# 8 | [underlined: 4,146] | #7 OR #6 Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=2011–2012 Lemmatization=On
# 9 | [underlined: 194] | #8 AND #5 Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=2011–2012 Lemmatization=On
# 10 | [underlined: 184] | (#9) AND Language=(English) AND Document Types=(Article OR Review) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=2011–2012 Lemmatization=On
# 11 | [underlined: 77,823] | Topic=(child) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=2011–2012 Lemmatization=On
# 12 | [underlined: 149] | (#10 NOT #11) AND Language=(English) AND Document Types=(Article OR Review) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=2011–2012 Lemmatization=On

EMBASE

No. | Query | Results
#1 | ‘posttraumatic stress disorder’/exp | 28,109
#2 | ‘psychotherapy’/exp | 178,445
#3 | ‘drug therapy’/exp | 1,581,241
#4 | #2 OR #3 | 1,746,450
#5 | #1 AND #4 | 5,908
#6 | ‘randomized controlled trial’/exp OR ‘single blind procedure’/exp OR ‘double blind procedure’/exp OR ‘systematic review’/exp OR ‘cohort analysis’/exp OR ‘meta analysis’/exp OR ‘comparative study’/exp OR ‘case control study’/exp | 1,496,266
#7 | #5 AND #6 | 783
#8 | #7 AND (‘article’/it OR ‘review’/it) | 716
#9 | ‘human’/exp | 13,435,263
#10 | ‘adult’/exp OR ‘middle aged’/exp OR ‘aged’/exp | 4,946,364
#11 | #8 AND #9 AND #10 ([embase]/lim OR [embase classic]/lim) AND [2011–2012]/py | 59

PILOTS

Query # | Search History
#1 | Search Query #1 DE=“PTSD” ([underlined: Copy Query]) 26706 Published Works results found in PILOTS Database Date Range: Earliest to 2012
#3 | Search Query #3 “post-traumatic stress disorder” OR “post-traumatic stress disorders” ([underlined: Copy Query]) 3430 Published Works results found in PILOTS Database Date Range: Earliest to 2012
#4 | Search Query #4 disorder* AND “post-traumatic” ([underlined: Copy Query]) 4309 Published Works results found in PILOTS Database Date Range: Earliest to 2012
#5 | Search Query #5 “combat disorders” ([underlined: Copy Query]) 29 Published Works results found in PILOTS Database Date Range: Earliest to 2012
#6 | Search Query #6 PTSD ([underlined: Copy Query]) 28781 Published Works results found in PILOTS Database Date Range: Earliest to 2012
#7 | Search Query #7 (DE=“PTSD”) or(“post-traumatic stress disorder” OR “post-traumatic stress disorders”) or(disorder* AND “post-traumatic”) or(“combat disorders”) or(PTSD) ([underlined: Copy Query]) 29010 Published Works results found in PILOTS Database Date Range: Earliest to Current Limited to:
#8 | Search Query #8 (DE=“PTSD”) or(“post-traumatic stress disorder” OR “post-traumatic stress disorders”) or(disorder* AND “post-traumatic”) or(“combat disorders”) or(PTSD) ([underlined: Copy Query]) 28942 Published Works results found in PILOTS Database Date Range: 1980 to 2012 Limited to:
#9 | Search Query #9 DE=“adults” ([underlined: Copy Query]) 19683 Published Works results found in PILOTS Database Date Range: 1980 to 2012 Limited to:
#10 | Search Query #10 ((DE=“PTSD”) or(“post-traumatic stress disorder” OR “post-traumatic stress disorders”) or(disorder* AND “post-traumatic”) or(“combat disorders”) or(PTSD)) and(DE=“adults”) ([underlined: Copy Query]) 13309 Published Works results found in PILOTS Database Date Range: Earliest to Current Limited to:
#11 | Search Query #11 DE=“exposure therapy” ([underlined: Copy Query]) 579 Published Works results found in PILOTS Database Date Range: Earliest to Current Limited to:
#12 | Search Query #12 “implosive therapy” OR (exposure AND (therapy OR psychotherapy)) OR “imaginal exposure” ([underlined: Copy Query]) 1478 Published Works results found in PILOTS Database Date Range: Earliest to 2012
#13 | Search Query #13 DE=“cognitive therapy” ([underlined: Copy Query]) 1683 Published Works results found in PILOTS Database Date Range: Earliest to 2012
#14 | Search Query #14 cognitive restructur* OR cognitive processing therap* ([underlined: Copy Query]) 255 Published Works results found in PILOTS Database Date Range: Earliest to 2012
#15 | Search Query #15 “psychological adaptation” ([underlined: Copy Query]) 36 Published Works results found in PILOTS Database Date Range: Earliest to 2012
#16 | Search Query #16 DE=“coping behavior” ([underlined: Copy Query]) 2281 Published Works results found in PILOTS Database Date Range: Earliest to 2012
#17 | Search Query #17 coping skill* ([underlined: Copy Query]) 202 Published Works results found in PILOTS Database Date Range: Earliest to 2012
#18 | Search Query #18 “stress inoculation” OR “assertiveness training” ([underlined: Copy Query]) 91 Published Works results found in PILOTS Database Date Range: Earliest to 2012
#19 | Search Query #19 psychodynamic AND (DE=“psychotherapy” OR psychotherapy) ([underlined: Copy Query]) 246 Published Works results found in PILOTS Database DateRange: Earliest to 2012
#20 | Search Query #20 psychodynamic AND (therapy OR therapeutics) ([underlined: Copy Query]) 195 Published Works results found in PILOTS Database Date Range: Earliest to 2012
#21 | Search Query #21 psychoanalytic AND (psychotherapy OR “psychoanalytic psychotherapy”) ([underlined: Copy Query]) 662 Published Works results found in PILOTS Database Date Range: Earliest to 2012
#22 | Search Query #22 psycho-analytic AND (psychotherapy OR “psychoanalytic psychotherapy”) ([underlined: Copy Query]) 2 Published Works results found in PILOTS Database Date Range: Earliest to 2012
#23 | Search Query #23 “psychoanalytic therapy” ([underlined: Copy Query]) 17 Published Works results found in PILOTS Database Date Range: Earliest to 2012
#24 | Search Query #24 “psycho-analytic therapy” ([underlined: Copy Query]) 0 Published Works results found in PILOTS Database Date Range: Earliest to 2012
#26 | Search Query #26 DE=“psychotherapy” ([underlined: Copy Query]) 3619 Published Works results found in PILOTS Database Date Range: Earliest to 2012
#28 | Search Query #28 “interpersonal therapy” OR “interpersonal psychotherapy” ([underlined: Copy Query]) 54 Published Works results found in PILOTS Database Date Range: Earliest to 2012
#29 | Search Query #29 “Eye Movement Desensitization Reprocessing” OR EMDR ([underlined: Copy Query]) 786 Published Works results found in PILOTS Database Date Range: Earliest to 2012
#30 | Search Query #30 “family therapy” OR “marital therapy” ([underlined: Copy Query]) 680 Published Works results found in PILOTS Database Date Range: Earliest to 2012
#31 | Search Query #31 “group therapy” OR “group psychotherapy” OR “group psychological therapy” ([underlined: Copy Query]) 1151 Published Works results found in PILOTS Database Date Range: Earliest to 2012
#32 | Search Query #32 DE=“hypnotherapy” ([underlined: Copy Query]) 295 Published Works results found in PILOTS Database Date Range: Earliest to 2012
#33 | Search Query #33 (DE=“exposure therapy”) or(“implosive therapy” OR (exposure AND (therapy OR psychotherapy)) OR “imaginal exposure”) or(DE=“cognitive therapy”) or(cognitive restructur* OR cognitive processing therap*) or(“psychological adaptation”) or(DE=“coping behavior”) or(coping skill*) or(“stress inoculation” OR “assertiveness training”) or(psychodynamic AND (DE=“psychotherapy” OR psychotherapy)) or(psychodynamic AND (therapy OR therapeutics)) or(psychoanalytic AND (psychotherapy OR “psychoanalytic psychotherapy”)) or(psycho-analytic AND (psychotherapy OR “psychoanalytic psychotherapy”)) or(“psychoanalytic therapy”) or(DE=“psychotherapy”) or(“interpersonal therapy” OR “interpersonal psychotherapy”) or(“Eye Movement Desensitization Reprocessing” OR EMDR) or(“family therapy” OR “marital therapy”) or(“group therapy” OR “group psychotherapy” OR “group psychological therapy”) or(DE=“hypnotherapy”) ([underlined: Copy Query]) 9126 Published Works results found in PILOTS Database Date Range: Earliest to Current Limited to:
#34 | Search Query #34 (((DE=“PTSD”) or(“post-traumatic stress disorder” OR “post-traumatic stress disorders”) or(disorder* AND “post-traumatic”) or(“combat disorders”) or(PTSD)) and(DE=“adults”)) and((DE=“exposure therapy”) or(“implosive therapy” OR (exposure AND (therapy OR psychotherapy)) OR “imaginal exposure”) or(DE=“cognitive therapy”) or(cognitive restructur* OR cognitive processing therap*) or(“psychological adaptation”) or(DE=“coping behavior”) or(coping skill*) or(“stress inoculation” OR “assertiveness training”) or(psychodynamic AND (DE=“psychotherapy” OR psychotherapy)) or(psychodynamic AND (therapy OR therapeutics)) or(psychoanalytic AND (psychotherapy OR “psychoanalytic psychotherapy”)) or(psycho-analytic AND (psychotherapy OR “psychoanalytic psychotherapy”)) or(“psychoanalytic therapy”) or(DE=“psychotherapy”) or(“interpersonal therapy” OR “interpersonal psychotherapy”) or(“Eye Movement Desensitization Reprocessing” OR EMDR) or(“family therapy” OR “marital therapy”) or(“group therapy” OR “group psychotherapy” OR “group psychological therapy”) or(DE=“hypnotherapy”)) ([underlined: Copy Query]) 2589 Published Works results found in PILOTS Database Date Range: Earliest to Current Limited to:
#35 | Search Query #35 DE=“benzodiazepine derivatives” ([underlined: Copy Query]) 94 Published Works results found in PILOTS Database Date Range: Earliest to Current Limited to:
#36 | Search Query #36 DE=“tricyclic derivatives” ([underlined: Copy Query]) 87 Published Works results found in PILOTS Database Date Range: Earliest to Current Limited to:
#37 | Search Query #37 DE=“antimanic drugs” ([underlined: Copy Query]) 104 Published Works results found in PILOTS Database Date Range: Earliest to Current Limited to:
#38 | Search Query #38 anticonvulsant* OR “anticonvulsant drug” OR “anticonvulsant drugs” ([underlined: Copy Query]) 67 Published Works results found in PILOTS Database Date Range: Earliest to 2012
#39 | Search Query #39 DE=“antiadrenergic agents” ([underlined: Copy Query]) 109 Published Works results found in PILOTS Database Date Range: Earliest to 2012
#40 | Search Query #40 DE=(“antipsychotic drugs” or “antiadrenergic agents”) ([underlined: Copy Query]) 246 Published Works results found in PILOTS Database Date Range: Earliest to 2012
#41 | Search Query #41 DE=(“antidepressant drugs” or “antiadrenergic agents”) ([underlined: Copy Query]) 253 Published Works results found in PILOTS Database Date Range: Earliest to 2012
#42 | Search Query #42 DE=(“antidepressant drugs” or “antiadrenergic agents”) ([underlined: Copy Query]) 253 Published Works results found in PILOTS Database Date Range: Earliest to 2012
#44 | Search Query #44 “citalopram” OR “escitalopram” OR “fluoxetine” OR “fluvoxamine” OR “paroxetine” OR “sertraline” OR “desvenlafaxine” OR “venlafaxine” OR “duloxetine” OR “imipramine” OR “amitriptyline” OR “desipramine” OR “bupropion” OR “mirtazapine” OR “nefazodone” OR “trazodone” OR “prazosin” OR “olanzapine” OR “risperidone” OR “benzodiazepines” OR “alprazolam” OR “diazepam” OR “lorazepam” OR “clonazepam” OR “topiramate” OR “tiagabine” OR “lamotrigine” OR “carbamazepine” OR “divalproex” ([underlined: Copy Query]) 666 Published Works results found in PILOTS Database Date Range: Earliest to 2012
#46 | Search Query #46 (DE=“benzodiazepine derivatives”) or(DE=“tricyclic derivatives”) or(DE=“antimanic drugs”) or(anticonvulsant* OR “anticonvulsant drug” OR “anticonvulsant drugs”) or(DE=“antiadrenergic agents”) or(DE=(“antipsychotic drugs” or “antiadrenergic agents”)) or(DE=(“antidepressant drugs” or “antiadrenergic agents”)) or(DE=(“antidepressant drugs” or “antiadrenergic agents”)) or(“citalopram” OR “escitalopram” OR “fluoxetine” OR “fluvoxamine” OR “paroxetine” OR “sertraline” OR “desvenlafaxine” OR “venlafaxine” OR “duloxetine” OR “imipramine” OR “amitriptyline” OR “desipramine” OR “bupropion” OR “mirtazapine” OR “nefazodone” OR “trazodone” OR “prazosin” OR “olanzapine” OR “risperidone” OR “benzodiazepines” OR “alprazolam” OR “diazepam” OR “lorazepam” OR “clonazepam” OR “topiramate” OR “tiagabine” OR “lamotrigine” OR “carbamazepine” OR “divalproex”) ([underlined: Copy Query]) 1051 Published Works results found in PILOTS Database Date Range: Earliest to Current Limited to:
#47 | Search Query #47 (((DE=“PTSD”) or(“post-traumatic stress disorder” OR “post-traumatic stress disorders”) or(disorder* AND “post-traumatic”) or(“combat disorders”) or(PTSD)) and(DE=“adults”)) and((DE=“benzodiazepine derivatives”) or(DE=“tricyclic derivatives”) or(DE=“antimanic drugs”) or(anticonvulsant* OR “anticonvulsant drug” OR “anticonvulsant drugs”) or(DE=“antiadrenergic agents”) or(DE=(“antipsychotic drugs” or “antiadrenergic agents”)) or(DE=(“antidepressant drugs” or “antiadrenergic agents”)) or(DE=(“antidepressant drugs” or “antiadrenergic agents”)) or(“citalopram” OR “escitalopram” OR “fluoxetine” OR “fluvoxamine” OR “paroxetine” OR “sertraline” OR “desvenlafaxine” OR “venlafaxine” OR “duloxetine” OR “imipramine” OR “amitriptyline” OR “desipramine” OR “bupropion” OR “mirtazapine” OR “nefazodone” OR “trazodone” OR “prazosin” OR “olanzapine” OR “risperidone” OR “benzodiazepines” OR “alprazolam” OR “diazepam” OR “lorazepam” OR “clonazepam” OR “topiramate” OR “tiagabine” OR “lamotrigine” OR “carbamazepine” OR “divalproex”)) ([underlined: Copy Query]) 377 Published Works results found in PILOTS Database Date Range: Earliest to Current Limited to:
#48 | Search Query #48 ((((DE=“PTSD”) or(“post-traumatic stress disorder” OR “post-traumatic stress disorders”) or(disorder* AND “post-traumatic”) or(“combat disorders”) or(PTSD)) and(DE=“adults”)) and((DE=“exposure therapy”) or(“implosive therapy” OR (exposure AND (therapy OR psychotherapy)) OR “imaginal exposure”) or(DE=“cognitive therapy”) or(cognitive restructur* OR cognitive processing therap*) or(“psychological adaptation”) or(DE=“coping behavior”) or(coping skill*) or(“stress inoculation” OR “assertiveness training”) or(psychodynamic AND (DE=“psychotherapy” OR psychotherapy)) or(psychodynamic AND (therapy OR therapeutics)) or(psychoanalytic AND (psychotherapy OR “psychoanalytic psychotherapy”)) or(psycho-analytic AND (psychotherapy OR “psychoanalytic psychotherapy”)) or(“psychoanalytic therapy”) or(DE=“psychotherapy”) or(“interpersonal therapy” OR “interpersonal psychotherapy”) or(“Eye Movement Desensitization Reprocessing” OR EMDR) or(“family therapy” OR “marital therapy”) or(“group therapy” OR “group psychotherapy” OR “group psychological therapy”) or(DE=“hypnotherapy”))) or((((DE=“PTSD”) or(“post-traumatic stress disorder” OR “post-traumatic stress disorders”) or(disorder* AND “post-traumatic”) or(“combat disorders”) or(PTSD)) and(DE=“adults”)) and((DE=“benzodiazepine derivatives”) or(DE=“tricyclic derivatives”) or(DE=“antimanic drugs”) or(anticonvulsant* OR “anticonvulsant drug” OR “anticonvulsant drugs”) or(DE=“antiadrenergic agents”) or(DE=(“antipsychotic drugs” or “antiadrenergic agents”)) or(DE=(“antidepressant drugs” or “antiadrenergic agents”)) or(DE=(“antidepressant drugs” or “antiadrenergic agents”)) or(“citalopram” OR “escitalopram” OR “fluoxetine” OR “fluvoxamine” OR “paroxetine” OR “sertraline” OR “desvenlafaxine” OR “venlafaxine” OR “duloxetine” OR “imipramine” OR “amitriptyline” OR “desipramine” OR “bupropion” OR “mirtazapine” OR “nefazodone” OR “trazodone” OR “prazosin” OR “olanzapine” OR “risperidone” OR “benzodiazepines” OR “alprazolam” OR “diazepam” OR “lorazepam” OR “clonazepam” OR “topiramate” OR “tiagabine” OR “lamotrigine” OR “carbamazepine” OR “divalproex”))) ([underlined: Copy Query]) 2920 Published Works results found in PILOTS Database Date Range: Earliest to Current Limited to:
#50 | Search Query #50 DE=“randomized clinical trial” ([underlined: Copy Query]) 613 Published Works results found in PILOTS Database Date Range: Earliest to Current Limited to:
#52 | Search Query #52 “single-blind” ([underlined: Copy Query]) 16 Published Works results found in PILOTS Database Date Range: Earliest to 2012
#53 | Search Query #53 “double-blind” ([underlined: Copy Query)] 187 Published Works results found in PILOTS Database Date Range: Earliest to 2012
#54 | Search Query #54 “random allocation” ([underlined: Copy Query)] 1 Published Works result found in PILOTS Database Date Range: Earliest to 2012
#55 | Search Query #55 DE=“meta analysis” ([underlined: Copy Query)] 272 Published Works results found in PILOTS Database Date Range: Earliest to 2012
#56 | Search Query #56 “meta-analysis” ([underlined: Copy Query)] 316 Published Works results found in PILOTS Database Date Range: Earliest to 2012
#57 | Search Query #57 “comparative study” OR case control stud* ([underlined: Copy Query)] 179 Published Works results found in PILOTS Database Date Range: Earliest to 2012
#58 | Search Query #58 “systematic review” OR (review AND systematic) ([underlined: Copy Query)] 331 Published Works results found in PILOTS Database Date Range: Earliest to 2012
#59 | Search Query #59 “cohort studies” OR “cohort effect” OR cohort* ([underlined: Copy Query)] 841 Published Works results found in PILOTS Database Date Range: Earliest to 2012
#60 | Search Query #60 trial ([underlined: Copy Query)] 1361 Published Works results found in PILOTS Database Date Range: Earliest to 2012
#62 | Search Query #62 “treatment outcome” OR “treatment outcomes” ([underlined: Copy Query)] 652 Published Works results found in PILOTS Database Date Range: Earliest to 2012
#63 | Search Query #63 (DE=“randomized clinical trial”) or(“single-blind”) or(“double-blind”) or(“random allocation”) or(DE=“meta analysis”) or(“meta-analysis”) or(“comparative study” OR case control stud*) or(“systematic review” OR (review AND systematic)) or(“cohort studies” OR “cohort effect” OR cohort*) or(trial) or(“treatment outcome” OR “treatment outcomes”) ([underlined: Copy Query]) 3432 Published Works results found in PILOTS Database Date Range: Earliest to Current Limited to:
#64 | Search Query #64 (((((DE=“PTSD”) or(“post-traumatic stress disorder” OR “post-traumatic stress disorders”) or(disorder* AND “post-traumatic”) or(“combat disorders”) or(PTSD)) and(DE=“adults”)) and((DE=“exposure therapy”) or(“implosive therapy” OR (exposure AND (therapy OR psychotherapy)) OR “imaginal exposure”) or(DE=“cognitive therapy”) or(cognitive restructur* OR cognitive processing therap*) or(“psychological adaptation”) or(DE=“coping behavior”) or(coping skill*) or(“stress inoculation” OR “assertiveness training”) or(psychodynamic AND (DE=“psychotherapy” OR psychotherapy)) or(psychodynamic AND (therapy OR therapeutics)) or(psychoanalytic AND (psychotherapy OR “psychoanalytic psychotherapy”)) or(psycho-analytic AND (psychotherapy OR “psychoanalytic psychotherapy”)) or(“psychoanalytic therapy”) or(DE=“psychotherapy”) or(“interpersonal therapy” OR “interpersonal psychotherapy”) or(“Eye Movement Desensitization Reprocessing” OR EMDR) or(“family therapy” OR “marital therapy”) or(“group therapy” OR “group psychotherapy” OR “group psychological therapy”) or(DE=“hypnotherapy”))) or((((DE=“PTSD”) or(“post-traumatic stress disorder” OR “post-traumatic stress disorders”) or(disorder* AND “post-traumatic”) or(“combat disorders”) or(PTSD)) and(DE=“adults”)) and((DE=“benzodiazepine derivatives”) or(DE=“tricyclic derivatives”) or(DE=“antimanic drugs”) or(anticonvulsant* OR “anticonvulsant drug” OR “anticonvulsant drugs”) or(DE=“antiadrenergic agents”) or(DE=(“antipsychotic drugs” or “antiadrenergic agents”)) or(DE=(“antidepressant drugs” or “antiadrenergic agents”)) or(DE=(“antidepressant drugs” or “antiadrenergic agents”)) or(“citalopram” OR “escitalopram” OR “fluoxetine” OR “fluvoxamine” OR “paroxetine” OR “sertraline” OR “desvenlafaxine” OR “venlafaxine” OR “duloxetine” OR “imipramine” OR “amitriptyline” OR “desipramine” OR “bupropion” OR “mirtazapine” OR “nefazodone” OR “trazodone” OR “prazosin” OR “olanzapine” OR “risperidone” OR “benzodiazepines” OR “alprazolam” OR “diazepam” OR “lorazepam” OR “clonazepam” OR “topiramate” OR “tiagabine” OR “lamotrigine” OR “carbamazepine” OR “divalproex”)))) and((DE=“randomized clinical trial”) or(“single-blind”) or(“double-blind”) or(“random allocation”) or(DE=“meta analysis”) or(“meta-analysis”) or(“comparative study” OR case control stud*) or(“systematic review” OR (review AND systematic)) or(“cohort studies” OR “cohort effect” OR cohort*) or(trial) or(“treatment outcome” OR “treatment outcomes”)) ([underlined: Copy Query]) 70 Published Works results found in PILOTS Database Date Range: Earliest to Current Limited to:

Total additional references identified by the update searches = 998; 362 remained after duplicates were removed.