# Outcome Measures and Instruments

Table A-1 Outcome measures and instruments

Abbreviated Name | Complete Name | Description | Range/Meaning of Possible Scores | Improvement Indicated by
BDI | Beck Depression Inventory | 21-item measure used to assess depression. Self-report or verbally administered by a trained professional administrator. Administration time approximately 5 minutes. | 0 to 63 | Decrease
CAPS | Clinician-Administered PTSD Scale | Current version includes a 30-item structured interview administered by a trained professional. Corresponds to the DSM-IV criteria for PTSD symptoms, impact on functioning, response validity, lifetime diagnosis, and overall PTSD severity. Time frame for assessment includes past week, month, or worst month since trauma. Administration time approximately 45 to 60 minutes. In the past there were different versions corresponding to different time periods. CAPS-1 (later renamed CAPS-DX) assessed current and lifetime PTSD diagnosis. The CAPS-2 (later renamed CAPS-SX) assessed the severity of symptoms over the past one week. These two versions were later combined into the current version, which can be used to assess either symptoms or diagnoses. | 0 to136 | Decrease
DTS | Davidson Trauma Scale | 17-item self-report measure that assesses the 17 DSM-IV symptoms of PTSD. Each item corresponds to a DSM-IV symptom of PTSD, and each symptom is rated in terms of frequency and severity. Scores can be calculated for each of the 3 PTSD symtpom clusters (B,C, and D). Administation time approximately 10 minutes. | 0 to 136 | Decrease
GAF | Global Assessment of Functioning | Clinician administered scale used to assess the social, occupational, and psychological functioning of adults. | 0 to 100 | Increase
HADS | Hospital Anxiety and Depression Scale | 14-item self-report measure developed to assess anxiety and depression in non-psychiatric populations. Meant to differentiate symptoms of depression with those of anxiety. Administration time 5 minutes. | 0 to 42 | Decrease
HAM-A or HAS | Hamilton Anxiety Scale | 14-item clinician administered measure used to assess the severity of anxiety symptoms. Administration time 10 to 15 minutes. | 0 to 56 | Decrease
HAM-D | Hamilton Depression Scale | 17 or 21 item (depending on version) clinician administered scale used to measure the severity of depressive symptoms. Administration time 15 to 20 minutes. | 0 to 54 (17 item) | Decrease
IES | Impact of Event Scale | 15-item self-reported measure used to assess the frequency with which experiences of “intrusions,” “avoidance,” and emotional numbing related to stressful events occurred in the last week. A total distress score is calculated by summing all 15 item responses. | 0 to 75 | Decrease
IES-R | Impact of Events Scale-Revised | 22-item self-report measure that assesses subjective distress caused by traumatic events. Contains 7 items more than the IES regarding hyperaraousal symptoms of PTSD. Items correspond directly to 14 of the 17 DSM-IV symptoms of PTSD. Subscales can be computed for Intrusion, Avoidance, and Hyperarousal. | 0 to 88 | Decrease
MADRS | Montgomery-Asberg Depression Rating Scale | 10-item clinician rated measure that assesses the severity of depression. Administration time approximately 15 minutes. | 0 to 60 | Decrease
MISS or M-PTSD | Mississippi Scale for Combat-related PTSD | 35-item self-report questionnaire used to assess DSM-III combat-related PTSD and related features (depression, suicidality, and substance abuse). Administration time approximately 10 to 15minutes. | 35 to 175 | Decrease
MPSS-SR | Modified PTSD Symptom Scale | 17-item self-report measure that assesses the 17 DSM-III-R symptoms of PTSD. Measure is a modification of the PTSD Symptom Scale (PSS). Major modifications are that items are not keyed to any particular traumatic event and that the MPSS-SR includes severity ratings in addition to the original measure’s frequency ratings for each item. It can be used to make a preliminary determination of the diagnosis of PTSD using either DSM-III-R criteria or a frequency, severity, or total score cutoff scores. It can be scored as a continuous measure of PTSD symptom severity. | 0 to 68 (intensity) 0 to 51 (frequency) | Decrease
PTDS or PDS | Posttraumatic Diagnostic Scale | 49- item self report measure for severity of PTSD symptoms related to a single identified traumatic event. Assesses all DSM-IV criteria (A-F) in the past month (time frame can be adjusted). Four sections include: trauma checklist, description of post traumatic event, assessment of 17 PTSD symptoms, and interference of symptoms. Total severity score reflecting frequency of 17 PTSD symptoms. | 0 to 51 | Decrease
PCL | PTSD Checklist | 17-item self-report measure of the 17 DSM-IV symptoms of PTSD. Has been used to screen individuals for PTSD, diagnose PTSD, and monitor symptom change during and after treatment. There are three versions of the PCL: PCL-M (military), PCL-C (civilian), and PCL-S (specific). Administration time approximately 5 to10 minutes. | 17 to 85 | Decrease
PTSD-I | PTSD Interview | Structured clinical interview. Patients given a copy of scale to read along with interviewer and asked to give subjective ratings for each symptom. | | Decrease
PSS-I | PTSD Symptom Scale Interview | 17-item semistructured interview that assesses the presence and severity of DSM-IV PTSD symptoms related to a single identified traumatic event in individuals with a known trauma history. Each item is assessed with a brief, single question. Interviewees are asked about symptoms they have experienced in the past 2 weeks. Administration time approximately 20 minutes. | 0 to 51 | Decrease
PSS-SR | PTSD Symptom Scale Self-report Version | 17-item self-report scale used to diagnose PTSD according to DSM-III-R criteria. Assesses the severity of PTSD symptoms (consists of the same 17 items as the PSS-I). | 0 to 51 | Decrease
Q-LES-Q-SF | Quality of Life Enjoyment and Satisfaction Questionnaire-Short Form | 16-item self-report questionnaire that assesses overall enjoyment and satisfaction with physical health, mood, work, household and leisure activities, social and family relationships, daily functioning, sexual life, economic status, overall well-being and medications. | 14 to 70 | Increase
SF-36 | 36-Item Short Form Health Survey | 36-item scale of patient health status. Administratin time less than 15 minutes | 0 to 100 (mean) | Increase
SI-PTSD or SIP | Structured Interview for PTSD | Assesses the 17 PTSD symptoms as well as survival and behavioral guilt. For each item, the interviewer assigns a severity rating that reflects both frequency and intensity. Responses can be used to make a determination about whether client’s symptoms meet DSM criteria B, C, and D for PTSD. Administration time approximately 20 to 30 minutes. | 0 to 68 | Decrease
SCID | Structured Clinical Interview PTSD Module | Semistructured interview used to assess the prevalence, absence, and subthreshold presence of PTSD used across trauma populations. Consists of separate modules corresponding to categories of diagnoses. Administration time 25 minutes. | Not quantitatively scored | Decrease
SCL-90-R | Symptom Checklist- 90-Revised | 90-item self-report questionnaire used to assess a broad range of psychological problems, symptoms of psychopathology, patient progress, and treatment outcomes. Administration time approximately 12 to15 minutes. | 0 to 360 | Decrease
SDS | Sheehan Disability Scale | 5-item self-report measure developed to assess functional impairment in work/school, social and family life. | 0 to 30 | Decrease
SF-12 | Medical Outcome Study Self-Report Form | 12-item self-report measure of overall health status. Administratin time less than 15 minutes. | 0 to 100 | Increase
SPRINT | Short PTSD Rating Interview | 8-item self-report measure that assesses the core symptoms of PTSD (intrusion, avoidance, numbing, arousal), somatic malaise, stress vulnerability, and role and social functional impairment. | 0 to 32 | Decrease
STAI | State-Trait Anxiety Inventory | 20-item self-report measure that assesses state and trait anxiety. Administration time approximately 10 to 20 minutes. | 20 to 80 | Decrease
TOP-8 | Treatment-outcome post-traumatic stress disorder scale | 8-item measure based on all three symptom clusters of post-traumatic stress disorder. | 0 to 32 | Decrease
WAS | Work and Social Adjustment Scale | 5-item measure of general social impairment. | 0 to 40 | Decrease