# References

1 Chen SL, Morgan TR. The natural history of hepatitis C virus (HCV) infection. Int J Med Sci. 2006;3(2):47-52. [pmid: 16614742].
2 Chak E, Talal AH, Sherman KE, et al. Hepatitis C virus infection in USA: an estimate of true prevalence. Liver Int. Sep. 2011;31(8):1090-101. [pmid: 21745274].
3 Centers for Disease Control and Prevention. Viral Hepatitis Surveillance - United States. 2009. 2011. http://www.cdc.gov/hepatitis/Statistics/index.htm.
4 Smith BC, Morgan RL, Beckett G, et al. Recommendations for the Identification of Hepatitis C Virus (HCV) Chronic Infection Among Persons Born During 1945 through 1965. [draft for public comment]. Atlanta, GA. Centers for Disease Control and Prevention. 2012.
5 Armstrong GL, Wasley A, Simard EP, et al. The prevalence of hepatitis C virus infection in the United States, 1999 through 2002. Ann Intern Med. May. 16. 2006;144(10):705-14. [pmid: 16702586].
6 Ly KN, Xing J, Klevens RM, et al. The increasing burden of mortality from viral hepatitis in the United States between 1999 and 2007. Ann Intern Med. Feb. 21. 2012;156(4):271-8. [pmid: 22351712].
7 Nelson PK, Mathers BM, Cowie B, et al. Global epidemiology of hepatitis B and hepatitis C in people who inject drugs: results of systematic reviews. Lancet. Aug. 13. 2011;378(9791):571-83. [pmid: 21802134].
8 Rifai MA, Gleason OC, Sabouni D. Psychiatric care of the patient with hepatitis C: a review of the literature. Prim Care Companion. J Clin Psychiatry. 2010;12(6). [pmid: 21494349].
9 Higgs P, Sacks-Davis R, Gold J, et al. Barriers to receiving hepatitis c treatment for people who inject drugs myths and evidence. Hepatitis Monthly. 2011;11(7):513-8. [pmid: 22087188].
10 Rifai MA, Moles JK, Short DD. Hepatitis C treatment eligibility and outcomes among patients with psychiatric illness. Psychiatr Serv. Apr. 2006;57(4):570-2. [pmid: 16603757].
11 Centers for Disease Control. Morbidity and Mortality Weekly Report. May. 22. 2009;58(SS-3):1-27.
12 Ghany MG, Strader DB, Thomas DL, et al. Diagnosis, management, and treatment of hepatitis C: an update. Hepatology (Baltimore, Md ). Apr. 2009;49(4):1335-74. [pmid: 19330875].
13 Maheshwari A, Ray S, Thuluvath PJ. Acute hepatitis C. Lancet. Jul. 26. 2008;372(9635):321-32. [pmid: 18657711].
14 National Institutes of Health Consensus Development Conference Statement: Management of hepatitis C 2002 (June 10–12, 2002). Gastroenterology. Dec. 2002;123(6):2082-99. [pmid: 12454863].
15 Poynard T, Bedossa P, Opolon P. Natural history of liver fibrosis progression in patients with chronic hepatitis C. The OBSVIRC, METAVIR, CLINIVIR, and DOSVIRC groups. Lancet. Mar. 22. 1997;349(9055):825-32. [pmid: 9121257].
16 Pawlotsky JM. Pathophysiology of hepatitis C virus infection and related liver disease. Trends Microbiol. Feb. 2004;12(2):96-102. [pmid: 15036326].
17 Nainan OV, Alter MJ, Kruszon-Moran D, et al. Hepatitis C virus genotypes and viral concentrations in participants of a general population survey in the United States. Gastroenterology. Aug. 2006;131(2):478-84. [pmid: 16890602].
18 Zein NN, Rakela J, Krawitt EL, et al. Hepatitis C virus genotypes in the United States: epidemiology, pathogenicity, and response to interferon therapy. Collaborative Study Group. Ann Intern Med. Oct. 15. 1996;125(8):634-9. [pmid: 8849147].
19 Colin C, Lanoir D, Touzet S, et al. Sensitivity and specificity of third-generation hepatitis C virus antibody detection assays: an analysis of the literature. J Viral Hepat. Mar. 2001;8(2):87-95. [pmid: 11264728].
20 Thio CL, Nolt KR, Astemborski J, et al. Screening for hepatitis C virus in human immunodeficiency virus-infected individuals. J Clin Microbiol. Feb. 2000;38(2):575-7. [pmid: 10655348].
21 Pawlotsky JM. Molecular diagnosis of viral hepatitis. Gastroenterology. May. 2002;122(6):1554-68. [pmid: 12016423].
22 Scott JD, Gretch DR. Molecular diagnostics of hepatitis C virus infection: a systematic review. JAMA. Feb. 21. 2007;297(7):724-32. [pmid: 17312292].
23 Gebo KA, Bartlett JG. Management of hepatitis C: a review of the NIH Consensus Development Conference. The Hopkins HIV Report: a Bimonthly Newsletter for Healthcare Providers. Sep. 2002;14(5):suppl i-iv. [pmid: 12240644].
24 Awad T, Thorlund K, Hauser G, et al. Peginterferon alpha-2a is associated with higher sustained virological response than peginterferon alfa-2b in chronic hepatitis C: systematic review of randomized trials. Hepatology. Apr. 2010;51(4):1176-84. [pmid: 20187106].
25 Brok J, Gluud LL, Gluud C. Ribavirin plus interferon versus interferon for chronic hepatitis. C Cochrane Database Syst Rev. 2010;(1):CD005445. [pmid: 20091577].
26 Parikh M, Singh A, Sood G. Extended treatment duration for treatment naive chronic hepatitis C genotype 1 late viral responders: a meta-analysis comparing 48 weeks vs 72 weeks of pegylated interferon and ribavirin. J Viral Hepat. Apr. 2011;18(4):e99-103. [pmid: 20950407].
27 Zhao S, Liu E, Chen P, et al. A comparison of peginterferon alpha-2a and alpha-2b for treatment-naive patients with chronic hepatitis C virus: A meta-analysis of randomized trials. Clin Ther. Aug. 2010;32(9):1565-77. [pmid: 20974315].
28 Fabrizi F, Dixit V, Martin P, et al. Combined antiviral therapy of hepatitis C virus in dialysis patients: meta-analysis of clinical trials. J Viral Hepat. Jul. 2011;18(7):e263-e269. [pmid: 21108701].
29 D’Heygere F, George C, Van VH, et al. Efficacy of interferon-based antiviral therapy in patients with chronic hepatitis C infected with genotype 5: a meta-analysis of two large prospective clinical trials. J Med Virol. May. 2011;83(5):815-9. [pmid: 21412790].
30 Agency for Healthcare Research and Quality. ’s Effective Health Care Program. Treatment for Hepatitis C Virus Infection in Adults: A Comparative Effectiveness Review (draft report). Forthcoming 2012.
31 Ghany MG, Nelson DR, Strader DB, et al. An update on treatment of genotype 1 chronic hepatitis C virus infection: 2011 practice guideline by the American Association for the Study of Liver Diseases. Hepatology. Oct. 1. 2011;54(4):1433-44. [pmid: 21898493].
32 Tanioka D, Iwasaki Y, Araki Y, et al. Factors associated with adherence to combination therapy of interferon and ribavirin for patients with chronic hepatitis C: importance of patient’s motivation and physician’s treatment experience. Liver International. May. 2009;29(5):721-9. [pmid: 19141025].
33 Satapathy SK, Lingisetty CS, Proper S, et al. Equally poor outcomes to pegylated interferon-based therapy in African Americans and Hispanics with chronic hepatitis C infection. J Clin Gastroenterol. Feb. 2010;44(2):140-5. [pmid: 19826275].
34 Rodriguez-Torres M, Jeffers LJ, Sheikh MY, et al. Peginterferon alfa-2a and ribavirin in Latino and non-Latino whites with hepatitis C. N Engl J Med. Jan. 15. 2009;360(3):257-67. [pmid: 19144941].
35 Evon DM, Ramcharran D, Belle SH, et al. Prospective analysis of depression during peginterferon and ribavirin therapy of chronic hepatitis C: results of the Virahep-C study. American Journal of Gastroenterology. Dec. 2009;104(12):2949-58. [pmid: 19789525].
36 Anand BS, Currie S, Dieperink E, et al. Alcohol use and treatment of hepatitis C virus: results of a national multicenter study. Gastroenterology. May. 2006;130(6):1607-16. [pmid: 16697724].
37 Chu CJ, Lee SD, Hung TH, et al. Insulin resistance is a major determinant of sustained virological response in genotype 1 chronic hepatitis C patients receiving peginterferon alpha-2b plus ribavirin. Aliment Pharmacol Ther. Jan. 2009;29(1):46-54. [pmid: 18680550].
38 Conjeevaram HS, Fried MW, Jeffers LJ, et al. Peginterferon and ribavirin treatment in African American and Caucasian American patients with hepatitis C genotype 1. Gastroenterology. Aug. 2006;131(2):470-7. [pmid: 16890601].
39 McHutchison JG, Manns M, Patel K, et al. Adherence to combination therapy enhances sustained response in genotype-1-infected patients with chronic hepatitis C. Gastroenterology. Oct. 2002;123(4):1061-9. [pmid: 12360468].
40 Manns MP. Adherence to combination therapy: influence on sustained virologic response and economic impact. Gastroenterol Clin North Am. Mar. 2004;33(Suppl 1):11-24. [pmid: 15081100].
41 Fried MW, Shiffman ML, Reddy KR, et al. Peginterferon alfa-2a plus ribavirin for chronic hepatitis C virus infection. N Engl J Med. Sep. 26. 2002;347(13):975-82. [pmid: 12324553].
42 Russo MW, Fried MW. Side effects of therapy for chronic hepatitis C. Gastroenterology. 2003;124(6):1711-9. [pmid: 12761728].
43 Ge D, Fellay J, Thompson AJ, et al. Genetic variation in IL28B predicts hepatitis C treatment-induced viral clearance. Nature. Sep. 17. 2009;461(7262):399-401. [pmid: 19684573].
44 Lo Re V, Teal V, Localio AR, et al. Relationship between adherence to hepatitis C virus therapy and virologic outcomes: a cohort study. Ann Intern Med. Sep. 20. 2011;155(6):353-60. [pmid: 21930852].
45 Weiss JJ, Brau N, Stivala A, et al. Review article: adherence to medication for chronic hepatitis C - building on the model of human immunodeficiency virus antiretroviral adherence research. Alimentary Pharmacology & Therapeutics. Jul. 2009;30(1):14-27. [pmid: 19416131].
46 Beste LA, Ioannou GN, Larson MS, et al. Predictors of early treatment discontinuation among patients with genotype 1 hepatitis C and implications for viral eradication. Clinical Gastroenterology & Hepatology. Nov. 2010;8(11):972-8. [pmid: 20692371].
47 Martin-Santos R, Diez-Quevedo C, Castellvi P, et al. De novo depression and anxiety disorders and influence on adherence during peginterferon-alpha-2a and ribavirin treatment in patients with hepatitis C. Alimentary Pharmacology & Therapeutics. Feb. 1. 2008;27(3):257-65. [pmid: 17988237].
48 Schaefer M, Schmidt F, Folwaczny C, et al. Adherence and mental side effects during hepatitis C treatment with interferon alfa and ribavirin in psychiatric risk groups. Hepatology. Feb. 2003;37(2):443-51. [pmid: 12540795].
49 Marcellin P, Chousterman M, Fontanges T, et al. Adherence to treatment and quality of life during hepatitis C therapy: a prospective, real-life, observational study. Liver International. Apr. 2011;31(4):516-24. [pmid: 21382162].
50 Sylvestre DL, Clements BJ. Adherence to hepatitis C treatment in recovering heroin users maintained on methadone. European Journal of Gastroenterology & Hepatology. Sep. 2007;19(9):741-7. [pmid: 17700258].
51 Cournot M, Glibert A, Castel F, et al. Management of hepatitis C in active drugs users: experience of an addiction care hepatology unit. Gastroenterologie Clinique et Biologique. Jun. 2004;28(6–7 Pt 1):533-9. [pmid: 15243385].
52 Wilkinson M, Crawford V, Tippet A, et al. Community-based treatment for chronic hepatitis C in drug users: High rates of compliance with therapy despite ongoing drug use. Alimentary Pharmacology and Therapeutics. 2009;29(1):29-37. [pmid: 18752631].
53 Eslam M, Aparcero R, Kawaguchi T, et al. Meta-analysis: insulin resistance and sustained virological response in hepatitis C. Aliment Pharmacol Ther. Aug. 2011;34(3):297-305. [pmid: 21623851].
54 Evon DM, Esserman DA, Ramcharran D, et al. Social support and clinical outcomes during antiviral therapy for chronic hepatitis C. Journal of Psychosomatic Research. Nov. 2011;71(5):349-56. [pmid: 21999979].
55 Julius RJ, Novitsky MA Jr, Dubin WR. Medication adherence: a review of the literature and implications for clinical practice. J Psychiatr Pract. Jan. 2009;15(1):34-44. [pmid: 19182563].
56 Cramer JA, Roy A, Burrell A, et al. Medication compliance and persistence: terminology and definitions. Value Health. Jan. 2008;11(1):44-7. [pmid: 18237359].
57 Haynes RB, Ackloo E, Sahota N, et al. Interventions for enhancing medication adherence. Cochrane Database Syst Rev. 2008. [pmid: 18425859].
58 McDonald HP, Garg AX, Haynes RB. Interventions to enhance patient adherence to medication prescriptions: scientific review. JAMA. Dec. 11. 2002;288(22):2868-79. [pmid: 12472329].
59 Osterberg L, Blaschke T. Adherence to medication. N Engl J Med. Aug. 4. 2005;353(5):487-97. [pmid: 16079372].
60 Yamada G, Iino S, Okuno T, et al. Virological response in patients with hepatitis C virus genotype 1b and a high viral load: impact of peginterferon-alpha-2a plus ribavirin dose reductions and host-related factors. [Erratum appears in Clin Drug Investig. 2008;28(4):210]. Clinical Drug Investigation. 2008;28(1):9-16. [pmid: 18081356].
61 Bertino G, Ardiri A, Boemi PM, et al. Epoetin alpha improves the response to antiviral treatment in HCV-related chronic hepatitis. European Journal of Clinical Pharmacology. Oct. 2010;66(10):1055-63. [pmid: 20652232].
62 Singh N, Squier C, Sivek C, et al. Determinants of compliance with antiretroviral therapy in patients with human immunodeficiency virus: prospective assessment with implications for enhancing compliance. AIDS Care. Jun. 1996;8(3):261-9. [pmid: 8827119].
63 Sola R, Galeras JA, Montoliu S, et al. Poor response to hepatitis C virus (HCV) therapy in HIV- and HCV-coinfected patients is not due to lower adherence to treatment. AIDS Research & Human Retroviruses. May. 2006;22(5):393-400. [pmid: 16706615].
64 Bonkovsky HL, Tice AD, Yapp RG, et al. Efficacy and safety of peginterferon alfa-2a/ribavirin in methadone maintenance patients: randomized comparison of direct observed therapy and self-administration. American Journal of Gastroenterology. Nov. 2008;103(11):2757-65. [pmid: 18684176].
65 Cohen SM, Kwasny MJ, Ahn J. Use of specialty care versus standard retail pharmacies for treatment of hepatitis C. Ann Pharmacother. Feb. 2009;43(2):202-9. [pmid: 19193591].
66 Alberti A. What are the comorbidities influencing the management of patients and the response to therapy in chronic hepatitis C?. Liver Int. Jan. 2009;29(Suppl 1):15-8. [pmid: 19207961].
67 Chou R, Clark EC, Helfand M. Screening for Hepatitis C Virus Infection: A Review of the Evidence for the U.S. Preventative Services Task Force. Ann Intern Med. 2004;140(6):465-79. [pmid: 15023713].
68 Gaeta GB, Precone DF, Felaco FM, et al. Premature discontinuation of interferon plus ribavirin for adverse effects: a multicentre survey in ‘real world’ patients with chronic hepatitis C. Alimentary Pharmacology & Therapeutics. Sep. 2002;16(9):1633-9. [pmid: 12197842].
69 Hassan Y, Al-Jabi SW, Aziz NA, et al. Antiplatelet therapy in diabetic ischemic stroke patients: associated factors and outcomes. Int J Clin Pharmacol Ther. Oct. 2011;49(10):605-13. [pmid: 21961485].
70 Rodgers PT, Ruffin DM. Medication nonadherence: Part II--A pilot study in patients with congestive heart failure. Manag Care Interface. Sep. 1998;11(9):67-9. 75. [pmid: 10187590].
71 Misdrahi D, Llorca PM, Lancon C, et al. Compliance in schizophrenia: predictive factors, therapeutical considerations and research implications. Encephale. May. 2002;28(3 Pt 1):266-72. [pmid: 12091789].
72 Sasadeusz JJ, Dore G, Kronborg I, et al. Clinical experience with the treatment of hepatitis C infection in patients on opioid pharmacotherapy. Addiction (Abingdon, England). 2011;106(5):977-84. [pmid: 21205057].
73 Foster GR, Fried MW, Hadziyannis SJ, et al. Prediction of sustained virological response in chronic hepatitis C patients treated with peginterferon alfa-2a (40KD) and ribavirin. Scandinavian Journal of Gastroenterology. Feb. 2007;42(2):247-55. [pmid: 17327945].
74 Dahlan Y, Ather HM, Al-ahmadi M, et al. Sustained virological response in a predominantly hepatitis C virus genotype 4 infected population. World Journal of Gastroenterology. Sep. 21. 2009;15(35):4429-33. [pmid: 19764095].
75 Nakagawa M, Sakamoto N, Ueyama M, et al. Mutations in the interferon sensitivity determining region and virological response to combination therapy with pegylated-interferon alpha 2b plus ribavirin in patients with chronic hepatitis C-1b infection. J Gastroenterol. 2010;45(6):656-65. [pmid: 20112032].
76 Nguyen NH, VuTien P, Garcia RT, et al. Response to pegylated interferon and ribavirin in Asian American patients with chronic hepatitis C genotypes 1 vs 2/3 vs 6. Journal of Viral Hepatitis. Oct. 2010;17(10):691-7. [pmid: 20002562].
77 Arora S, Thornton K, Murata G, et al. Outcomes of Treatment for Hepatitis C Virus Infection by Primary Care Providers. N Engl J Med. Jun. 2011;364(23):2199-207. [pmid: 21631316].
78 Cadranel JF, Boujenah JL, Bourliere M, et al. Satisfaction of patients treated for chronic hepatitis C with the peginterferon alfa-2b pen device: the VISA observational study. Gastroenterologie Clinique et Biologique. Feb. 2007;31(2):180-4. [pmid: 17347628].
79 Castera L, Constant A, Henry C, et al. Impact on adherence and sustained virological response of psychiatric side effects during peginterferon and ribavirin therapy for chronic hepatitis C. Alimentary Pharmacology & Therapeutics. Oct. 15. 2006;24(8):1223-30. [pmid: 17014581].
80 Gujral H, Viscomi C, Collantes R. The role of physician extenders in managing patients with chronic hepatitis C. Cleveland Clinic Journal of Medicine. May. 2004;71(Suppl 3):S33-37. [pmid: 15468616].
81 Ong JP, Younossi ZM. Managing the hematologic side effects of antiviral therapy for chronic hepatitis C: anemia, neutropenia, and thrombocytopenia. Cleveland Clinic Journal of Medicine. May. 2004;71(Suppl 3):S17-21. [pmid: 15468613].
82 Pearlman BL. Hepatitis C treatment update. American Journal of Medicine. Sep. 1. 2004;117(5):344-52. [pmid: 15336584].
83 Scottish Intercollegiate Guidelines Network (SIGN). Management of hepatitis C A national clinical guideline. Edinburgh, Scotland. Scottish Intercollegiate Guidelines Network (SIGN). 2006.
84 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. Apr. 2001;20(3 Suppl):21-35. [pmid: 11306229].
85 Wells GA, Shea B, O’Connell D, et al. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. Ottawa. Ottawa Hospital Research Institute. 2011. www.ohri.ca/programs/clinical_epidemiology/oxford.asp. Accessed March 11, 2011.
86 Bland JM, Altman DG. Statistics notes The odds ratio. BMJ. May. 27. 2000;320(7247):1468. [pmid: 10827061].
87 Agency for Healthcare Research and Quality’s Effective Health Care Program. Medication Adherence Interventions: Comparative Effectiveness. Rockville, MD. 2012.
88 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
89 Atkins D, Chang S, Gartlehner G, et al. Assessing applicability when comparing medical interventions. J Clin Epidemiol. Nov. 2011;64(1198):1207. [pmid: 21463926].
90 Alam I, Stainbrook T, Cecil B, et al. Enhanced adherence to HCV therapy with higher dose ribavirin formulation: final analyses from the ADHERE registry. Alimentary Pharmacology & Therapeutics. Aug. 2010;32(4):535-42. [pmid: 20500732].
91 Cacoub P, Ouzan D, Melin P, et al. Patient education improves adherence to peg-interferon and ribavirin in chronic genotype 2 or 3 hepatitis C virus infection: a prospective, real-life, observational study. World Journal of Gastroenterology. Oct. 28. 2008;14(40):6195-203. [pmid: 18985810].
92 Curcio F, Di MF, Capraro C, et al. Together... to take care: multidisciplinary management of hepatitis C virus treatment in randomly selected drug users with chronic hepatitis. Journal of Addiction Medicine. Dec. 2010;4(4):223-32. [pmid: 21769040].
93 Hussein M, Benner JS, Lee D, et al. Propensity score matching in the evaluation of drug therapy management programs: an illustrative analysis of a program for patients with hepatitis C virus. Qual Manag Health Care. Jan. 2010;19(1):25-33. [pmid: 20042931].
94 Larrey D, Salse A, Ribard D, et al. Education by a Nurse Increases Response of Patients With Chronic Hepatitis C to Therapy With Peginterferon-alpha2a and Ribavirin. Clinical Gastroenterology and Hepatology. 2011;9(9):781-5. [pmid: 21683161].
95 Liu SS, Schneekloth TD, Talwalkar JA, et al. Impact of depressive symptoms and their treatment on completing antiviral treatment in patients with chronic hepatitis C. J Clin Gastroenterol. Sep. 2010;44(8):e178-e185. [pmid: 20495464].
96 Morasco BJ, Loftis JM, Indest DW, et al. Prophylactic antidepressant treatment in patients with hepatitis C on antiviral therapy: a double-blind, placebo-controlled trial. Psychosomatics. Sep. 2010;51(5):401-8. [pmid: 20833939].
97 Ramsey SE, Engler PA, Stein MD, et al. Effect of CBT on Depressive Symptoms in Methadone Maintenance Patients Undergoing Treatment for Hepatitis C. J Addict Res Ther. May. 13. 2011;2(2):2-10. [pmid: 21743837].
98 Bruce RD, Eiserman J, Acosta A, et al. Developing a modified directly observed therapy intervention for hepatitis C treatment in a methadone maintenance program: implications for program replication. American Journal of Drug & Alcohol Abuse. May. 2012;38(3):206-12. [pmid: 22242700].
99 Patel K, Dev A. Adherence to antiviral therapy in chronic hepatitis C. Current Hepatitis Reports. Mar. 1. 2004;3(1):10-5.
100 Thompson MA, Mugavero MJ, Amico KR, et al. Guidelines for improving entry into and retention in care and antiretroviral adherence for persons with HIV: evidence-based recommendations from an International Association of Physicians in AIDS Care panel. Ann Intern Med. Jun. 5. 2012;156(11):817-284. W. [pmid: 22393036].
101 Staines GL, Cleland CM. Observational studies versus randomized controlled trials of behavioral interventions in field settings. Review of General Psychology. 2012;16(1):37-58.
102 Jepsen PF, Johnsen SP FAU, Gillman MW FAU, et al. Interpretation of observational studies. Heart. 2004. 1468-201X [Electronic]. [pmid: 15253985].
103 Williamson E, Morley R, Lucas A, et al. Propensity scores: From naive enthusiasm to intuitive understanding. Stat Methods Med Res. Jun. 2012;21(3):273-93. [pmid: 21262780].
104 Vrijens B, De GS, Hughes DA, et al. A new taxonomy for describing and defining adherence to medications. Br J Clin Pharmacol. May. 2012;73(5):691-705. [pmid: 22486599].
105 Bruce RD. Effective Treatment of Hepatitis C in Substance Users. 2008. http://clinicaltrials.gov/ct2/show/NCT00633243.
106 Klein MB, Cooper C, Brouillette MJ, et al. CTN-194 (PICCO): design of a trial of citalopram for the prevention of depression and its consequences in HIV-hepatitis C co-infected individuals initiating pegylated interferon/ribavirin therapy. Contemporary Clinical Trials. Jul. 2008;29(4):617-30. [pmid: 18262853].
107 Litwin AH, Berg KM, Li X, et al. Rationale and design of a randomized controlled trial of directly observed hepatitis C treatment delivered in methadone clinics. BMC Infect Dis. Nov. 12. 2011;11:315. [pmid: 22078241].
108 North CS. Psychoeducation for Hepatitis and Alcohol Behaviors. 2008. http://clinicaltrials.gov/ct2/show/NCT00598416.
109 Shun SS. Effects of Activity and Education Program on Patients With Chronic Hepatitis C Infection. 2012. http://clinicaltrials.gov/ct2/show/NCT01572233.
110 Sulkowski M. Management of Hepatitis C in HIV Infected Injection Drug Users (IDUs). 2011. http://clinicaltrials.gov/ct2/show/NCT01448915.
111 Weiss JJ, Ferrando SJ. Armodafinil for Patients Starting Hepatitis C Virus Treatment. 2011. http://clinicaltrials.gov/ct2/show/NCT01470651.