# Methods

The Agency for Healthcare Research and Quality (AHRQ) requested a CER on the effectiveness of Hepatitis C treatment adherence interventions as a part of its Effective Health Care (EHC) Program. The Evidence-based Practice Center (EPC) established a team and a protocol to develop this evidence report.

## Topic Development and Refinement

The topic for this report was nominated through a public process. The Scientific Resource Center (SRC) for the AHRQ EHC Program compiled information about this topic to evaluate its priority for CER. EHC Program staff evaluated and discussed this information and it was approved for a full review.

The Oregon EPC drafted a topic refinement document with proposed Key Questions after consulting with five Key Informants. Key Informants included representatives from Hepatitis C patient advocacy groups, gastroenterologists, and infectious disease experts. Key Questions were posted on AHRQ’s Web site for public comment in July 2011 for four weeks, and were revised as needed. We then drafted a protocol for the CER and recruited a Technical Expert Panel (TEP) to provide high-level content and methodological expertise throughout the review. The TEP comprised five individuals who specialized in Hepatitis C treatment, treatment adherence, and systematic review methodology. The TEP was established to ensure scientific rigor, reliability, and the methodological soundness of the research. The TEP commented on the review protocol and offered advice on the review process. The final review protocol can be found on AHRQ’s EHC Program Web site: http://www.effectivehealthcare.ahrq.gov/ehc/products/326/839/HepatitisC-Adherence_Protocol-amended_20120522.pdf.

## Analytic Framework

The analytic framework for evaluating the comparative effectiveness of Hepatitis C treatment adherence interventions is shown in Figure 1. In general, the figure illustrates how Hepatitis C treatment adherence interventions may affect adherence, intermediate outcomes (e.g., early viral response, sustained viral response, drug resistance), and/or ultimate health outcomes (e.g., morbidity, mortality, and QOL). Figure 1 also depicts the possibility of adverse events or harms occurring after exposure to an adherence intervention. We did not systematically review the association between intermediate outcomes and final health outcomes.

Figure 1 Analytic framework

HCV = hepatitis C virus

Note: Numbers in circles refer to Key Questions.

This figure depicts the key questions within the context of the PICOTS described in the next section. In general, the figure illustrates how Hepatitis C treatment adherence interventions may result in improved treatment adherence; intermediate outcomes such as early viral response, sustained viral response, histological changes, biochemical markers, drug resistance, relapse rate, adherence; and/or long-term outcomes such as morbidity, mortality, quality of life, or transmission of HCV. Also, adverse events may occur at any point after the intervention is received.

## Literature Search Strategy

A research librarian performed comprehensive literature searches in the following databases:

- MEDLINE^®^ accessed via Ovid
- PubMed^®^
- Cochrane Central Register of Controlled Trials (CENTRAL)
- PsycInfo
- EMBASE
- Cumulative Index to Nursing and Allied Health Literature (CINAHL)

Appendix A outlines our search strategy for each database. We used these searches to locate relevant studies for all three Key Questions. We restricted searches to the time period of January 2001 to June 20, 2012. We chose 2001 because pegIFN-α received FDA approval in 2001. We supplemented searches of these databases with manual searching of reference lists of relevant review articles and suggestions made by TEP members. We also conducted an ancillary search of the non-English language literature to identify the volume of publications that would have been reviewed if we included non-English-language studies. We also searched ClinicalTrials.gov to identify any trials currently underway that may meet our inclusion criteria once the results are available (Appendix B). Finally, we sent a request to the manufacturer of RibaPak^®^ for scientific information that might be relevant to our review.

We downloaded and imported our search results in version 12.0.3 of Reference Manager^®^ (Thomson Reuters, New York, NY), a bibliographic management database. We manually removed duplicates. We used Reference Manager to track search results at the levels of title/abstract review and article inclusion/exclusion.

## Process for Study Selection

We used a two-step process for study selection. First, two members of the research team independently reviewed each title and abstract (if available) to determine if an article met the broad inclusion/exclusion criteria for study design, population, and intervention (Table 3). We coded each title/abstract as: potentially included, excluded, or background. Next, we retrieved full-text articles for all potentially included studies, including those that were questionable or unclear at the abstract stage. Two reviewers independently assessed each full-text article using a standard form that detailed the predetermined inclusion and exclusion criteria. We resolved disagreements through discussion.

Table 3 Inclusion and exclusion criteria

Category | Inclusion Criteria | Exclusion Criteria
Population | Adults undergoing combination HCV antiviral therapy with pegIFN-α 2a or 2b and ribavirin, or Combination therapy with pegIFN, ribavirin, and HCV protease inhibitors | Adults undergoing: HCV monotherapy Long-term HCV maintenance therapy (longer than 52 weeks) Children (<18 years) Patients for whom HCV treatment is contraindicated: Pregnant women Patients with renal failure Hemodialysis patients Transplant recipients
Interventions | Treatment adherence interventions
Comparator | Other treatment adherence interventions or usual care
Outcomes | Key Question 1: All-cause mortality HCV-specific mortality QOL Transmission of HCV Liver transplants Liver complications (cirrhosis, liver failure, liver cancer) Change of HCV RNA from baseline Liver function (i.e., change in ALT level from baseline) Histological response (i.e., reduction in fibrosis) Early viral response Sustained viral response HCV relapse rates Key Question 2: Frequency Dosage Treatment length (duration) Timing Key Question 3: Adverse events | Costs
Time period | 2001 to present | Studies prior to 2001
Setting | All settings | Not applicable
Study geography | All locations | Not applicable
Publication language | English | All other languages
Study design | RCT of any design (i.e. parallel, cross-over, factorial, cluster) Controlled clinical trial Prospective cohort study Retrospective cohort study Case-control study | Single case studies Cross-sectional studies Case series
Minimum followup | KQ 1–2: 12 weeks postbaseline KQ3: any
Study quality | Any

ALT = alanine transaminase; HCV = hepatitis C virus; KQ = Key Question; pegIFN = pegylated interferon; pegIFN-α = pegylated interferon alpha; QOL = quality of life; RCT = randomized controlled trial; RNA = ribonucleic acid; vs. = versus

## Data Abstraction and Data Management

We abstracted data from all included studies into a standard evidence table. One investigator abstracted the data and a second checked these data. Discrepancies regarding data abstraction were resolved by rereview, discussion, and comments from others. We collected the following information for each study, where available: author identification; year of publication; study location; study design; recruitment setting and approach; inclusion/exclusion criteria; demographic and health characteristics of the sample including baseline HCV severity (as defined by the individual study [e.g. fibrosis stage, baseline viral load]); description of intervention and control arms (or exposed and nonexposed cohorts); and sample retention. We abstracted the following outcomes: patient adherence, definition and method of adherence measurement, health outcomes (EVR, SVR, histological and biochemical responses), QOL, and adverse events.

## Individual Study Quality Assessment

We used predefined criteria developed by the USPSTF84 and the Newcastle-Ottawa Quality Assessment Scale85 (specific to cohort studies) to assess the internal validity of included studies. Two independent reviewers assigned a quality rating of the internal validity for each study. Disagreements were resolved by discussion and consensus. We assigned a rating of “good,” “fair,” or “poor” to each study using predefined criteria for studies meeting inclusion criteria. For randomized controlled trials (RCTs), specific areas assessed included:

- Adequate randomization, including allocation concealment and whether potential confounders were comparable among groups
- Measurements: equal, reliable, and valid
- Blinding of patients, providers, and outcome assessors
- Adequacy of followup
- Intervention fidelity and compliance with the intervention
- Appropriate analysis (e.g., intention-to-treat)

For cohort studies, specific areas assessed included:

- Selection of the nonexposed cohort
- Ascertainment of exposure
- Demonstration that the outcome of interest was not present at start of study
- Measurements: equal, reliable, and valid (including blinding of outcome assessment)
- Adequacy of followup of cohorts
- Matching or adjustment for potential confounders

We used these items to evaluate the internal validity. Generally, a good-quality study met all major criteria, although it was possible to get a “good” rating if an item was not reported (so could not be assessed) if the remaining methods were judged to be “good.” A fair-quality study did not meet all criteria, but was judged to have no flaws so serious that they invalidated the results. A poor-quality study contained a serious flaw in design, analysis, or execution, such as differential attrition, or some other flaw judged serious enough to cast doubt on the results’ validity. Examples of serious flaws include: very large baseline group differences that were not or could not be adjusted for in the analysis, no information about followup, or insufficient information provided so we could not judge the risk of bias.

## Data Synthesis

We summarized all included studies in narrative form as well as in summary tables that present the important features of the study populations, design, intervention, outcomes, and results. We reported odds ratios (ORs) for dichotomous outcomes. When studies did not report effect estimates, but did provide sufficient raw data, we calculated ORs using an approximation method.86 Because of the significant clinical and methodological heterogeneity of studies, and poor reporting of results, we did not conduct any pooled analysis. We conducted a qualitative analysis for all Key Questions and stratified the comparisons into four groups based on the primary intervention focus: (1) system-level interventions versus usual care, (2) regimen/therapy-related interventions versus usual care, (3) patient-level interventions versus usual care, and (4) adverse event management interventions versus usual care or placebo. We developed this classification system based on two previous systematic reviews that evaluated the effect of adherence interventions for various disease conditions.57,87 There was no literature included that addressed policy-level interventions. We discuss outcomes for each of the four groups separately.

## Grading the Strength of Evidence

We graded the strength of the evidence for all outcomes using the standard process of the Evidence-based Practice Centers outlined in the AHRQ Methods Guide for Effectiveness and Comparative Effectiveness Reviews.88 Specifically, we assessed the strength of evidence for the subset of major outcomes that are most meaningful for each of the Key Questions. These outcomes included the final health outcomes of QOL, morbidity/mortality, and harms and intermediate outcomes of SVR and EVR, and adherence. The grade of evidence is based on four major domains: (1) risk of bias (low, medium, high), (2) consistency (no inconsistency present, inconsistency present, unknown or not applicable), (3) directness (direct, indirect), and (4) precision (precise, imprecise). The risk of bias domain reflects the degree to which the included studies for a given outcome or comparison were very likely to be adequately protected from the impact of bias in their reported estimates of effect. Low risk of bias suggests a high likelihood that bias is not a major factor. We evaluated risk of bias considering both study design and aggregate quality of the studies. Consistency refers to the degree to which reported effect sizes from included studies appear to have the same direction and magnitude of effect. When only a single study was included, consistency could not be judged. Directness relates to whether the evidence links the interventions directly to health outcomes. Precision refers to the degree of certainty surrounding an effect estimate with respect to a given outcome. We assigned an overall strength of evidence grade based on the ratings for these four individual domains for each key outcome and for each comparison of interest. The overall strength of evidence was rated using four basic grades (as described in the AHRQ Methods Guide): high, moderate, low, or insufficient (Table 4).88 We rated the evidence as insufficient when no studies were available for an outcome or comparison of interest or the evidence was limited to small trials that are methodologically flawed and/or highly heterogeneous. Ratings were assigned based on our judgment of the likelihood that the evidence reflected the true effect for the major comparisons of interest.

Table 4 Strength of evidence grades and definitions

Grade | Definition
High | High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
Moderate | Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
Low | Low confidence that the evidence reflects the true effect. Further research is likely to change the confidence in the estimate of effect and is likely to change the estimate.
Insufficient | Evidence is unavailable or does not permit a conclusion.

## Applicability

To assess applicability, we used data abstracted on the population studied, the intervention and comparator, the outcomes measured, settings (including cultural context), and timing of assessments to identify specific issues that may limit the applicability of individual studies or the body of evidence to the U.S. health care settings, as recommended in the AHRQ Methods Guide.89 We used these data to evaluate applicability, paying particular attention to study eligibility criteria, inclusion/exclusion criteria, baseline demographic factors, and the intervention characteristics (e.g., setting).

## Review Process

A full draft report was reviewed by experts and posted for public commentary from July 11, 2012 through August 8, 2012. Comments received from either invited peer reviewers or through the public comment Web site were compiled and addressed in a disposition of comments table. The disposition of comments will be posted three months after the final report is posted on the EHC Web site.