# Introduction

## Condition Definition

Hepatitis C is an infectious liver disease caused by the hepatitis C virus (HCV). Chronic HCV infection is associated with an increased risk of liver complications, such as cirrhosis, liver failure, and hepatocellular carcinoma (HCC).1

## Prevalence and Disease Burden

HCV is the most common chronic blood-borne infectious disease in the United States.2,3 The Centers for Disease Control and Prevention estimated that 16,000 Americans were newly infected in 2009, and between 2.7 and 3.9 million community-dwelling persons were living with chronic HCV infection.3 When prevalence estimates specifically include individuals that are not typically part of national surveillance (i.e., those who were incarcerated, homeless, nursing home residents, hospitalized patients, on active military service, or immigrants), this number climbs to 5.2 million.2 Additionally, in June 2012, the CDC recommended universal HCV screening of the “baby boomer” population (i.e., individuals born between 1945 and 1965).4 Such screening could result in a substantial increase in the number of individuals being infected with HCV.

The prevalence of HCV infection in men is roughly double the rate for women. The prevalence is also highest in non-Hispanic blacks, compared to all other ethnic groups. Individuals born from 1945 through 1965 are five times more likely than other American adults to be infected HCV. Age-related prevalence is highest (4.3%) among individuals who were 40 to 49 years of age from 1999 through 2002.^5^ The prevalence also increases with lower family income and education.6 Injection drug users are among those at greatest risk of HCV infection, with an estimated prevalence of 73.4 percent among adults in the United States with a history of injection drug use.7 The prevalence of HCV is also estimated to be 4 to 9 times higher among individuals with severe persistent mental illness than in the general population.8 In addition, nearly 10 percent of those with chronic HCV infection in the United States are co-infected with HIV. Historically, many of these high-risk groups were considered ineligible for treatment given their previous or hypothesized nonadherence to treatment.9,10

## Etiology and Natural History of Hepatitis C Infection

HCV is primarily transmitted through large and repeated percutaneous exposure to infected blood.11 While the most common mode of HCV transmission in the United States is through the use of injection drugs, HCV can also be transmitted through needle-stick injuries and vertical transmission from an infected mother to infant. Less-common modes of transmission include sexual activities with an HCV-infected person and receipt of donated blood or blood products or organs.11

Hepatitis C ribonucleic acid (RNA) can be detected in the blood within 2 weeks after the initial infection with the virus. HCV antibodies can be identified at 8 to 12 weeks after infection.12 Acute HCV infection can cause symptoms such as jaundice, fatigue, nausea, and vomiting in 15 percent of infected cases.13 Fifty-five to 85 percent of patients with acute HCV infection develop chronic HCV infection.12

Chronic hepatitis C is defined as failure to clear the HCV within 6 months of acute viral infection.1 Chronic HCV infection leads to progressive liver fibrosis and 10 to 15 percent of chronic HCV infected patients develop cirrhosis within 20 years.14 One to 4 percent of those with established cirrhosis progress to HCC annually.1 Factors associated with an increased risk of cirrhosis and HCC in those with chronic HCV include: aged 40 years or older, daily alcohol consumption of 50 grams or more, co-infection with hepatitis B virus (HBV), HIV, and male gender.15

## Hepatitis C Virus Genotypes and Detection

HCV is a RNA virus16 with six major genotypes. In the United States, 75 percent or more of patients are infected with the genotype 1 virus, followed by genotypes 2 (16%) and 3 (8%).17,18 Genotyping is among the best predictor of viral response to treatment and is used to determine treatment duration, and more recently the specific treatment, in hepatitis C management.12

HCV infection can be detected through an antiHCV serological assay or one of several molecular assays designed to identify HCV RNA.12 Third-generation serological assays (e.g., enzyme-linked immunosorbent assay [ELISA]) have a sensitivity of 97.2 percent and specificity of over 99 percent in patients with chronic liver disease when appropriately timed.19 The likelihood of false negatives, however, increases in the presence of immunosuppressive conditions such as HIV.20 Molecular assays, including polymerase chain reaction (PCR) and transcription-mediated amplification (TMA) techniques, are sensitive to HCV RNA levels as low as 10 to 50 IU/mL and have a specificity of 98 to 99 percent.21,22 Both of these molecular assay techniques can quantitatively analyze HCV RNA and are often used to diagnose and monitor treatment response.12

## Treatment of Chronic Hepatitis C Infection

The primary goal of chronic HCV detection and treatment is preventing complications and death from HCV infection. Treatment response is typically defined by surrogate virological measures, such as sustained viral response (SVR) and early viral response (EVR). SVR indicates long-term viral clearance and is defined as the absence of detectable HCV RNA in the serum 24 weeks following the end of therapy.12 Early viral response is defined as a ≥2 log reduction in HCV RNA levels, compared to baseline HCV RNA level, or an undetectable viral load at 12 weeks of therapy. Early viral response is a strong predictor of achieving SVR.12

Until early 2011, the standard antiviral therapy for chronic HCV infection was a combination of pegylated interferon-alpha (pegIFN-α) (α2a or α2b) administered once-weekly by subcutaneous injection in combination with twice-daily oral ribavirin (so-called “dual therapy”). Dual therapy is typically administered for 24 weeks in patients infected with HCV genotype 2 or 3 and is administered for 48 weeks in patients with HCV genotypes 1 or 4.^12,23^ The effects of antiviral dual therapy for HCV have been examined in a large number of randomized trials and systematic reviews, including a recent AHRQ-funded comparative effectiveness review (CER).24–30 These studies have consistently shown that the combination of pegIFN-α with ribavirin improves SVR and biochemical response. These studies have also shown this combination may improve histological response, compared to monotherapy or combination therapy with consensus interferon (interferon used before pegIFN-α became available).

In May 2011, the Food and Drug Administration (FDA) approved two novel protease inhibitors (boceprevir and telaprevir) to treat chronic HCV infection. The treatment regimen for these new agents is more complex. According to the American Association for the Study of Liver Diseases (AASLD) Practice Guideline, the protease inhibitors be used in combination with existing antiviral drugs (so-called “triple therapy”) for genotype 1 HCV-infected patients.31 The duration of triple therapy treatment varies depending on patient characteristics (e.g., treatment naïve vs. previously treated; presence vs. absence of cirrhosis), type of protease inhibitor, and is contingent on achieving a satisfactory level of EVR (e.g., 4 and 12 weeks).

Studies have shown that a variety of factors affect treatment response. These factors include viral or disease-related factors, including HCV genotype and disease severity; treatment-related factors such as the dose and duration of treatment and history of prior treatment; and several patient-related factors (i.e., age, ethnicity, and the presence of comorbid conditions).9,30–37 HCV genotype is one of the most important factors affecting treatment response. Individuals who are infected with genotype-1 HCV, for example, are the least likely to respond to dual therapy.38,39 Medication and medical plan adherence also affects response to treatment in addition to viral, disease, and patient-related factors.

Fully adhering to recommended HCV treatment is particularly challenging given its demands, which include the lengthy treatment duration and the adverse events associated with treatment that are common among many patients. Adverse events include fatigue, depression, flulike symptoms, anemia, dermatologic effects, and gastrointestinal events.40,41,41,42 Some of these events can also be severe enough to necessitate clinician-directed dose reductions or discontinuation of treatment.

Because of this, articulating how patient adherence independently impacts treatment response is a very complex matter in HCV. This deliberation must account for differences in clinical recommendations (initially and over the course of treatment) and differences in virus-related, disease-related, and patient-related factors that impact the likelihood of treatment response. As outlined in Table 1, separating the variables that are associated with a lower likelihood of treatment response (as measured by SVR) from those associated with a lower likelihood of patient adherence is conceptually very important. Understanding the different roles these “risk factors” play in treatment response is critical for interpreting the role of confounding in studies of patient adherence interventions (since outcomes are generally measured by SVR), the comparability of study findings, and the applicability to the United States health care setting. Risk factors related to response to treatment and patient nonadherence are discussed below.

Table 1 Variables that may affect viral response and adherence to treatment

Variable | | Response to Treatment (SVR) | Patient Adherence to Treatment
Viral-related | Genotype | ↓ with genotype 1^30^ | Not a major factor
Viral-related | Pretreatment Viral Load | ↓with higher viral load | Not a major factor
Viral-related | Genetic variations | IL28B gene43 | No data suggesting association
Treatment-related | History of Prior Treatment | ↓with prior treatment vs. treatment naive32 ↓ with nonresponders vs. relapsers for retreatment | Mixed
Treatment-related | Treatment burden and adverse events management | Not a major factor | ↑with adverse events management9,44 ↓with higher pill burden and length of treatment45
Treatment-related | Provider Experience & type of facility (high vs. low volume) | Not a major factor | ↑with high volume site and/or provider experience32,46
Patient-related | Demographics | ↓with older age and male30 ↓in African American30,33 ↓in Hispanic33,34 | Not a major factor^*,34,46^
Patient-related | Mental Health | Not a major factor9,35 | ↓with treatment-related depression when not managed9 Not a major factor when patients receive mental health treatment9,35,47,48
Patient-related | Substance Abuse | Not a major factor as long as patients adhere to treatment9,36 | ↓with active substance abuse9,36,49 Not a major factor in patients in substance treatment or abstaining48,50–52
Patient-related | Comorbid Medical Conditions | ↓ with medical comorbidities30,37,53 | Not a major factor^†,46^
Patient-related | Disease Stage | ↓with fibrosis/cirrhosis30 | ↓with cirrhosis^‡,46^
Patient-related | Socioeconomic status/ social supports | No data suggesting association54 | Mixed45,54,55

SVR = sustained viral response; vs. = versus

* African-Americans may have decreased adherence vs. Caucasians33.

† Coinfected HIV/HCV in some studies shows higher patient adherence;49 however, treating both HIV and HCV at once is associated with an increase in adverse events and a need for clinician-directed reduction in treatment dosages or discontinuation of treatment, especially in women.

‡ May be clinician-directed for adverse events of treatment.

## Adherence in the Context of Chronic Hepatitis C Treatment

In the medical literature, the terms adherence, compliance, and concordance all generally refer to the extent to which individuals follow their providers’ recommended treatment advice.45,55–58 Patients often have difficulties adhering to medication regimens, particularly those with chronic diseases. Even within the context of clinical trials, where patients may be closely monitored, adherence rates may average only between 43 to 78 percent.59

Adherence to therapy may be particularly challenging for patients undergoing antiviral therapy for Hepatitis C. Adherence, in the context of HCV treatment, includes patient adherence to both the medication regimen and the overall medical plan. Medication adherence is defined as the patient’s use of antiviral agents according to the prescribed dose, duration, frequency, and timing. In contrast, medical plan adherence indicates that patients complete followup visits, laboratory tests, or other medical procedures according to the physician’s directions. In this report, we refer to adherence to medication and adherence to the overall medical plan during HCV treatment as patient adherence, or “adherence” more generally.

Adverse events of hepatitis C antiviral therapy may lead physicians to initiate dose reductions or treatment discontinuation.12 This can complicate the distinctions between patient-led nonadherence that would be amenable to improvement and appropriate clinical care that can result in poorer treatment responses. The most common cause of physician-led treatment change is the presence of laboratory abnormalities (e.g., anemia), for which patients usually do not experience symptoms.12 Physicians may also advise patients who do not exhibit early viral response to stop therapy.12 As such, physician-led dose reductions and treatment discontinuation should not be viewed as treatment nonadherence because they do not reflect patient deviation from an agreed treatment recommendation. Unfortunately, many studies fail to report data on physician-led dose reduction or treatment discontinuation separately from patient-directed treatment reduction or discontinuation.45,60,61 Thus, in the HCV literature the reported “adherence” data commonly reflect a mixture of actual patient nonadherence (e.g., missed doses by active decision or simply forgetting ) and physician-directed dose reductions or treatment discontinuation data.

Using complex combination drug regimens (dual or triple therapies), with varying lengths of treatment that depend on viral genotype (48 weeks for genotype 1 and 4, and 24 weeks for genotype 2 and 3) also complicates the issue. Measuring adherence to HCV treatment requires considering multiple components, including the type of agents (i.e., pegIFN, ribavirin, and protease inhibitors) and the treatment duration by genotype (24 vs. 48 weeks).

With no current standard for measuring hepatitis C treatment adherence, various adherence measures have been used in the hepatitis C literature. While some studies define adherence as a patient taking 80 percent or more of the total prescribed dose, other studies define patients as adherent if they comply with treatment for 80 percent or more of the prescribed duration.39,62,63 Other studies, however, do not use a prespecified threshold.64,65 The most commonly used measure of adherence in the HCV literature is the “80/80/80” rule, which is defined as greater than 80 percent adherence to the total number of ribavirin and interferon doses, greater than 80 percent of required dosage of one or both drugs, for greater than 80 percent of the expected duration of therapy.39

Several methods are available to collect hepatitis C treatment adherence data, including DOT, patient self-report, electronic monitoring (e.g. Medication Event Monitoring Systems [MEMS] technology such as MEMS caps^®^), pharmacy refill data, subject diaries, and pill counts.45 The strengths and limitations of these methods have been detailed elsewhere.45,59

## Risk Factors for Nonadherence to Antiviral Treatment

Understanding the factors that increase a patient’s risk of nonadherence to HCV treatment is a crucial first step in evaluating the success of adherence interventions. Known risk factors for nonadherence to HCV treatment include active substance abuse, nonmanaged treatment related depression, a lack of social support, the patient’s current or previous treatment experience and disease status, provider inexperience or receiving care at a low-volume facility, and poor symptom or side effect management (Table 1).32,46,59,66,67 Physicians commonly exclude patients with suspected risk factors for nonadherence from treatment because of the concerns about the emergence of resistant viral strains and possible decreased treatment response, although the appropriateness of this practice has been debated.10,45

A large, retrospective cohort study investigated the risk factors for nonadherence to HCV treatment in a population of genotype 1 HCV infected Veterans Affair’s patients (n=11,019).46 In patients who achieved EVR, the investigators found that cirrhosis, a history of substance abuse, anemia, and a lack of hematopoietic growth factor use were all statistically significant, independent risk factors for early treatment discontinuation prior to completing 12 weeks of treatment. This study also found that lack of growth factor use was a statistically significant risk factor for patient nonadherence during 12 to 24 weeks of treatment, along with depression.46 Likewise, separate studies have found that a patient’s treatment history played a significant role in early discontinuation of treatment, with those naïve to treatment being found to have an increased risk of nonadherence.32,68

## Association of Adherence With Sustained Viral Response

Studies have shown that fully completing a recommended treatment course improves treatment outcomes in both infectious and chronic diseases.59,69–71 As such, clinicians and patients rightly seek to know what is the minimal level of adherence associated with improved treatment response. While some studies have considered this issue for chronic HCV, no study has provided a definitive answer. Several studies have examined the association between adherence and SVR;44,72–76 however, it is difficult to quantify this association, in part due to heterogeneous measurement approaches. Definitions of adherence measures, for example, vary across these studies in ways that could impact SVR. One study measured adherence using the commonly cited “80/80/80” rule,72 while another study less-stringently defined patients as adherent if they completed of 80 percent or more of planned duration.73 A third study identified patients as adherent if they completed the full treatment duration,74 while another study defined adherence as completion of 80 percent of recommended dose of pegIFN and 80 percent of the intended duration of ribavirin.76 Two other studies44,75 did not specify a predefined threshold. Rather, they divided patients according to multiple strata of adherence (≤40%, 41–50%, 51–60%, 61–70%, 61–80, 81–90%, 91–100% of treatment completion). The fact that none of the studies examining the relationship between adherence and SVR clearly differentiated between patient- and provider-directed dose reduction or treatment discontinuation further complicates this issue. In two studies,73,74 patients categorized as “nonadherent” likely included those who were directed by their physicians to discontinue treatment.

In analyzing the association between adherence and SVR, three studies72,74,75 conducted unadjusted analyses, while three others38,44,73,76 conducted multivariable regression analyses to control for the influence of other factors. These factors included: baseline viral load, age, body mass index (BMI), genotype, presence of fibrosis, treatment duration, ribavirin dose, and/or race.44,73,76 In the two studies that performed unadjusted analyses,74,75 more than half of patients with good adherence (≥80%) achieved SVR, compared to approximately 10 percent of patients with poor adherence (<60%). Four studies performing adjusted analyses also found a relationship between higher levels of adherence and a higher probability of patients achieving SVR, but with inconsistent levels of association between SVR and adherence.38,44,73,76

Despite limitations related to measurement and potential confounding, the existing body of literature consistently shows that achieving an increased level of adherence to dual therapy is associated with improved likelihood of SVR. In one study of treatment naïve Asian American HCV patients, the association between adherence and SVR was similar in both unadjusted and adjusted analyses (inclusive of sex, age, BMI, viral load, and genotype) (unadjusted odds ratio [OR] 3.73 vs. adjusted odds ratio [ORadj] 3.49), which suggests that these other factors may not influence this association.76 Another study reporting the adjusted association of SVR with different levels of adherence (≤40%, 41–50%, 51–60%, 61–70%, 61–80, 81–90%, 91–100%) found that higher adherence levels were associated with improved SVR (trend test p=0.005). This result implies that the association may be continuous.44 This study also demonstrated that patients with similar levels of adherence with genotype 2 or 3 consistently achieved higher SVR, compared to patients with genotype 1 or genotype 4. This suggests that genotype may be an important modifier of the association between adherence and SVR; thus, it would be prudent to explore the association separately in patients with genotype 1 or 4 and 2 or 3.

## Interventions for Improving Adherence

Adherence interventions can be categorized according to the primary risk factor targeted: (1) policy-level interventions, (2) system-level interventions, (3) provider-level intervention,( 4) regimen- or therapy-related interventions, (5) patient-level interventions, or (6) interventions designed to help manage adverse events (Table 2). This final category may be particularly relevant to chronic hepatitis C patients receiving antiviral therapy, given the noted treatment side effects. These adherence interventions are often multi-faceted and can be used alone or in combination.

Table 2 Types of interventions for improving patient adherence

Type of Intervention | Examples
Policy-level interventions | Decreasing insurance copay and refill practices Change in prescription formularies
System-level interventions | Increasing convenience of care (e.g., provision at worksite or home) Care coordination Programmed reminder systems Appointment and prescription refill reminders DOTS Augmented pharmacy services
Provider-level interventions | Training regarding communication style and enhancing shared decision-making Training on the use of motivational enhancement techniques
Regimen/Therapy-related interventions | Simplified dosing Dose-dispensing units of medication and medication charts Different medication formulations (e.g., tablet vs. syrup)
Patient-level interventions | Education/instruction for patients (e.g., verbal, written materials) Counseling (about disease, importance of therapy and compliance, empowerment, etc.) Automated telephone, computer-assisted patient monitoring and counseling Special ‘reminder’ pill packaging Family interventions Self-monitoring Reinforcement or rewards for adherence Lay health mentoring
Adverse event management interventions | Psychological therapy (e.g., CBT) Medications to manage side effects

CBT = cognitive behavioral therapy; DOTS = direct observation treatments; vs. = versus

Interventions designed to increase patient adherence to chronic HCV treatment can include one or more specific components, such as: detailed instructions to patients (e.g., written instructions), increased communication and counseling (e.g., telephone followup, regular counseling programs, medication use training), increasing convenience of medication use (e.g., simplifying drug dosing, tailoring the treatments to daily habits), reminder systems (e.g., devices such as MEMS caps, appointment schedules, medication charts), and reinforcement or incentives for maintaining compliance with treatment (e.g., simplifying clinic visits).58,77–82 These interventions can be delivered and/or implemented by various professionals including clinicians, pharmacists, case managers, psychologists, or insurance or other policy makers in the case of policy- or system-level interventions or can be managed by multidisciplinary teams.

## Scope and Purpose

No systematically reviewed evidence addresses the impact of HCV treatment-adherence interventions on health outcomes, intermediate outcomes, or adherence itself. A previous systematic review on screening for hepatitis C completed in 2004 for the U.S. Preventative Services Task Force (USPSTF) included only a limited discussion on treatment adherence and found that 14 to 22 percent of patients receiving the recommended combination therapy of pegIFN-α plus ribavirin discontinued treatment.67 Another review descriptively summarized previous studies addressing treatment adherence for HCV antiviral therapy.45 Of the nine published guidelines for HCV management, including the AASLD practice guideline, only one discussed treatment adherence, and this discussion was very brief.83

We assessed the comparative effectiveness of treatment adherence interventions for adults receiving standard combination antiviral therapy for chronic HCV infection in this review. The outcomes of interest include all-cause mortality and HCV-specific mortality, liver complications (cirrhosis, liver failure, and liver cancer), quality of life (QOL), transmission of HCV, sustained and early viral response, biochemical response (e.g., alanine transaminase [ALT] level), histological response, and patient adherence.

## Key Questions

This report addresses three systematically reviewed key questions that consider the impact of adherence interventions on health outcomes, intermediate outcomes including adherence, and harms related to adherence interventions in the treatment of chronic HCV.

Key Question 1 In adult patients with chronic HCV infection undergoing antiviral therapy, what is the comparative effectiveness of treatment adherence interventions in improving intermediate (e.g., sustained viral response, histological changes, drug resistance, relapse rates, and treatment side effects) and health outcomes (e.g., disease-specific morbidity, mortality, QOL, transmission of HCV)?
  a. Does the comparative effectiveness of treatment adherence interventions differ by patient subgroups?
Key Question 2 What is the comparative effectiveness of treatment adherence interventions in improving treatment adherence (e.g., medication adherence; medical plan adherence)?
  a. Does the comparative effectiveness of treatment adherence interventions in improving treatment adherence differ by patient subgroups?
Key Question 3 What are the harms associated with hepatitis C antiviral treatment adherence interventions?