# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

Imtiaz Alam, M.D.

Medical Director

Austin Hepatitis Center

Austin, TX

Terrence Blaschke, M.D.

Emeritus Faculty

Department of Medicine

Stanford University

Stanford, CA

Donna Evon, Ph.D.

Assistant Professor

Division of Gastroenterology and Hepatology

University of North Carolina

Chapel Hill, NC

Joel J. Gagnier, Ph.D., N.D., M.S.C.

Assistant Professor

Department of Orthopaedic Surgery Epidemiology

University of Michigan

Ann Arbor, MI

Daniel Hartung, Pharm.D., M.P.H.

Assistant Professor

College of Pharmacy

Oregon State University

Corvallis, OR

Alain H. Litwin, M.D., M.S.

Associate Professor

Clinical Medicine and Psychiatry

Albert Einstein College of Medicine

Yeshiva University

Bronx, NY

Vincent Lo Re, III, M.D., M.S.C.E.

Assistant Professor

Division of Infectious Diseases

Department of Biostatistics and Epidemiology

University of Pennsylvania

Philadelphia, PA

Milo Puhan, M.D., Ph.D.

Associate Professor

Department of Epidemiology

Johns Hopkins School of Public Health

Baltimore, MD

John Scott, M.D.

Assistant Professor

Department of Allergy and Infectious Diseases

University of Washington

Seattle, WA

Jeffrey Weiss, Ph.D., M.S.

Assistant Professor

Division of General Internal Medicine

Mount Sinai School of Medicine

New York, NY