# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

Imtiaz Alam, M.D.

Medical Director

Austin Hepatitis Center

Austin, TX

Donna Evon, Ph.D.

Assistant Professor

Division of Gastroenterology and Hepatology

University of North Carolina

Chapel Hill, NC

Daniel Hartung, Pharm.D., M.P.H.

Assistant Professor

College of Pharmacy

Oregon State University

Corvallis, OR

Milo Puhan, M.D., Ph.D.

Associate Professor

Department of Epidemiology

Johns Hopkins School of Public Health

Baltimore, MD

John Scott, M.D.

Assistant Professor

Department of Allergy and Infectious Diseases

University of Washington

Seattle, WA

Jeffrey Weiss, Ph.D., M.S.

Assistant Professor

Division of General Internal Medicine

Mount Sinai School of Medicine

New York, NY