# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

Imtiaz Alam, M.D.

Medical Director

Austin Hepatitis Center

Austin, TX

Alan Franciscus

Executive Director

HCV Advocate

San Francisco, CA

Eliot Godofsky, M.D.

Chief Operating Officer

Pointe West Infectious Diseases

Bradenton, FL

John Scott, M.D.

Assistant Professor

Department of Allergy and Infectious Diseases

University of Washington

Seattle, WA

Nancy Steinfurth

Executive Director

Hep C Connection

Denver, CO