# Quality of Life Outcomes

Table F-1 Quality of life outcomes

Study, Year Quality | Study Design | Comparison | Group | Sample Size (N) | Quality of Life Measure | Followup | Quality of Life Score, Mean (SD) | P-value for Difference Between Groups at Followup
Bertino, 2010^61^ Fair | RCT | HCV Patients on epoetin vs. usual care | IG | 67 | Energy Score Change^*^ | 36 weeks | 18 ± 17.3 | Energy Score Change: p<0.05 Activity Score Change: p<0.01
Bertino, 2010^61^ Fair | RCT | HCV Patients on epoetin vs. usual care | IG | 67 | Activity Score Change^*^ | 36 weeks | 20 ± 18.5 | Energy Score Change: p<0.05 Activity Score Change: p<0.01
Bertino, 2010^61^ Fair | RCT | HCV Patients on epoetin vs. usual care | CG | 67 | Energy Score Change^*^ | 36 weeks | 12.2 ± 21.6 | Energy Score Change: p<0.05 Activity Score Change: p<0.01
Bertino, 2010^61^ Fair | RCT | HCV Patients on epoetin vs. usual care | CG | 67 | Activity Score Change^*^ | 36 weeks | 7 ± 18.7 | Energy Score Change: p<0.05 Activity Score Change: p<0.01
Bonkovsky, 2008^64^ Poor | RCT | Supervised treatment vs. self-administered treatment in methadone clinic users | IG | 24 | Hepatitis specific limitations | Baseline | 74.5 (6.0) | NR
Bonkovsky, 2008^64^ Poor | RCT | Supervised treatment vs. self-administered treatment in methadone clinic users | IG | 24 | Hepatitis specific limitations | End of Treatment | 59.1 (7.4) | NR
Bonkovsky, 2008^64^ Poor | RCT | Supervised treatment vs. self-administered treatment in methadone clinic users | IG | 24 | Hepatitis specific limitations | End of Followup (72 weeks) | 84.2 (5.6) | NR
Bonkovsky, 2008^64^ Poor | RCT | Supervised treatment vs. self-administered treatment in methadone clinic users | IG | 24 | Hepatitis specific health distress | Baseline | 63.8 (5.5) | NR
Bonkovsky, 2008^64^ Poor | RCT | Supervised treatment vs. self-administered treatment in methadone clinic users | IG | 24 | Hepatitis specific health distress | End of Treatment | 58.7 (8.2) | NR
Bonkovsky, 2008^64^ Poor | RCT | Supervised treatment vs. self-administered treatment in methadone clinic users | IG | 24 | Hepatitis specific health distress | End of Followup (72 weeks) | 81.6 (6.0) | NR
Bonkovsky, 2008^64^ Poor | RCT | Supervised treatment vs. self-administered treatment in methadone clinic users | CG | 24 | Hepatitis specific limitations | Baseline | 76.8 (6.1) | NR
Bonkovsky, 2008^64^ Poor | RCT | Supervised treatment vs. self-administered treatment in methadone clinic users | CG | 24 | Hepatitis specific limitations | End of Treatment | 40.0 (8.7) | NR
Bonkovsky, 2008^64^ Poor | RCT | Supervised treatment vs. self-administered treatment in methadone clinic users | CG | 24 | Hepatitis specific limitations | End of Followup (72 weeks) | 68.9 (9.6) | NR
Bonkovsky, 2008^64^ Poor | RCT | Supervised treatment vs. self-administered treatment in methadone clinic users | CG | 24 | Hepatitis specific health distress | Baseline | 69.8 (5.7) | NR
Bonkovsky, 2008^64^ Poor | RCT | Supervised treatment vs. self-administered treatment in methadone clinic users | CG | 24 | Hepatitis specific health distress | End of Treatment | 50.4 (7.4) | NR
Bonkovsky, 2008^64^ Poor | RCT | Supervised treatment vs. self-administered treatment in methadone clinic users | CG | 24 | Hepatitis specific health distress | End of Followup (72 weeks) | 67.3 (7.3) | NR

* Linear Analogue Self-Assessment (LASA) Scale

CG = control group; HCV = hepatitis C virus; IG = intervention group; NR = not reported; RCT = randomized controlled trial; SD = standard deviation; Vs = versus