# Quality of Included Cohort Studies

Table E-1 Quality of included cohort studies

Study, Year | Study Type | Selection of the Nonexposed Cohort | Method of Ascertaining Exposure | Measurements: Equal, Reliable, Valid | Blinding of Outcome Assessors | Completeness of Followup | Adjustment/Matching for Potential Confounders | Overall Quality
Alam, 2010^90^ | Prospective cohort study | Appropriate | Patient registry data | Likely | NR | 24 weeks Total: 450/503=89.5% E: 311/346=89.9% NE: 139/157=88.5% | Unadjusted | Fair
Cacoub, 2008^91^ | Prospective cohort study | Appropriate | Patient self-report of therapeutic education by a third party including distribution of support documents | Likely | NR | Total (646/674=96%) Loss to followup not presented by exposure | Adjusted for all important factors that could be obtained | Good
Cohen, 2009^65^ | Retrospective cohort study | Appropriate | Patient charts; Pharmacy reports of being a “specialty” versus “standard” pharmacy added to patient chart | Likely | NR | NR (all patients included in analyses) | Adjusted for a limited number of important factors in SVR analyses, but not in adherence analyses | Fair
Curcio, 2010^92^ | Prospective cohort study | Inappropriate | Exposure is the TTTC group (adequate exposure) | Uncertain | Uncertain | Total (100/100=100%) | Inadequate matching | Poor
Hussein, 2010^93^ | Retrospective cohort study | Appropriate | Enrollment in BIC program recorded in claims database | Likely | NR | Retrospective cohort - but missing data at 24 and 48 weeks 24 weeks: E: 638/780=81.8% NE: 7014/8572=81.8% 48 weeks: E: 333/780=42.7% NE: 4071/8572=47.5% | Used propensity score matching technique, included several factors in generating propensity score | Good
Liu, 2010^95^ | Retrospective cohort study | Appropriate | Chart review of antidepressant use | Likely | NR | Total (100/100=100%) | Unadjusted | Poor

BIC = Be in Charge; E = exposed group; NE = nonexposed group; NR = not reported; SVR = sustained viral response; TTTC = Together to Take Care