# Quality of Included Randomized Controlled Trials

Table D-1 Quality of included randomized controlled trials

Study, Year | Valid Random Assignment? | Allocation Concealed? | Groups Similar at Baseline? | Measurements: Equal, Reliable, Valid | Blinding of Patients | Blinding of Outcome Assessors | Completeness of Followup | Intervention Fidelity? | Adequate Compliance to Intervention? | ITT Analysis | Overall Quality
Bertino 2010^61^ | NR | NR | NR | Likely | No | NR | Week 72 Total: 134/134 = 100% IG: 100% CG: 100% | NR | NR | ITT | Poor
Bonkovsky 2008^64^ | NR | NR | Yes | Likely | No | NR | Total (28/48=58%) IG: 16/42=63% CG: 12/24=50% | NR | NR | ITT | Poor
Bruce 2012^98^ | Uncertain | NR | Unclear | Likely | No | No | Total (16/21=76.2%) IG: 100% CG: 4/9=44.4% | Likely | NR | Completers only | Poor
Larrey, 2011^94^ | NR | NR | Yes | NR | No | NR | Total (244/250=97.6%) IG: 123/123=100% CG: 121/127=95.3% | Likely | NR | ITT | Poor
Morasco, 2010^96^ | Uncertain | NR | Yes | NR | Yes | NR | NR | Likely | NR | NR | Poor
Ramsey, 2011^97^ | Yes | Yes | No | Likely | NR | NR | Total 82.5% at 48 weeks for DNA data IG: 10/14=71% CG: 14/15=93% | Likely | IG completed mean of 5.93 (out of 8) sessions; 9 of 14 participants completed 6 or more sessions | ITT | Fair

CG = control group; IG = intervention group; ITT = intention to treat; NR = not reported