# Studies Pending Assessment

Table B-1 Studies pending assessment

Study Reference | Design | Aim | Location | Number of Participants | Intervention Description | Relevant Outcomes | 2012 Status
Bruce 2008^105^ | RCT | Investigate whether integrating HCV treatment into methadone and buprenorphine improves HCV outcomes | US | 125 | Integrated substance abuse and HCV treatment with DOT | 1. HCV viral load; 2. Adherence; 3. Drug treatment outcomes | Protocol
Klein 2008^106^ | RCT | Investigate whether antidepressant prophylaxis can increase successful completion of HCV therapy | Canada | NR | Administration of citalopram to prevent neuropsychiatric symptoms | 1. Proportion of prescribed pegIFN and ribavirin doses taken per month; 2. Development of depression | Protocol
Litwin 2011^107^ | RCT | Investigate whether enhanced DOT (PEG/RBV-DOT) is associated with increased adherence and SVR compared to standard DOT (PEG-DOT) | US | 80 | Provide adults with directly observed daily ribavirin plus provider-administered weekly IFN | 1. Self-reported and pill count adherence; 2. End to treatment response or SVR | Protocol; Currently recruiting
North 2008^108^ | RCT | Investigate whether family-responsive psychoeducation can increase eligibility and adherence to HCV treatment | US | 400 | PsychoEducation Response to Families (PERF) | 1. Treatment readiness and adherence to HCV treatment; 2. Quality of life | Protocol
Shun 2012^109^ | RCT | Investigate whether exercise can improve health related fitness, quality of life and adherence to HCV therapy | Taiwan | 300 | Personalized Physical Activity and Psych-Education (PPAPE) Program | 1. Health related physical fitness; 2. Quality of life; 3. Adherence | Protocol; Currently recruiting
Sulkowski 2011^110^ | RCT | Determine extent of HCV disease and treatment in IDU; evaluate if behavioral reinforcement interventions increase adherence | US | 800 | Contingent Voucher Incentive (CVI) provided based on clinic visits and HCV treatment adherence | 1. Treatment eligibility; 2. Liver disease staging; 3. Treatment incentives; 4. Liver stiffness; 5. BMI; 6. Serum markers | Protocol; Currently recruiting
Weiss 2011^111^ | RCT | Investigate whether patients undergoing HCV treatment receiving Armodafinil have fewer missed doses, dose reductions, treatment discontinuation. | US | 130 | Administration of Armodafinil (FDA approved stimulant) | 7 Adherence to medications; 8 Fatigue Severity Scale (FSS) | Currently recruiting

DOT = directly observed treatment; FDA = Food and Drug Administration; HCV = hepatitis C virus; IDU = intravenous drug users; IFN = interferon; PEG = pegylated; RBV = ribavirin; RCT = randomized controlled trial; SVR = sustained viral response; US = United States