# Original Search Strategy

Key:

/ = subject heading (including MeSH, Emtree,etc.)

MH = subject heading

ti = word in title

ab = word in abstract

adj# = adjacent within x number of words

$ = truncation

* = truncation

pt = publication type

sb = subset

kw = keyword

Databases searched:

MEDLINE

PubMed (publisher-supplied references only)

Cochrane Central Register of Controlled Trials (CENTRAL)

PsycINFO

Cumulative Index to Nursing and Allied Health (CINAHL)

Embase

## MEDLINE via Ovid [search date: 12/2/2011]

Database(s): Ovid MEDLINE(R) without Revisions 1996 to November Week 3 2011, Ovid MEDLINE(R) Daily Update November 16, 2011, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations December 01, 2011

# | Searches | Results
1 | Hepatitis C/ | 19947
2 | Hepatitis C, chronic/ | 12822
3 | Hepacivirus/ | 15764
4 | hepatitis c.ti,ab. | 37596
5 | hcv.ti. | 5683
6 | 1 or 2 or 3 or 4 or 5 | 45172
7 | “Patient Acceptance of Health Care”/ | 18940
8 | Patient Dropouts/ | 3594
9 | Patient Compliance/ | 27211
10 | Medication Adherence/ | 3080
11 | Patient Participation/ | 10918
12 | Patient Satisfaction/ | 43563
13 | Patient Preference/ | 981
14 | Treatment Refusal/ | 6511
15 | “Retention (Psychology)”/ | 3782
16 | ((adhere$ or nonadhere$) adj6 (treatment$ or medication$ or therapy$ or therapies or regimen)).ti,ab. | 12806
17 | ((compliance or comply$ or complies or complied) adj6 (treatment$ or medication$ or therapy$ or therapies or regimen)).ti,ab. | 9662
18 | ((compliance or comply$ or complies or complied) adj3 patient$).ti,ab. | 7688
19 | (noncomplian$ adj6 (treatment$ or medication$ or therapy$ or therapies or regimen)).ti,ab. | 946
20 | (noncomplian$ adj3 patient$).ti,ab. | 751
21 | (persistence adj6 (treatment$ or medication$ or therapy$ or therapies or regimen)).ti,ab. | 1628
22 | (concordance adj6 (treatment$ or medication$ or therapy$ or therapies or regimen)).ti,ab. | 399
23 | patient cooperation.ti,ab. | 312
24 | (refusal adj3 (treatment$ or medication$ or therapy$ or therapies or regimen)).ti,ab. | 449
25 | (withdrawal adj3 (treatment$ or medication$ or therapy$ or therapies or regimen)).ti,ab. | 3890
26 | (discontinu$ adj3 (treatment$ or medication$ or therapy$ or therapies or regimen)).ti,ab. | 12505
27 | ((dropout$ or drop$ out$) adj3 patient$).ti,ab. | 1428
28 | 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 | 144127
29 | 6 and 28 | 1469
30 | clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ | 142687
31 | (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt. | 403700
32 | control groups/ or double-blind method/ or single-blind method/ | 80471
33 | random$.ti,ab. | 440638
34 | placebo$.ti,ab. | 90664
35 | clinical trial$.ti,ab. | 133471
36 | controlled trial$.ti,ab. | 73483
37 | case-control studies/ | 126566
38 | retrospective studies/ | 304625
39 | cohort studies/ | 111550
40 | longitudinal studies/ | 50064
41 | follow-up studies/ | 262459
42 | prospective studies/ | 227185
43 | cohort.ti,ab. | 155175
44 | longitudinal.ti,ab. | 80303
45 | follow up.ti,ab. | 366017
46 | followup.ti,ab. | 10035
47 | prospective$.ti,ab. | 275033
48 | retrospective$.ti,ab. | 241307
49 | comparison group$.ti,ab. | 7362
50 | control group$.ti,ab. | 169872
51 | observational.ti,ab. | 48908
52 | nonrandom$.ti,ab. | 8674
53 | 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 | 1959137
54 | 29 and 53 | 886
55 | limit 54 to yr=“2001 -Current” | 769
56 | remove duplicates from 55 | 766
57 | limit 56 to english language | 700
58 | 56 not 57 | 66

## PubMed [search date: 12/2/2011]

#1 “hepatitis c” AND publisher[sb] AND (adhere*[tiab] OR compliance[tiab] OR nonadhere*[tiab] OR noncomplian*[tiab] OR refusal[tiab] OR dropout*[tiab]) Limits: Publication Date from 2001 to 2013 25
#2 “hepatitis c” AND publisher[sb] AND (adhere*[tiab] OR compliance[tiab] OR nonadhere*[tiab] OR noncomplian*[tiab] OR refusal[tiab] OR dropout*[tiab]) Limits: English, Publication Date from 2001 to 2013 24
#3 #14 NOT #15 1

## Embase via Ovid [search date: 11/28/2011]

Database(s): Embase 1996 to 2011 Week 46 via Ovid

# | Searches | Results
1 | hepatitis C/ | 49960
2 | Hepatitis C virus/ | 30192
3 | 1 or 2 | 61667
4 | patient attitude/ | 32594
5 | patient compliance/ | 65391
6 | patient participation/ | 10418
7 | patient preference/ | 947
8 | patient satisfaction/ | 61564
9 | refusal to participate/ | 586
10 | treatment refusal/ | 6852
11 | or/4–10 | 165624
12 | 3 and 11 | 1271
13 | randomized controlled trial/ | 244592
14 | clinical trial/ or clinical study/ | 686750
15 | controlled clinical trial/ | 166321
16 | meta analysis/ | 53262
17 | randomization/ | 45268
18 | double blind procedure/ | 75164
19 | single blind procedure/ | 13023
20 | placebo/ | 140037
21 | “systematic review”/ | 45174
22 | case control study/ | 50896
23 | population based case control study/ | 3688
24 | retrospective study/ | 208153
25 | cohort analysis/ | 99458
26 | longitudinal study/ | 39417
27 | follow up/ | 463440
28 | prospective study/ | 152369
29 | control group/ | 27599
30 | observational study/ | 24075
31 | or/13–30 | 1592663
32 | 12 and 31 | 645
33 | limit 32 to yr=“2001 -Current” | 637
34 | limit 33 to english language | 596
35 | 33 not 34 | 41

## PsycINFO via APA PsycNET [search date: 11/29/2011]

((KEYWORDS:adhere* OR ab:adhere*) OR (KEYWORDS:nonadhere* OR ab:nonadhere*) OR (KEYWORDS:compliance OR ab:compliance ) OR (KEYWORDS:noncomplian* OR ab:noncomplian*)) OR( (IndexTermsFilt:(“Client Attitudes” OR “Client Participation” OR “Client Satisfaction” OR “Treatment Barriers” OR “Treatment Compliance” OR “Treatment Dropouts” OR “Treatment Refusal”))

AND

(KEYWORDS:”hepatitis c”) OR (ab:”hepatitis c”)

AND

[2001 TO 2011]:PublicationYear = 114

english:Language= 109

non-english = 5

## CINAHL via EBSCOhost [search date: 11/29/2011]

S1 ( (MH “Hepatitis C, Chronic”) OR (MH “Hepatitis C”) ) OR TX “hepatitis c”
S2 ( (MH “Medication Compliance”) OR (MH “Patient Compliance”) ) OR ( (MH “Patient Dropouts”) OR (MH “Patient Satisfaction”) ) OR (MH “Treatment Refusal”)
S3 TX ( adhere* OR nonadhere* ) OR TX ( compliance OR noncomplian* )
S4 S2 or S3
S5 S1 and S4
S6 (MH “Case Control Studies”) OR (MH “Matched Case Control”) OR (MH “Population-Based Case Control”) OR (MH “Prospective Studies”) OR (MH “Concurrent Prospective Studies”) OR (MH “Nonconcurrent Prospective Studies”)
S7 (MH “Correlational Studies”) OR TX cohort OR TX observational
S8 (MH “Randomized Controlled Trials”) OR (MH “Clinical Trials”) OR (MH “Random Assignment”) OR (MH “Single-Blind Studies”) OR (MH “Double-Blind Studies”) OR (MH “Triple-Blind Studies”) OR TX clinical n1 trial* OR TX controlled n1 trial* OR PT Clinical trial OR PT randomized controlled trial
S9 S6 or S7 or S8
S10 S5 and S9 Limiters - Published Date from: 20010101–20111231 = 80

## Cochrane Central Register of Controlled Trails via Wiley, issue 4 of 4, Oct. 2011 [search date: 12/2/2011]

#1 | “hepatitis c”:ti,ab,kw, from 2001 to 2011 in Clinical Trials | 1779
#2 | adhere*:ti,ab,kw OR nonadhere*:ti,ab,kw OR compliance:ti,ab,kw OR noncomplian*:ti,ab,kw, from 2001 to 2011 in ClinicalTrials | 9853
#3 | “patient acceptance”:ti,ab,kw OR refusal:ti,ab,kw OR dropout*:ti,ab,kw, from 2001 to 2011 in Clinical Trials | 2606
#4 | (#2 OR #3), from 2001 to 2011 | 11922
#5 | (#1 AND #4), from 2001 to 2011 | 112