# Abbreviations and Acronyms

AASLD: American Association for the Study of Liver Diseases
ALT: alanine transaminase
AHRQ: Agency for Healthcare Research and Quality
BIC: Be In Charge
BMI: body mass index
CBT: cognitive behavioral therapy
CDC: Centers for Disease Control and Prevention
CENTRAL: Cochrane Central Register of Controlled Trials
CER: comparative effectiveness review
CHIP: Children’s Health Insurance Program
CI: confidence interval
CINAHL: Cumulative Index to Nursing and Allied Health Literature
DOTS: direct observation treatments
EHC: Effective Health Care
ELISA: enzyme-linked immunosorbent assay
EPC: Evidence-based Practice Center
EVR: early viral response
FDA: Food and Drug Administration
HBV: hepatitis B virus
HCC: hepatocellular carcinoma
HCV: hepatitis C virus
HDV: hepatitis D virus
Kg: kilograms
LASA: linear analogue self-assessment
MEMS: Medication Event Monitoring System
OR: odds ratio
ORadj: adjusted odds ratio
PCR: polymerase chain reaction
pegIFN: pegylated interferon
pegIFN-α: pegylated interferon alpha
QOL: quality of life
RCT: randomized controlled trial
RNA: ribonucleic acid
SRC: Scientific Resource Center
SVR: sustained viral response
TEP: technical expert panel
TMA: transcription-mediated amplification
TTTC: Together to Take Care
USPSTF: U.S. Preventative Services Task Force
vs.: versus
Wks: weeks