# Results

## Overview

The results of the search and study selection are summarized in the study flow diagram (Figure 4 and Table 1). Searches of databases, review of reference lists of published studies, and review of gray literature resulted in 7,274 potentially relevant articles. After dual review of abstracts and titles 1,836 studies were selected for full-text review. Gray literature was assessed, but did not meet the inclusion criteria for this report or provide data that was not already available in the peer reviewed literature. One hundred seventy-four studies (with results published in 182 full-text articles) were included in this review. These studies examined a wide range of interventions, but sample sizes often were small. We found moderate-strength evidence that some interventions improved healing of pressure ulcers, but no interventions were found to be effective with a high strength of evidence. Several other interventions had limited evidence of effectiveness (strength of evidence rated as low). A minority of studies examined complete wound healing as an outcome. In general, the evidence about the harms of any of these treatments was limited. See Appendix B for complete inclusion and exclusion criteria and Appendix G for strength of evidence assessments.

Figure 4 Study flow diagram: Comparative effectiveness of treatment for pressure ulcers

CCRCT = Cochrane Central Register of Controlled Trials; CDSR = Cochrane Database of Systematic Reviews; CINAHL = Cumulative Index to Nursing and Allied Health Literature; DARE = Database of Abstracts of Reviews of Effectiveness; EBM Reviews = Evidence-Based Medicine Reviews; Embase = Excerpta Medica Database; HTA = Health Technology Assessment; MEDLINE = Medical Literature Analysis and Retrieval System Online

^a^ The code for “Unable to obtain” includes conference proceedings without full text publications (33), untranslatable foreign language texts (33), unobtainable full texts, excluded as abstracts (23), and articles that were not available (22). The full text code for “Not relevant” includes non-English language articles, animal studies, wrong study design, and other excluded articles for which existing codes did not apply.

This figure is a flow chart that summarizes the search and selection of articles related to pressure ulcer treatment strategies. Citations were identified through bibliographic databases, including MEDLINE, Embase, CINAHL, and EBM Reviews, Cochrane Central Register of Controlled Trials, Cochrane Database of Systematic Reviews, Database of Abstracts of Reviews of Effects, and Health Technology Assessment, as well as through other sources, including experts, reference lists, and grey literature. The results of the search and study selection are summarized in the study flow diagram figure. Searches of databases, review of reference lists of published studies, and review of gray literature resulted in 7,274 potentially relevant articles. After dual review of abstracts and titles 1,836 studies were selected for full-text review. 174 studies (with results published in 182 full-text articles) were included in this review.

Table 1 Overview of included studies by treatment strategy

Treatment Strategy | Included Trials | Included Observational Studies
Support | 21 | 3
Nutrition | 11 | 5
Local wound applications | 76 | 13
Surgery | 1 | 5
Adjunctive | 34 | 5

## Overall Effectiveness of Pressure Ulcer Treatment

Pressure ulcer treatment encompasses numerous intervention strategies: alleviating the conditions contributing to ulcer development (support surfaces, repositioning, and nutritional support); protecting the wound from contamination, creating a clean wound environment, and promoting tissue healing (local wound applications, debridement, wound cleansing, and various adjunctive therapies); and surgically repairing the wound. We evaluated evidence addressing the comparative effectiveness and harms in treatment categories where significant uncertainty exists about the best therapeutic options. Results for each key question are presented here, within these specific treatment categories: support surfaces, nutrition, local wound applications (including wound dressings, topical therapies and biological agents), surgical interventions, and adjunctive therapies. Although we evaluated multiple outcomes, only measures of wound improvement (complete wound healing, wound size reduction, healing time) were consistently reported. Other outcomes including pain were reported sporadically. Ulcer recurrence was used as an outcome in some studies of surgery and are reported in that section of this report. Prevention of serious infectious complications was not reported as an outcome in any included study. There was no body of literature for which it was possible to synthesize evidence for the impact of a given intervention on outcomes other than wound improvement. In reporting results of wound improvement, when a body of literature allowed conclusions about a particular measure of wound improvement (e.g., complete wound healing), we report those findings. In many cases, however, the use of different measures of wound improvement allowed us only to report on the overall effect of an intervention on wound improvement, which included complete wound healing, wound size reduction, and healing time. The overall findings of this review and a summary of the strength of the evidence for the key findings are presented in Table 31.

## Results of Pressure Ulcer Treatment by Treatment Strategy

### Effectiveness of Support Surfaces

Many factors contribute to both the development of pressure ulcers and the likelihood that pressure ulcers will heal once they develop. Of these, pressure, friction, or shear that limits blood flow and/or damages skin and underlying tissues are the most direct contributors to the development of pressure ulcers. Treatments that redistribute pressure, reduce friction, and prevent shear are used to promote healing and prevent further damage to the skin in the area of the ulcer.

Healing can be promoted by a variety of types of support surfaces. A support surface is defined as “a specialized device for pressure redistribution designed for management of tissue loads, micro-climate, and/or other therapeutic functions (i.e., any mattress, integrated bed system, mattress replacement, overlay, or seat cushion, or seat cushion overlay).”17 While support surfaces are frequently used to prevent pressure ulcers for people at risk, they are also used (though less frequently studied) as a component of pressure ulcer treatment. This section summarizes the studies that met the inclusion criteria for this review, including that they compare different support surfaces used in the treatment of existing pressure ulcers and evaluate the impact of these support surfaces on healing.

#### Description of Studies

We identified 24 studies of the use of various support surfaces that met our inclusion criteria (see Appendix D). These studies were reported in 26 articles published between 1987 and 2012. Two studies were reported in more than one publication.18–21 Most of the studies were published in the 1990s (10 studies22–31) and early 2000s (six studies; eight articles18–21,32–35). Only five were published during or after 2005^36–40^ and these were sometimes based on older data (e.g., Valente was published in 2012 but reports data from patients treated in July 2001 to June 2002). A limitation of the literature on support surfaces for pressure ulcer treatment is that there are few recent comparative studies.

Details extracted from each study are included in the evidence tables (see Appendix H, Table H-1). Of these, four were rated as good quality, 10 as fair, and 10 as poor. The assessments of the quality rating criteria used for each study are provided in Appendix H, Table H-2.

Of the 24 studies identified, 20 were randomized trials. The other four included one trial in which the method of assignment was not clearly stated,24 two retrospective cohort studies,40,41 and one small, prospective cohort study.30 Fourteen of these studies were conducted in the United States,26,27,29,32,34,38,41–46 seven in the United Kingdom,18–21,23,25,33,35,36 and one each in Holland,31 Japan,24 and Belgium.39

The populations in the studies were predominately older hospital patients and long-term care residents. Mean ages were in the late 60s to 80s, with the exception of one study of people with spinal cord injuries living in the community. In this study the mean ages for the treatment and control groups were 42 and 45.^38^ All subjects had at least one pressure ulcer, as this was the key inclusion criteria. The stage of the ulcers varied, with most studies including people with a range of severities (see details in Summary Table 31), though some studies were limited to patients with ulcers of a particular stage (e.g., Stage II19,36 or Stage I33).

The interventions and comparators in studies of support surfaces included several different types of surfaces and brands. Support surfaces vary in terms of form factor (e.g., mattress, mattress overlays, seat cushions, and seat overlays), materials, action, and method of pressure redistribution or environment control. While definitions of key terms have been proposed,17 currently there is no universally accepted classification of support surfaces into categories that are mutually exclusive. Some studies, reviews, and guidelines have classified support surfaces based on reimbursement policies37,41 or the primary action such as constant low pressure (CLP), low-air-loss (LAL), alternating pressure (AP), or air-fluidized (AF). Other studies have created categories such as whether they require power or not for operation10 or as “low tech” compared with “high tech.”47,48 There is significant overlap with nonpowered, CLP, and “low tech,” while powered is often AP or AF and considered “high tech.” However, this categorization does not allow for the possibility of a high-tech material or design that does not require power. Some studies compared a new design with AP as “standard care.” For this reason, we organized our presentation of the studies into four groups (AF, AP, LAL, and “other”) based on the surface that is considered to be the experimental intervention. The “other” category corresponds to surfaces that are not AF, AP, or LAL and were tested as new interventions.

The comparators in the studies varied and were not always well specified. Some studies compared two specific types and/or brands of surfaces, while others compared the study surface to “usual care” or normal hospital beds. These comparators were not always described in the articles. The comparator is specified in as much detail as is provided by the article authors in the evidence tables in the appendix as well as discussed in the detailed analyses as appropriate. Although it might not be considered best practice today to treat a patient with a pressure ulcer on a normal hospital bed, it is not unheard of for less severe pressure ulcers to be treated on a normal hospital bad. For this reason we retained studies that met the overall inclusion criteria for this review (e.g. published after 1985 and report the comparative impact on a measure of healing) even if they compared the support surface that was the subject of study to a surface that could be considered outdated or not currently the best recommended practice because these are still used in some circumstances.

The outcomes measured and reported in the identified studies reflect the goals of treatment, but were restrained by the timing of possible followup measurement, which ranged from 5 days33 to 36 weeks.45 The ultimate goal, and therefore outcome, of pressure ulcer treatment is complete healing of the wound. Eight of the identified studies reported how many patients in the study had pressure ulcers that healed,23,25,29,31,33,36,40,42 two also reported the time to complete healing,34,36 while one reported time to 30 percent healed.38 Most pressure ulcers, particularly larger ulcers and those that involve many layers of tissue, often require months to heal17 and some never heal completely in the patient’s lifetime. Given these constraints, the majority of studies (16 of 24) included in this review20,21,23–27,30,32,36,38,39,41–44,46 reported changes in the surface area or volume of either an index ulcer (usually the worst) or all pressure ulcers over a set period of time or until the patient was discharged or died. An additional outcome reported in seven studies was simply “improvement.” Improvement was defined as healing or change in the stage of the ulcer determined through blinded assessment by experts.18,19,24,35,39,43–45 Five studies also reported pain or patient comfort as an outcome20,21,23,27,43,46 and two included hospital admissions and emergency department visits41,45 as an outcome compared across patients treated on different surfaces.

The setting for these studies included hospitals, long-term care facilities (e.g., nursing facilities, post-acute care facilities, and home health care agencies), and the community. Eleven studies were conducted in acute care hospitals18,19,26,27,30,33,35,36,39,43,44,46 and ten in long-term care facilities.23,24,29,31,32,34,40–42,45 One study was of people living in the community38 and two included both hospital patients and nursing facility residents.20,21,25

#### Key Points

Five studies conducted in the late 1980s and 1990s were identified that compared AF beds to other surfaces. All reported greater wound improvement on the AF beds in terms of reduction in ulcer size (strength of evidence: moderate).

Complete wound healing and reduction in ulcer size were similar across different brands of AP beds made by different manufacturers or types of AP surfaces (i.e., overlays and full beds). (four studies, strength of evidence: moderate).

The evidence about the effectiveness of AP beds was mixed, though most findings were of similar wound improvement for AP beds when compared to air, fluid or standard beds. (four studies, strength of evidence: low).

Two studies of AP chair cushions were conducted in two very different populations (younger people with spinal cord injury and older hospital patients or nursing home residents) and produced different results, making it difficult to draw a generalizable conclusion about AP chair cushions (strength of evidence: insufficient).

Wound improvement was similar with LAL beds compared with foam surfaces (three of five studies) or with LAL beds compared with LAL overlays (strength of evidence: low).

While harms were reported in seven studies, each study included different harms for different surfaces (strength of evidence: insufficient).

There was insufficient evidence to draw conclusions about the impact of patient or setting characteristics on the effectiveness or harms of different support surfaces in ulcer healing because most studies did not provide relevant information.

#### Detailed Analysis

The identified studies are categorized by the experimental surface in both the summary of evidence in Table 31 and the narrative below.

##### Evidence About the Comparative Effectiveness of Support Surfaces (Key Question 1)

###### Air-Fluidized Beds

AF beds are made of small beads and air is forced through the beads to create a fluid-like surface that redistributes pressure. The five studies of AF beds (Table 2) were all conducted in the United States and included one large, fair-quality cohort study published in 2005 and four randomized trials published between 1987 and 1991. One trial was rated as good quality,43 two as fair,45,46 and one as poor.44 The combined results of these studies provide limited evidence that AF beds have a positive effect in that they are more effective than alternatives in promoting the reduction in the size of pressure ulcers. The moderate strength of evidence rating is based in part on the fact that the results are consistent across all of these studies. However, as is detailed in the text and Table 2, the trials were conducted 10 or more years ago in the late 1980s and early 1990s and in three of the trials the AF bed was compared with standard beds or multiple surfaces that were not well defined.44–46

Table 2 Support surfaces: Air-fluidized beds

Author Year Study Type Quality Number Enrolled/Completed Setting | Pressure Ulcer Stage^a^ | Mean Age (range) Sex Population | Followup | Surfaces Compared | Outcome Measures and Treatment Effect | Benefit: Wound Improvement
Allman 1987^43^ Trial Good N=72/65 Hospital | I, II, III, IV, and unstageable | 67 years (NR) Female: 58% General | Median13 days (range 4 to 77 days) | A: AF bed (Clinitron Therapy) B: AP-air covered with foam (Lapidus Air Float) | Complete wound healing (mean): A: 65% B: 44% (p=0.10) Change in total surface area (median): A: −1.2 cm^2^ B: +0.5 cm^2^ (p=0.01) Regression results: Odds of improvement in A vs. B: 5.6 (95% CI, 1.0 to 27.5) Decrease in Pain A: 62% B: 36% (p=0.01) Harms: New skin breakdown (29% vs. 44%); epistaxis, (1 in A) | ~/+ ~ complete healing + change is size
Jackson 1988^44^ Trial Poor N=35/35 Hospital | II, III, IV | 77 years (NR) Female: 64% General | Until discharge | A: AF mattress B: Several non-AF surfaces | Complete wound healing: NR Wound area reduction (% of patients): A: 60% B: 45% (p-value NR) No significant difference in changes of stage, granulation/bleeding, necrosis. Harms: NR | +
Munro 1989^46^ Trial Fair N=40/40 VA Hospital | II, III | 67 years (48–88) Female: 0% General | 15 days | A: AF bed (Clinitron Therapy) B: Standard hospital bed | Complete wound healing: NR Wound area reduction: Significant improvement in A vs. B (p=0.05). No difference between groups in pain scores (p=0.359). Harms: NR | +
Ochs 2005^41^ Observational Fair N=664/664 Nursing facility | I, II, III, IV Eschar and unstaged | 78 years (19–106) Female: 63% General | 3 months | A: AF beds B: Low tech surfaces C: High tech except AF | Complete wound healing: NR Wound healing rate (mean for largest ulcer): A: 5.2 cm^2^/week (p=0.0071 vs. B and C) B: 1.5 cm^2^/week C: 1.8 cm^2^/week Faster healing with A compared with B or C when assessed by stage. Harms: NR | +
Strauss 1991^45^ Trial Fair N=112/97 Home Care | III, IV | Age: 64 years (NR) Female: 49% General | 36 weeks | A: AF bed (Clinitron Therapy) B: Conventional or standard therapy | Complete wound healing: NR More patients in A improved to stage II (62%) vs. B (% NR) (p-value NR) More patients in A classified as improved by independent assessment (NS; p-value NR) Harms: Dry skin in several patients; mild dehydration in 1 patient | +

AF = air-fluidized; AP = alternating pressure; NPUAP = National Pressure Ulcer Advisory Panel; NR = not reported; NS = not significant

a Pressure ulcer stage indicates NPUAP staging unless otherwise stated. Non-NPUAP staging was converted to the equivalent. NPUAP stage where possible.

++Complete wound healing.

+Reduction in wound size.

~No difference.

The one good-quality randomized trial compared 31 hospitalized patients on an AF bed who were repositioned every four hours with 34 patients on an AP bed with a foam overlay, which was conventional treatment for patients with pressure ulcers at the location of the study, who were repositioned every two hours.43 Those on AF beds experienced a median decrease in the size of their pressure ulcers (−1.2 cm^2^) that was significantly better than the median increase (+0.5 cm^2^) in the size of pressure ulcers in patients on the AP beds. Blinded assessors rated 71 percent of patients on the AF beds as improved compared with 47 percent on the AP beds and 62 percent of patients on the AF mattress reported a decrease in pain compared to 36 percent on the AP beds despite the difference in repositioning that could have favored the AP bed.43 A fair-quality study of hospital patients46 compared 20 people on AF beds with 20 on standard hospital beds and reported that the mean ulcer area declined on the AF beds and increased for those on standard beds and that pain declined for all patients and did not differ by bed type. A third study (poor quality) of hospital patients compared 15 patients on AF beds with 20 patients that used several alternatives that were standard care and found wound surface area reductions were higher in the patients treated on the AF beds.44

The other two studies of AF beds were in long-term care settings and similarly report favorable results in terms of reduction in pressure ulcer size. One followed 97 home care patients randomized to either an AF bed (n=47) or conventional treatment (n=50). The authors reported that more stage III and IV ulcers healed and were assessed as stage II after treatment on the AF beds (29 of 47, data for control group not provided) compared with patients on conventional surfaces and a higher proportion were rated as improved by blinded nurse raters.45 A large, fair-quality retrospective cohort study (n=664) of residents with at least one pressure ulcer in their medical record examined healing rates across groups of patients on AF beds, low-tech surfaces, and high-tech surfaces other than AF beds. Comparisons were made for healing rates for the largest ulcer for each person as well as the change in each ulcer (multiples allowed per resident) during 7 to 10 day episodes. Stage III and IV ulcers healed more quickly for patients on the AF beds (3.1 cm^2^ per week) compared with other high- (0.7) and low-tech surfaces (0.6). Residents on AF beds and residents on lower-tech surfaces (who overall were less severely ill) had fewer hospitalizations and emergency room visits than did residents who used the other higher-tech beds.41

###### Alternating Pressure Beds and Chair Cushions

AP mattresses, overlays, and cushions have cells or sections that inflate and deflate to change the distribution of pressure. The sizes of the cells, patterns of inflation and deflation, and the length of the cycles can vary across brands. Ten studies—six conducted in the United Kingdom,18–21,23,25,35,36 two in the United States,39,40 and one each in Belgium39 and Japan24—evaluated AP mattresses or chair cushions (Table 3).

Table 3 Support surfaces: Alternating pressure beds and chair cushions

Author Year Study Type Quality Number Enrolled/Completed Setting | Pressure Ulcer Stage^a^ | Mean Age (Range) Sex Population | Followup | Surfaces Compared | Outcome Measures and Treatment Effect | Benefit: Wound Improvement
Alternating Pressure Beds: Different Brands or Forms
Devine 1995^23^ Trial Fair N=41/30 Hospital | II, III, IV | 83 years (69–98) Female: 59% General | 4 weeks | A: AP bed (Nimbus 1) B: AP bed (Pegasus Airwave) | Complete wound healing: A: 63% B: 36% (NS; p-value NR) Wound area reduction (median): A: 0.089 cm^2^/day B: 0.107 cm^2^/day (p=0.92) No difference in patient reported comfort Harms: NR | ~
Evans and Land 2000^20,21^ Trial Good N=32/32 (12 hospital; 20 nursing facility) | II, III, IV | Hospital: 81 years (65–91) Female: 50% Nursing facility 85 years (71–99) years Female: 95% Elderly | Until healing, discharge, or death | A: AP bed (Nimbus 3) B: AP bed (other brands) | Complete Wound Healing: NR Wound area reduction (median): Hospital: A: 0.12 cm^2^ B: 0.08 cm^2^ (NS; p-value NR) Nursing facility: A: 0.11 cm^2^ B: 0.05 cm^2^ (NS; p-value NR) Median Comfort Rating: 1 (least) to 5 (most) Hospital A: 5 B: 4 p=0.006 Nursing facility A: 5 B: 4 p=0.002 Harms: NR | ~
Nixon 2006^36^ Trial Good N=1971/1540 (113 patients with pressure ulcers) Hospital | II (split into IIa partial thickness wound involving dermis only or IIb also epidermis) | 75 years (55–100) Female: 64% General | 30 days | A: AP bed B: AP bed overlay | Complete wound healing A: 20/59 (33.9%) B: 19/54 (35.2%) (NS) No difference between groups in time to healing (p=0.86) Harms: Mattress-related adverse events reported in 8 patients (2 overlay, 7 bed) | ~
Russell 2000^18,19^ Trial Fair N=183/112 Hospital | I, II | 84 years (NR) Female: NR General | Until healing or discharge | A: AP bed (Nimbus 3) and Aura seat cushion B: AP bed (Pegasus C airwave) and ProActive seat cushion | Complete wound healing: NR Wound improvement: All ulcers A: 91% B: 93% (p=0.78) Sacral ulcers A: 45% B: 51% (p=0.45) Heel ulcers A: 33% B: 57% (p=0.025) Harms: NR | ~
AP Beds vs. Other Surfaces
Izutsu 1998^24^ Trial Poor N=31/31 Long-term care | I, II, III, IV | 78 years (NR) Female: 58% General | 3 months | A: Lateral rolling bed B: Standard hospital bed | Complete wound healing: NR Wound area reduction: No significant difference (p-value NR) Wound grade change: A: −0.8 B: +0.2 (p<0.01) Harms: NR | ~
Malbrain 2010^39^ Trial Fair N=16/16 Hospital | I, II, III | 64 years (NR) Female: 50% ICU | Until discharge | A: AP bed (Nimbus 3) B: Air overlay (ROHO) | Complete wound healing: NR Wound area reduction: A: −2.1 cm^2^ B: 25.8 cm^2^ (p=0.05) Wound grade change: A: 0 B: 0.8 (p=0.03) Harms: NR | +
Russell 2003^35^ Trial Fair N=199/158 Hospital | I or higher | 80 years (NR) Female: 54% General | Until discharge | A: AP bed (Nimbus 3) B: Fluid overlay (RIK) | Complete wound healing: NR Wound progress (Worst ulcer per patient improved): A: 76% B: 84% (p=0.053) (Overall ulcer progress): A: 72% B: 75% (p=0.67) Harms: NR | ~
Valente, 2012^40^ Observational Poor N=122/122 Long-term Care | Unclear (Stage II and IV excluded) | 68 years (NR) Female: 65% General | 2, 3 or 4 weeks | A. Alternating Pressure Overlay (FirstStep Power Air Overlay) B. Gel Overlay (KIKTM fluid mattress | Complete wound healing: PU on admission Treatment A: 27% Treatment B: 17% (p-value NR) PU developed during stay Treatment A: 22% Treatment B: 11% (p-value NR) Harms: None | ~
AP Cushions
Clark 1998^25^ Trial Fair N=33/25 Hospital and Nursing facility | II, III, IV | 83 years (NR) Female: 72% Elderly | Until healing, discharge, or death | A: AP cushion (Pegasus) B: Static air-filled cushion (ROHO) | Complete wound healing: A: 21% B: 45% (p-value NR) Wound area reduction (superficial sores only): A: 0.13 cm^2^ B: 0.27 cm (p-value NR) Harms: Malfunction of cushion (1 in each group) | ~
Makhsous 2009^38^ Trial Fair N=44/44 Community | Unclear (Stage II or III, staging system not cited or described) | 43 years (18–79) Female: 7% Spinal cord injury | 30 days | A: AP, cyclic pressure relief system B: Regular wheelchair cushions | Complete Wound Healing: NR Wound area reduction: A: 45% B: 10% (p=0.001) Time to 30% healing: A: 25 days B : >30 days (p=0.007) Probability of 30% closure within 30 days: A: 0.73 B: 0.36 (p=0.007) Harms: NR | +

AP = alternating pressure; EPUAP = European Pressure Ulcer Advisory Panel; ICU = Intensive-care unit; NPUAP = National Pressure Ulcer Advisory Panel; NR = not reported; NS = not significant; PU = Pressure ulcer

a Pressure ulcer stage indicates NPUAP staging unless otherwise stated. Non-NPUAP staging was converted to the equivalent NPUAP stage where possible.

++Complete wound healing.

+Reduction in wound size.

~No difference.

###### Different Brands or Form Factors of Alternating Pressure Beds

Researchers found no significant differences in healing in the three studies that compared different AP beds, all involving a version of the Nimbus brand bed.18–20,23,49 One additional study that compared AP beds with AP overlays36 also found no significant difference in the number of ulcers that healed or the number of days they took to heal (four studies, moderate strength of evidence).

A fair-quality study of residents admitted to a geriatric hospital in Scotland found that, in 4 weeks, 10 of 16 patients on the Nimbus 1 AP bed healed compared with five of 14 who used the Pegasus brand AP bed, but this difference was not significant, there was no difference in patient-reported comfort and the study was stopped after 2 years due to difficulties recruiting patients and changes in the beds.23 Other researchers comparing a later version of the same AP mattress (Nimbus 3) with other brands of AP mattresses in a good-quality trial found no significant difference in change in size of the pressure ulcers in 12 hospital patients and 20 nursing facility residents. This study found that there were some differences in comfort, with the Nimbus 3 rated as more comfortable.20,21 The third study (fair quality) found a trend toward improvement in heel ulcers on the Nimbus 3 beds compared with another brand (Pegasus C airwave), but there was no significant difference in healing for sacral ulcers.18,19 A good-quality study that compared an AP mattress to an AP overlay reported no statistically significant differences in the number of ulcers healed or the median time to healing.36

###### Alternating Pressure Beds Compared With Other Surfaces

Four studies (two fair quality and two poor quality) evaluated AP surfaces by comparing them with other surfaces. Three studies included patients with pressure ulcers at all stages24,35,39 and one excluded patients with pressure ulcers that advanced to stage III or IV.40 The findings were conflicting, though most studies found no significant differences in at least one measure of healing (low strength of evidence).

Two studies followed hospital patients who were predominately elderly until discharge.35,39 One fair-quality trial found no significant difference in ulcer progress for 83 patients treated on the AP mattress compared with 75 patients treated on a fluid mattress overlay.35 The most recently published of the identified studies compared hospitalized patients on ventilators on AP beds with patients on air overlays and documented significant improvement (reduction in wound surface area) on the AP mattress, however the sample size was small (n=16).39 A poor-quality trial involving long-term care hospital patients in Japan found no significant difference in change in pressure ulcer surface area in patients on a specific type of AP bed (lateral rolling bed which moves residents from left side to back to right side on a timed cycle) compared with a traditional hospital bed. However, the mean stage of the pressure ulcers for patients on the rolling bed declined while the mean stage increased on the standard hospital bed.24 A poor-quality observational study published in 2012 reports on chart review data of patients admitted to long-term care beds between July 2001 and June 2002.

Physicians treated patients with pressure ulcers with either an AP overlay or a gel overlay. The study reported that a higher percentage of patients on the AP overlay experienced complete wound healing, but the difference was not statistically significant.40

###### Alternating Pressure Chair Cushions

AP is also used in chair cushions. Two studies compared AP cushions used in wheelchairs or day chairs with other types of cushions.25,38 One fair-quality trial of AP cushions, conducted in the United States, randomized 44 wheelchair users with spinal cord injuries living in the community who had stage II or III pressure ulcers to either an AP wheelchair cushion or a standard foam cushion for 30 days. People using the AP cushion experienced significantly better rates of healing measured as reduction in wound area, days to 30 percent wound closure, and probability of wound closure within 30 days.38

The second study of AP cushions included 25 hospital or nursing residents who used an AP cushion or a dry floatation cushion in their wheelchair or day chair. Pressure ulcers healed for three of 14 patients on AP cushions and five of 11 on the dry floatation cushions; however, this difference was not significant.25

###### Low-Air-Loss Beds

Five studies evaluated LAL mattresses,27,29,30,32,42 which use power to provide a flow of air that helps regulate heat and humidity and also may adjust pressure. All of these studies were conducted in the United States. Two trials and one observational cohort study followed hospitalized patients and two studied nursing facility residents. Four of the studies compared the LAL bed with a foam overlay27,29,42 or foam mattress30 and one compared an LAL bed with an LAL overlay (Table 4).26

Table 4 Support surfaces: Low-air-loss beds

Author Year Study Type Quality Number Enrolled/Completed Setting | Pressure Ulcer Stage^a^ | Mean Age (Range) Sex Population | Followup | Surfaces Compared | Outcome Measures and Treatment Effect | Benefit: Wound Improvement
Caley 1994^26^ Trial Poor N=93/55 Hospital | NR | 76 years (42–98) Female: 60% General | 1 month or until discharge; mean time in study 23.9 days | A: LAL bed (Monarch) B: LAL overlay | Wound surface area change (mean): A: 3.8 cm^2^ B: 10.2 cm^2^ (p=0.06) Healing progress over time: A: 0.22 B: 0.39 (p-0.10) Harms: NR | ~
Day 1993^27^ Trial Poor N=83/83 Hospital | II, III IV | Age: 76 years (32–102) Female: 58% General | Until discharge | A: LAL bed B: Foam overlay | Complete wound healing: No difference between groups (p>0.05) Change in wound surface area controlling for initial size: No difference between groups (p>0.05) No significant difference in comfort scores (n=39) Harms: NR | ~
Ferrell 1993^42^ Trial Good N=84/84 Nursing facility | III, IV | 85 years (NR) Female: 50% Elderly | Until healing, transfer, or, death | A: LAL bed (Kinair) B: Foam overlay | Complete wound healing: A: 60% B: 46% (p=0.19) Decrease in wound surface area: A: 9.0 mm^2^ per day B: 2.5 mm^2^ per day (p=0.0002) Harms: NR | ~/+ ~ complete healing + change is size
Mulder 1994^29^ Trial Poor N=49/39 Nursing facility | III, IV | Age: NR Female: NR General | Shorter of 12 weeks or ulcer completely healed | A: LAL bed (Therapulse) B: Foam overlay (GeoMatt) | Complete wound healing: A: 5/31 (16%) B: 3/18 (17%) (p-value NR) Change in ulcer area adjusted for initial stage: A more effective than B (p=0.042) Harms: No major adverse effects | ~/+ ~ complete healing + change is size
Warner, 1992^30^ Observational Poor N=20/20 Hospital | I, II, III | 64 years (NR) Female 45% General | Up to 4 weeks | A: LAL bed (Mediscus) B: Foam mattress with loose-fitting cover (Comfortex) | Complete wound healing: NR Progress to wound closure: Treatment A: mean 0.16 cm (SD 0.13) Treatment B: mean 0.27 cm (SD 0.23) No statistically significant difference ANOVA (f [1, 18] =1.568, p>0.05) Harms: NR | ~

LAL = low-air-loss; NPUAP = National Pressure Ulcer Advisory Panel; NR = not reported; NS = not significant; PU=pressure ulcer

a Pressure ulcer stage indicates NPUAP staging unless otherwise stated. Non-NPUAP staging was converted to the equivalent NPUAP stage where possible.

++Complete wound healing.

+Reduction in wound size.

~No difference.

None of the five studies found the LAL bed had a significant advantage over other surfaces for the study’s primary outcome. Two of the studies in long-term care compared LAL beds with foam overlays and reported mixed findings for residents with stage III or IV pressure ulcers: One study found no significant difference in complete wound healing, but did report a significantly larger reduction in surface area on the LAL bed.42 Similarly, the second study reported higher rates of wound healing and decrease in surface area, but no significant difference in complete healing.29

One poor-quality trial of LAL beds used with hospital patients compared the LAL mattress with foam overlays and found no significant difference in changes in wound surface area and no significant difference in comfort.27 A second observational study followed patients for up to 4 weeks and found no difference between the LAL bed and foam bed in terms of progress to wound closure.30 The study that compared an LAL bed with an LAL overlay for hospital patients also reported that there was no significant difference in changes in pressure ulcer surface area.26

###### Other Surfaces

Four studies compared a surface that was a new design to a surface that was the standard of care at the time or conducted a cost-effectiveness analysis.31–34 These four studies involved 361 total subjects. Two studies were conducted in the United States,32,34 one in Holland,31 and one in the United Kingdom.33 The experimental surfaces included a high-quality foam mattress, a profiling bed, an airbed with a foam overlay, and a total contact seat (see Table 5). Given these differences and the overall quality of the studies (one fair31 and three poor quality32–34) the evidence could not be summarized across the studies. Each study is described below and in Table 5.

Table 5 Support surfaces: Other surfaces

Author Year Study Type Quality Number Enrolled/Completed Setting | Pressure Ulcer Stage^a^ | Mean Age (Range) Sex Population | Followup | Support Surfaces Compared | Outcome Measures and Treatment Effect | Benefit: Wound Improvement
Branom 2001^32^ Trial Poor N=20/20 Long-term care hospital/post-acute center | Unclear (Stage III or IV, staging system not cited) | 74 years (36–100) Female: NR Bedridden | 8 weeks | B: Air bed with foam overlay (PressureGuard CFT) B: LAL bed | Healing rate as % of wound closed per week: A: 9% B: 5% (p-value NR; summary data only presented) Harms: NR | +
Groen 1999^31^ Trial Fair N=120/101 Nursing facility | II, III, IV (Grade III=superficial cutaneous or subcutaneous necrosis or Grade IV = deep subcutaneous necrosis. Grading system not cited) | 83 years (NR) Female: NR General | 4 weeks | A: High-quality foam replacement mattress (TheraRest) B: Water mattress (Secutex) | Complete wound healing: A: 45% B: 48.3% (NS; p-value NR) Harms: NR | ~
Keogh 2001^33^ Trial Poor N=100/70 (14 patients had pressure ulcers) Hospital | I (Grade 1 EPUAP Grade) | 70 (40–90) years Female: 45% General | 5 to 10 days | A: Profiling bed B: Conventional bed | Incidence of pressure ulcers was 0% in both groups Complete wound healing: A: 4/4 (100%) B: 2/10 (20%) (p-value NR) Harms: NR | ++
Rosenthal 2003^34^ Trial Poor N=207/203 Nursing home | III, IV (Stage III or IV, cites AHCPR Practice Guideline, 1984) | 70 years (NR) Female: NR General | 6 months or until healed | A: Generic total contact seat with adjustable air bladders (Sandia Labs) B: LAL bed (TheraPulse) C: Bed overlay-foam (Geo-Matt) | Median time to complete healing: A: 3.33 months B: 4.38 months C: 4.55 months (p<0.001 for A vs. B or C) No difference between B and C (p=0.58) Harms: 3 patients worsened on bed overlay and were withdrawn. | ++

AHCPR=Agency for Health Care Policy and Research, EPUAP=European Pressure Ulcer Advisory Panel, LAL=low-air-loss, NPUAP=National Pressure Ulcer Advisory Panel, NR=not reported, NS=not significant, PU=pressure ulcer

a Pressure ulcer stage indicates NPUAP staging unless otherwise stated. Non-NPUAP staging was converted to the equivalent NPUAP stage where possible.

++Complete wound healing.

+Reduction in wound size.

~No difference.

Three of the studies were in long-term care settings.31,32,34 The one fair-quality study followed nursing facility residents randomized to either foam or water mattresses for 4 weeks.31 In that time the number of residents who were completely healed was not significantly different on the two surfaces (45 percent on foam and 48.3 percent on water).31 A randomized trial compared the use of a seat with customized shape and air bladders, a LAL bed, and a foam bed overlay in the treatment of nursing facility residents and found that ulcers healed most quickly in patients treated up to 4 hours a day in the seat as opposed to a LAL bed or bed with overlay.34 The third study in long-term care treated the LAL bed as the standard of care and compared it with a less expensive air bed with foam overlay for 20 patients in a post-acute care center. The researchers reported that the wound surface area closures per week were similar or better on the air and foam bed (9 percent air/foam vs. 5 percent LAL, no statistical test or variance reported).32

A larger study of the incidence of pressure ulcers in hospital patients randomized patients to either a profiling bed (electronically controlled and designed to keep patients from slipping down in bed) or a conventional bed. The recruited subjects included a subset of 14 patients with stage I pressure ulcers on admission; four of the four on the profiling bed healed by discharge and two of 10 assigned to conventional beds healed (no statistical tests reported).33

##### Evidence About the Comparative Effectiveness of Support Surfaces by Subgroup Analysis (Key Question 1a, 1b, and 1c)

Most of the studies of support surfaces identified for this review did not include any subgroup analyses. Four studies presented some results by pressure ulcer characteristics,18, 19, 27, 34,42 addressing Key Question 1a, however these subgroup analyses were not always presented as part of the original analysis plan.

While initial stage of the pressure ulcer or size at enrollment were incorporated into results by reporting changes or by including these as variables in regressions or ANOVA analyses, four of the 23 studies addressed whether the effect of the support surface varied across patients with differences in baseline pressure ulcer severity.

In a study of hospitalized patients that compared two brands of AP mattresses, results were compared for pressure ulcers staged (as defined by the study authors) as IIa (persistent erythema with intact epidermis) compared with IIb (persistent erythema with epidermal loss). There was no significant difference in healing on the two beds, whether the results were combined or separated by ulcer stages.18,19

Nursing home residents using an LAL bed and a foam overlay were divided by whether their pressure ulcers were superficial or deep. However, the results were the same for the two categories with residents on the LAL beds experiencing a larger decrease in wound surface area regardless of the initial depth of the pressure ulcer.42

A comparison of LAL beds with foam beds in hospitals presented the initial and end size of ulcers separately for stage II and stages III/IV, but the authors did not discuss differences in healing by pressure ulcer stage and no test of differences by stage was provided. The data presented suggests that the change was similar on the two types of beds for stage II pressure ulcers, but that there was greater improvement on the LAL bed for stage III/IV pressure ulcers.27

In the comparison of a generic total contact seat with a LAL bed and foam overlay, the results were divided by the location of pressure ulcer. Pressure ulcers on the trochanter and coccyx healed more quickly on the total contact seat, while there was no significant difference in the time to complete healing for pressure ulcers located on the ischial tuberosity.34

None of the identified studies examined the impact of support surfaces by other patient characteristics (Key Question 1b).

None of the studies in a single setting reported on any relationships between setting characteristics and pressure ulcer outcomes. Three studies included both hospital patients and nursing home residents, but only one reported the results separately by setting20,21 and then only in one of two articles reporting the results of the trial.21 In this study comparing a specific brand of AP bed (Nimbus 3) with any other AP beds, the results were examined together and separately for the 12 hospital patients and the 20 nursing home residents, and no significant differences were found in wound size when the results were examined by setting.

##### Support Surfaces: Harms (Key Question 2)

Few of the identified studies, 7 of 24, explicitly addressed harms that could be attributable to or related to support surfaces.29,31,36,43–46 Harms were rarely mentioned in the study descriptions, discussions, or results of the articles about support surfaces. In these seven studies where harms were mentioned, four reported no significant differences in harms in the treatment and comparator groups. For this reason they are not reported in the tables above; however, they are described in the text that follows.

Four of the seven studies that mentioned harms were from the subgroup of five studies of AF beds. One study reported that a single patient on the AF bed had a severe episode of epistaxis requiring a transfusion that might have been caused by the drying action of the bed and four patients had trouble transferring in and out of the AF bed.43 Another study reported no significant differences in bleeding, granulation, necrosis, or nursing time on the AF beds compared with a variety of surfaces.44 In a study comparing AF beds with standard hospital beds, the author stated that they tested for dehydration, pulmonary congestion, confusion, and microsphere leakage. They found that none of the patients experienced these problems.46 The study of AF bed use in home care reported safety issues including minor mechanical problems that were corrected within 24 hours (six leaks and seven beds overheated), several cases (number not reported) of dry skin, and one case of mild dehydration.45

One29 of the three studies of LAL beds compared LAL beds with foam overlays and mentioned that no harms were identified, but did not specify what harms were considered. Pain was reported as a potential complicating factor in another study and was found not to differ across the support surfaces (foam and water beds) during the course of the trial.31

A large trial (n=1972; but n=113 in the treatment subgroup, the rest in prevention) of AP beds and AP overlays for both prevention and treatment reported nine mattress-related adverse events (four falls, three other slips, one suspected contact dermatitis, and one patient who caught his back on the bed rail) for the entire trial, but did not report whether these occurred in the prevention or treatment arm.36

##### Evidence About the Harms Related to Support Surfaces by Subgroups According to Pressure Ulcer Characteristics (Key Question 2a), Patient Characteristics (Key Question 2b), or Setting (Key Question 2c)

None of the identified studies examined harms by any subgroups.

### Effectiveness of Nutrition

Studies of risk factors for the development of pressure ulcers have found that signs of poor nutrition, such as low levels of prealbumin, vitamin C, or zinc, are associated with an increased incidence of pressure ulcers.50,51 Guidelines for pressure ulcer prevention developed by the European Pressure Ulcer Advisory Panel (EPUAP) and the United States National Pressure Ulcer Advisory Panel (NPUAP) include recommendations for providing high-protein, mixed nutritional supplementation to patients at risk for pressure ulcer development.52 These approaches provide the rationale for using various types of dietary supplements as a treatment for patients who have developed a pressure ulcer. The most widely studied nutritional intervention is the use of dietary protein or single amino acids. Vitamin and zinc supplements have also been examined as either sole interventions or in combination with protein-based supplements. Nutritional interventions have always been studied along with other interventions such as specialized beds and dressings. The predominant clinical view is that nutritional supplementation is one part of multi-component regimens to treat pressure ulcers.

#### Description of Studies

We identified eleven randomized controlled trials of nutritional interventions for the treatment of pressure ulcers. Three were rated good quality,53–55 two were rated fair quality,56,57 and six were rated poor quality.58–63 These trials were published between 1990 and 2012 and were conducted in the United States,60,61,63,64 Australia,55,59 Italy,53,58 Japan,62,65 and The Netherlands.54 Two trials were conducted in multiple European countries.56,57 The studies generally were small, with sample sizes ranging from 16–160 (total n=527). Only one study had more than 100 participants.56

We also identified five observational studies. Of these three were rated fair 66,67,68,69 and two were rated poor.70,71 These studies were conducted in the United States,64–66,68,70 Japan,64,65,69 and Australia.67 The sample sizes of the observational studies ranged from 7 to 70 (total n=192). The observational studies were published between 1993 and 2010.

Details extracted from each study are included in the evidence tables (see Appendix H, Table H-3). The assessments of the quality rating criteria used for each study are provided in Appendix H, Table H-4.

The populations in the studies were predominantly older patients, some with mobility impairment. Although not all studies reported prior nutritional status, only one study was conducted among patients without reported baseline malnutrition.57 Mean age of the patients ranged from 49 to 83 years. The two studies with the lowest mean ages both studied groups of patients with spinal cord injuries.64,67 All subjects had at least one pressure ulcer and the majority of studies included patients with ulcers ranging in stage from II–IV. Two observational studies also included patients with stage I ulcers61,69 (see details in Table 6). All studies included both male and female patients.

Table 6 Nutrition therapy: Protein or amino acid supplementation

Author Year Study Type Quality Number Enrolled/Completed Setting | Pressure Ulcer Stage^a^ | Mean Age (Range) Sex Population | Followup | Nutrition Interventions Compared | Outcome Measures and Treatment Effect | Benefit: Wound Improvement
Barnes 2007^70^ Observational Poor N=28/28 Hospital | III, IV | NR (NR) Female: NR Chronically malnourished | ≥30 days | A: Oral or enteral nutrition support to raise prealbumin levels B: No comparator | Complete wound healing: NR Wound healing rate: Significant improvement for patients with prealbumin levels > 9.0 mg/dL (0.82cc/day) vs. patients with prealbumin levels <9.0 mg/dL (0.02cc/day) (p<0.03) Harms: NR | +
Benati 2001^58^ Trial Poor N=36/16 Hospital | NR | NR (72–91 years) Female: 44% Severe cognitive Impairment | 2 weeks | A: Normal hospital diet B: High protein supplement C: High protein enriched with arginine, zinc and antioxidants | Complete wound healing: NR Improvement in pressure sore status tool scores in arms B and C, with greatest improvement in arm C (p-value NR) Harms: NR | ~
Breslow 1993^66^ Observational Fair N=48/28 Nursing facility | III, IV | 72 years (NR) Female: 57% Malnourished | 8 weeks | A: Oral or enteral nutrition supplement, 14% protein B: Oral or enteral nutrition supplement, 24% protein | Complete wound healing: NR Wound area reduction, all ulcer stages (% improvement): A: 2.1 cm^2^ (15%) B: 4.2 cm^2^ (15%) (p<0.02) Stage IV ulcers: A: 3.2 cm^2^ B: 7.6 cm^2^ (p<0.05) Harms: None | +
Brewer 2010^67^ Observational Fair N=35/35 Community | II, III, IV | 51 years (NR) Female: 3% Spinal cord injury | 10 months | A: Daily supplement of 9 mg of arginine (essential amino acid) B: Historical controls | Complete wound healing: A: 100% (n=30) B: 100% (n=26) Mean ulcer healing time: A: 11 weeks B: 21 weeks (p<0.05) Harms: NR | ++
Cereda 2009^53^ Trial Good N=30/28 Nursing facility | II, III, IV | 82 years (NR) Female: 64% Population: Elderly | 12 weeks | A: Oral nutrition supplement/enteral nutrition supplement B: Standard hospital diet | Complete Wound Healing: Documented for only 1 patient in A Wound area reduction, week 12: A: 68% B: 41% (p<0.005) Harms: No hospitalizations to treat complications. | +
Chernoff, 1990^63^ Trial Poor N=NR/12 Hospital | II, III, IV | 72 years (NR) Female: 58% Elderly, tube feeding dependant | 8 weeks | A: High protein (16% of calories) B: Very high protein (25% of calories) | Complete wound healing: A: 0% B: 67% (p-value NR) Reduction in ulcer size: A: 42% B: 73% (p-value NR) Harms: NR | +
Desneves 2005^59^ Trial Poor N=16/16 Hospital | II, III, IV | 73 years (37–92) Female: 38% Elderly | 3 weeks | A: Standard hospital diet B: Standard hospital diet plus high-protein, high-energy supplement C: Standard hospital diet plus arginine supplement | PUSH score at 3 weeks (lower is better) : A: 7.0 B: 6.0 C: 2.6 (p<0.05) Estimated time to complete healing: A: 16 weeks B: 15 weeks C: 5 weeks (p-value NR) Harms: NR | +
Lee 2006^60^ Trial Poor N=89/71 Nursing facility | II, III or IV | NR Female: NR Residents of long-term care facilities | 8 weeks | A: Standard care plus concentrated, fortified, collagen protein hydrolysate supplement, 3 times per day B: Standard care plus placebo, 3 times per day | Reduction in PUSH tool scores: A: 5.56 (60%) B: 2.85 (48%) (p<0.05) Harms; (discontinuations): Hip fracture due to fall (2), changes in renal lab values (3), nausea or distention (4), death (2). No difference between groups in rate of events (p>0.05) | +
Leigh 2012^55^ Australia Trial Good N=29/23 Nursing facility | II, III or IV | 69 years (NR) Female: 39% Elderly | 3 weeks | A: Standard hospital diet plus 4.5g arginine B: Standard hospital diet plus 9g arginine | Complete wound healing: A: 0% B: 0% Reduction in PUSH tool scores: A: 8.9 to 5.0 (56%) B: 9.0 to 5.9 (66%) (p<0.01) Estimated time to complete healing: A: 9 weeks B. 8 weeks (p=0.99) Harms: None | ~
Meaume 2009^56^ Trial Fair N=165/160 Hospital | II or III | 81 years (NR) Female: 57% Elderly | 6 weeks | A: Ornithine alpha-ketoglutarate (amino acid salt, precursor of glutamine, arginine, polyamines),10 g/day B: Placebo | Complete wound healing: A: 2% (n=2) B: 4% (n=3) Change in wound area (wounds with baseline area ≤ 8 cm^2^) A: −2.3cm^2^ B: −1.7 cm^2^ (p=0.0006) Wounds with baseline area > 8 cm^2^: no significant differences Closure rate A: −0.07 cm^2^/day B: 0.4 cm^2^/day (p=0.0007) Harms: 33 adverse events reported in 22 patients (15 OKG, 7 placebo). Higher incidence of gastrointestinal events in treatment group. No serious adverse events related to treatment. | +
Myers 1990^61^ Trial Poor N=80/80 Hospital | I to IV | 70 years (NR) Female: 43% General(NR) | 7 days | A: Wound care B: Nutritional support C: Wound care and nutritional support D: Standard hospital care | Complete wound healing: NR Wound surface area, mean change in ulcer size (% improvement): A: 2.76 mm (70%) B: 2.6 mm (70%) C: 2.34 mm (65%) D: 2.7 mm (50%) (p-value NS) | ~
Ohura 2011^62^ Trial Poor N=60/50 Hospital | III, IV | 81 years (58–95) Female: 68% Tube-fed patients | 12 weeks | A: Increased caloric intake of Racol® enteral nutrition B: Standard caloric intake of Racol® | Complete Wound Healing A: 24% (n=7) B : 19% (n=4) (p-value NR) Wound Area Reduction (% improvement): A: 30cm^2^ to 0.5cm^2^ (83%) B: 40cm^2^ to 7cm^2^ (82%) Ulcer Depth Reduction: Significant improvement in A vs. B (p<0.05) Harms: None | +
van Anholt 2010^57^ Trial Fair N=47/43 Health care centers, hospitals, Nursing facility | III, IV | 75 years (NR) Female: 56% General | 8 weeks | A: High energy enriched oral nutritional supplement B: Placebo | Complete wound healing: A: 27% (n=6) B: 24% (n=5) (NS; p-value NR) Wound area reduction (%improvement): A: 10.5cm^2^ to 2cm^2^ (81%) B: 11.5cm^2^ to 3cm^2^ (74%) (p=0.0006) Harms: Similar in both groups, including constipation, diarrhea, dyspepsia, nausea, and vomiting. | +
Yamamoto, 2009^69^ Observational Fair N=40/40 Hospital | I, II | 69 years (NR) Female: NR General | 6 weeks | Retrospective assessment of total energy intake through normal feeding and nutritional supplementation | Complete wound healing: 53% (n=21) healed or improved Wound area reduction: 53% (n=21) healed or improved Nutrition status: Patients that healed or improved had higher total energy intake and protein intake along with increased serum albumin levels and stable hemoglobin levels than patients that did not improve Harms: NR | +

NPUAP = National Pressure Ulcer Advisory Panel; NR = not reported; NS = not significant; OKG = ornithine alpha-ketoglutarate; PUSH = Pressure Ulcer Scale for Healing

a Pressure ulcer stage indicates NPUAP staging unless otherwise stated. Non-NPUAP staging was converted to the equivalent NPUAP stage where possible.

++Complete wound healing.

+Some improvement.

~No difference.

Six of the randomized trials used a protein-fortified formula that also included amino acids and micronutrients as the nutritional intervention.53,57–59,62,63 One trial used a single amino acid (arginine),55 one used a specialized amino acid compound,56 and another used a collagen protein hydrolysate.60 One trial used a variety of nutrition support measures61 and one used only vitamin C.54 Of the observational studies, five64,66,67,69,71 studied the use of protein-containing dietary supplements. One observational study evaluated zinc supplementation68 and two did not specify the type of nutritional supplement.65,70

The comparators used in four of the clinical trials were placebos similar in look and taste to the treatments.54,56,57,60 Four other clinical trials performed head-to-head comparisons. Two trials compared different doses of a nutritional supplement,55,63 and two trials compared a protein supplement to the same supplement plus arginine and vitamins.58,59 Three studies used standard nutritional care as the comparator.53,61,62 One observational study also performed a comparison between two different dosages of a protein supplement.66 Three observational studies did not report comparators.64,70,71

The key outcomes measured were complete wound healing, healing time, and reduced wound surface area. The most commonly reported harms were gastrointestinal events and infection.

The timing, or duration of followup for all but two of the studies ranged from 3 to 12 weeks. One study evaluated patients for 12 months67 and another study followed patients for 1 week.61

The setting for the studies included hospitals or long-term care facilities, and one study was conducted among people living in the community.67 The studies were conducted in Australia, Europe, Japan, and the United States.

#### Key Points

- When used in addition to other measures for treating pressure ulcers, protein-containing nutritional supplementation resulted in wound improvement (strength of evidence: moderate).
- The optimal dosage and form of protein has not been defined in nine clinical trials of protein supplementation (strength of evidence: insufficient).
- Vitamin C used as a single nutritional supplement does not result in wound improvement (strength of evidence: low).
- The evidence is insufficient to determine whether zinc supplementation improves pressure ulcer healing.
- Harms or adverse events were reported in about half of the studies (8 of 19), but they reported different harms, did not describe the harm, or did not specify if it was related to treatment (strength of evidence: insufficient).

#### Detailed Analysis

We were unable to conduct meta-analyses of nutritional supplementation treatment comparisons due to the small number of studies, the variety of specific nutritional formulas studied, and the poor quality of some of the clinical trials.

##### Evidence About the Comparative Effectiveness of Nutritional Supplementation (Key Question 1)

###### Protein-Containing Nutritional Supplements

The most frequently studied nutritional supplements were formulas that included a mixture of protein, carbohydrates, lipids, and various micronutrients. Although there were some differences in the content of the nutritional supplements used in the clinical trials, these differences were generally small. To assess whether protein supplementation in any form appears to provide benefit for the healing of pressure ulcers, we evaluated clinical trials that compared protein supplementation to a placebo or usual care comparator. One good-quality trial and one fair-quality trial used a liquid formula known as Cubitan that contains protein, arginine, zinc, and vitamin C.53,57 Both trials compared Cubitan supplementation to a placebo. In the good-quality trial,53 patients in the intervention group were provided an additional 500 kilocalories of the formula each day. In the fair-quality trial,57 patients in the intervention group were provided 750 more kilocalories of nutritional support than patients in the comparison group. The outcome measure in both studies was reduction in surface area of the pressure ulcer. Both studies found slightly greater reductions in ulcer size in the intervention groups by 8 to 12 weeks. Neither study examined complete healing of the pressure ulcers.

A fair-quality clinical trial examined the use of ornithine alpha-ketoglutarate (OKG) as a nutritional supplement.56 OKG is an amino acid salt containing ornithine and glutarate in a 2:1 ratio; it has been advocated as a stimulant of wound healing. The dose of OKG used in this trial was 10 grams per day and all participants had healed ulcers. The primary outcome was reduction in surface area of the ulcer at 6 weeks. The participants were stratified by size of the ulcer at baseline. In the subgroup with ulcers of 8 cm^2^ or less, the group given OKG had a greater reduction is ulcer size that the placebo group. There was no difference in ulcer size reduction in the subgroup having ulcers greater than 8 cm^2^ in size.56

Four poor-quality clinical trials also examined protein-based nutritional support.58,59,61,62 All of these trials were relatively small, with the largest trial enrolling 89 participants.60 All studies used measures of pressure ulcer size as the outcome variable, with followup periods ranging from 15 days to 12 weeks. All studies found greater reductions in pressure ulcer size in the intervention groups. One study assessed complete healing by 12 weeks.60 Complete healing occurred in 33 percent of the intervention group patients and in 14 percent of the control group patients. (difference not statistically significant). In this trial the intervention group patients received on average 27 percent higher protein and calorie intake than the control group patients.

A fair-quality observational study67 examined the use of arginine as a single amino acid for treating pressure ulcers. Participants receiving the intervention were treated with 9 g of arginine and 310 mg of vitamin C per day. The outcome measure was mean time to complete healing of the ulcer. The intervention patients had a mean time of 10.5 weeks while a historical control group had a mean time of 21.1 weeks. The only other study that examined arginine as a sole means of nutritional supplementation was a good-quality clinical trial that randomized patients to receive either 4.5 g or 9 g of arginine per day.55 Only 23 patients were enrolled and the pressure ulcers were followed for 3 weeks. The two groups did not differ in the mean reduction of size of the ulcers.

One poor-quality clinical trial61 examined generic nutritional support for patients with pressure ulcers. There was no difference in either ulcer size or ulcer stage, but followup in this study was only 7 days. Due to poor specification of the nutritional intervention and the limited duration of followup, this study provides little useful information.

A poor-quality clinical trial and a fair-quality observational study compared differing dosages of protein-containing nutritional supplements. The clinical trial randomized patients to receive either 16 or 25 percent of their calories as protein.63 The ulcer healing rate was faster in the group receiving 25 percent protein. In the observational study, patients were allocated in a nonrandomized fashion to either of two commercial nutritional formulas.66 One formula contained 14 percent protein and the other contained 24 percent protein. Reduction in ulcer area was greater in the group receiving the 24 percent protein formula. The analyses found that both protein intake and intake of total calories was associated with ulcer size reduction. While these studies do not define the optimal dosage of protein, both support the conclusion that protein supplementation enhances healing of pressure ulcers.

The studies of protein supplementation used a wide variety of formulations that included single amino acids (arginine), OKG, generic protein formulations, and formulas supplemented with vitamins. The studies uniformly showed small, positive benefits. In general, higher protein dosages appeared to provide better results. Although the nutritional formulas used in the studies are diverse, they have the common characteristic that they all include protein or amino acids. The most commonly studied outcome was size reduction rather than complete healing of ulcers. All of the studies also included other standard approaches (dressings and support surfaces) for pressure ulcer treatment, with protein supplementation being an adjunct to these other treatments.

Due to the consistency of findings across the studies, we concluded that the strength of evidence is moderate that protein supplementation improves healing of pressure ulcers (when used along with other standard treatments for pressure ulcers). Due to there being only a small number of head-to-head trials, the existing evidence base does not define whether any specific type of protein supplementation is superior to any others. All of the studies had relatively small sample sizes, and several were of poor quality.

###### Micronutrient-Containing Nutritional Supplements

Few other nutritional interventions for pressure ulcers have been studied. A good-quality clinical trial54 has examined ascorbic acid (vitamin C), and a fair-quality observational study68 has evaluated zinc supplementation. The clinical trial of vitamin C used a dose of 1000 mg per day for a population of nursing home patients in The Netherlands.54 About two-thirds of patients in both groups were judged to have poor nutritional status. The outcome measure was complete healing of pressure ulcers. About half of the ulcers had healed by 12 weeks, with no significant difference in healing rate between the vitamin C and placebo groups. This single good-quality study suggests that vitamin C as a single agent is ineffective, but the confidence in this conclusion is low given the lack of other studies (see Table 7).

Table 7 Nutrition therapy: Vitamin supplementation with vitamin C or zinc

Author Year Quality Study Type Number Enrolled/Completed Setting | Pressure Ulcer Stage^a^ | Age Sex Population | Duration/Followup | Nutrition Interventions Compared | Outcome Measures and Treatment Effect | Benefit: Wound Improvement
Houston 2001^68^ Observational Fair N=70/68 Nursing facility | II–IV | NR (NR) Female: NR Elderly | 30 days | A: 440 mg/day zinc sulfate B: Similar care without zinc sulfate supplementation | Complete wound healing: NR Wound healing: greater improvement in volume in Stage III and IV, not Stage II (p<0.05) No difference in surface area or complete closure Harms (A vs. B): Infection requiring antibiotic: Odds ratio=7.8 (p=0.0009) Nausea/vomiting: Odds ratio=12.5 (p=0.02) | ~
Ter Riet54,b Trial Good N=88/67 Nursing facility/hospital | II, III | NR (NR) Female: NR Residents of nursing facilities | 12 weeks | A: Ascorbic acid supplementation, 500 mg twice daily B: Ascorbic acid, 10 mg twice daily | Complete wound healing: A: 40% (n=17) B: 55% (n=25) Mean wound surface area reduction per week: A: 13.9% B: 22.9% (NS) No difference between groups in wound survival curves (projected time to healing) Harms: None | ~

NPUAP = National Pressure Ulcer Advisory Panel; NR = not reported; NS = not significant

a Pressure ulcer stage indicates NPUAP staging unless otherwise stated. Non-NPUAP staging was converted to the equivalent NPUAP stage where possible.

b A 1974 publication, Taylor also evaluated Vitamin C but did not meet the inclusion criteria because of our 1985 cutoff.

++Complete wound healing.

+Some improvement.

~No difference.

The study of zinc supplementation performed a retrospective analysis comparing patients who had been prescribed zinc sulfate 440 mg per day to patients who had not been prescribed this supplement.68 After controlling for patient characteristics, there was no difference between the two groups in ulcer healing rates over 30 days. This study is limited by its small size and retrospective design. We concluded that the evidence is insufficient to draw a conclusion about zinc as a single agent to enhance pressure ulcer healing.

##### Evidence About the Comparative Effectiveness of Nutrition by Subgroup-Analysis (Key Question 1a, 1b, and 1c)

Because of the generally small sample sizes of the studies in this category, there was limited power to detect subgroup effects. All of the information about sub-groups comes from studies of protein-containing supplements. The clinical trial of vitamin C54 found no subgroup effects for this intervention.

In the one study of OKG,56 the study participants were stratified by size of the pressure ulcer at baseline (all participants had healed ulcers). The beneficial effect of OKG was found only in the subgroup with ulcer sizes of 8 cm^2^ or smaller. While other studies included patients with varying sizes of pressure ulcers, none examined this factor in the data analyses.

There is some evidence that a patient’s baseline nutritional status may affect whether protein-containing nutritional supplementation accelerates ulcer healing. A fair-quality observational study compared patients whose pressure ulcers improved to those whose ulcers did not improve.64,65,69 Patients in the group that improved had a higher sustained daily calorie intake than those in the unimproved group. A poor-quality observational study stratified patients by baseline level of prealbumin in an open-label study of generic nutritional support.70 Patients with a baseline prealbumin level of less than 8 mg/dL showed little healing of pressure ulcers. Because prealbumin reflects sustained calorie intake, these two studies suggest that adequate calorie intake is necessary for protein-containing supplements to be effective.

In general, the published clinical trials did not include severely malnourished patients. The clinical trials evaluating OKG,56 Cubitan,53,57 another product similar to Cubitan,59 and a protein hydrolysate60 included subjects whose body mass indexes were between 20 and 30. A poor-quality clinical trial of a protein supplement enrolled patients having a mean body mass index of 18.6^62^ This study found a significantly higher rate of complete healing of pressure ulcers in the group given the nutritional supplement. Overall, there are too few studies that included participants with very poor baseline nutritional status. Thus, there is insufficient indirect evidence to determine whether baseline nutritional status affects the results of using protein-containing nutritional supplements.

All but one of the studies were conducted in inpatient or nursing home settings. The one study conducted among community-dwelling individuals67 had findings similar to those of the other studies. There were no trends toward different results in nursing home settings than in acute-care hospital settings.

##### Nutritional Supplementation: Harms (Key Question 2)

Eight studies reported information about harms or adverse events. Six of these were studies of protein supplements and two were studies of nutrients. Harms were not always described, nor was it always clear whether they were attributed to treatment. The most commonly reported harms were gastrointestinal events and infection. Studies did not always specify whether the harms could be reasonably attributed to the treatment.

Five clinical trials provided information about harms related to the use of protein-containing supplements. In the study of OKG, diarrhea, vomiting, and nausea occurred in 12 percent of patients randomized to the active product and in 7 percent of patients randomized to the placebo.56 In the study of a protein hydrolysate, adverse event rates were reported to be equal in the two study arms, but the actual rates were not reported.60 A study including 50 patients reported study-related adverse events in five controls (16.7 percent) and eight intervention patients (27.6 percent), but these events were not described and the authors report that the difference in the rate of the events is not significantly different for the two groups.62 Another study of mixed nutritional supplementation reported that none of the 28 patients studied were hospitalized to treat complications of treatment and that the control group had slightly higher occurrence of infection (9 vs. 3 points, p=0.07) and greater number of days of antibiotic therapy (103 vs. 36, p<0.001).53 In a study that followed 43 patients, 41 adverse events were reported in 16 patients in the treatment group and 35 events for 13 patients in the control. Most (88 percent) of the events were considered were mild or moderate. Four in the control group were related to treatment (two diarrhea, one nausea, and one vomiting) compared with nine in the intervention group (six diarrhea, one constipation, and dyspepsia, and one nausea). Overall, 41 percent of those receiving the supplement and 19 percent of those receiving placebo reported diarrhea, constipation, dyspepsia, or nausea. These differences between the groups were not significant.57

In the multicenter trial of amino acid supplementation, involving 160 patients, 33 mild to moderate adverse events were reported for 22 patients (15 in the intervention group and seven in placebo) that were considered related to study medication. Gastrointestinal events were more common in intervention patients, but more serious gastrointestinal events (diarrhea, vomiting and nausea) were evenly distributed with 68 percent of events in the intervention group and 67 percent in the placebo group, suggesting the difference is in mild events. There were 30 serious adverse events reported during the course of the study, but none were considered treatment related.56 In a study comparing high and low protein supplementation among 28 patients, recurring mild diarrhea was reported in one patient receiving high protein (24 percent) in the tube feeding group and mild to severe diarrhea was reported in one patient each in the high and lower protein group receiving tube feeding, but no problems were reported for any patients receiving oral nutrition.66 Another study of protein supplementation that included 71 patients reported reasons for study discontinuation by 11 patients (two hip fractures, three change in renal lab values; four nausea or distention, and two patients died) and added that there was no significant difference in events for the intervention and comparison group but did not discuss whether these reasons were related to the treatment.60

Nausea also is a side effect associated with zinc treatment. In the observational study of zinc supplementation, nausea or vomiting occurred in 20 percent of those receiving the zinc sulfate and 2 percent of those not receiving the product.68

##### Evidence About the Harms Related to Nutritional Supplementation by Subgroups According to Pressure Ulcer Characteristics (Key Question 2a), Patient Characteristics (Key Question 2b), or Setting (Key Question 2c)

No studies reported subgroup analyses to evaluate harms by ulcer, patient, or setting characteristics.

### Effectiveness of Local Wound Applications

Wound dressings are a mainstay of pressure ulcer treatment. Dressings serve multiple functions, including padding and protection of the ulcer from pressure and friction, providing a moist wound environment and protection against drying, serving as a barrier in patients with incontinence or other sources of wound contamination, absorbing wound exudate, and promoting autolytic debridement of necrotic tissue and slough. Topical ointments and other therapies such as fibrinolytic enzymes and antimicrobial agents are also used in pressure ulcer management to provide moisture, promote tissue debridement, and eliminate or prevent infection. Finally, biological agents, particularly cellular growth factors, are used to enhance pressure ulcer healing by promoting angiogenesis, epithelialization, and connective tissue deposition.

Different types of local wound applications have different primary functions and the choice of a particular therapy or combination of therapies is often guided by the features and severity of the ulcer. For many pressure ulcers, however, there is more than a single therapeutic need (e.g., exudate absorption, tissue debridement, moist environment), and the most appropriate choice of dressing or topical therapies is not always clear. The harms of different treatments also differ. Studies have therefore compared the effectiveness and harms of different local wound applications for pressure ulcers.

#### Description of Studies

We identified two systematic reviews that were used for background and 89 original studies, reported in 92 articles published between 1985 and 2012, examining the effectiveness and/or harms of local wound applications for pressure ulcers in a total of 7,115 patients. Seventy-six of the original studies were clinical trials. Of these, 11 were rated as good-quality studies, 20 as fair, and 45 as poor. Sample sizes in the trials ranged from 10 to 168 patients. There were 13 observational studies, including two cohort studies with concurrent intervention and control groups, one pre-post intervention study, and three studies describing outcomes of a single series of patients who all received the same intervention. One cohort study was rated as fair quality and the other observational studies were poor quality.

Details extracted from each study are included in the evidence tables (see Appendix H, Table H-5). The assessments of the quality rating criteria used for each study are provided in Appendix H, Table H-6.

The populations in most studies were elderly patients (mean age typically between 70 and 85) with 11 studies including patients with spinal cord injury who were typically younger (mean age between 30 and 50). There was a relatively even distribution of men and women across studies, except in the spinal cord injury populations, which were predominantly men. Patient race and ethnicity were infrequently reported. Most studies included NPUAP stage II and III ulcers, except for studies of biological agents, in which most patients had stage III and IV ulcers. Ulcer sites varied widely, but most commonly included the sacrum, trochanter, ischium, buttocks, and heel.

The interventions studied included a wide range of dressings, topical treatments, and biological agents.

- Dressings come in a variety of forms and serve various functions. Dressings within a given category vary in design and composition, but generally have several common features.
  ○ Hydrocolloid dressings were the most commonly studied. These are adhesive wafers that absorb wound fluid to form a gelatinous mass that conforms to the wound and creates a protective and moist wound environment.
  ○ Hydrogel dressings are moisture-producing and are commonly used to hydrate dry wounds.
  ○ Transparent films are clear, semipermeable membranes that provide a protective barrier that allows wound visualization and promote autolytic debridement.
  ○ Foam and polymeric membrane dressings provide wound padding and protection and absorb exudate.
  ○ Silicone dressings offer benefits similar to foam dressings, but are less adhesive and have the potential to reduce skin damage during dressing changes.
  ○ Alginates are seaweed-derived dressings that are typically used to absorb large amounts of exudate.
  ○ Radiant heat dressings are noncontact dressings attached to a heating element that provides warmth intended to promote wound healing by increasing capillary blood flow and resistance to infection.
  ○ Gauze dressings are fabrics used to protect wounds and provide a wet or dry wound environment and are often used in conjunction with topical solutions and ointments. Gauze dressings are often considered conventional care and used as the comparator in studies of other types of dressings.
- A wide variety of topical ointments and solutions have been used in the treatment of pressure ulcers. Common topical therapies include antimicrobials, enzymes promoting tissue debridement, polymeric pastes (e.g., dextranomer) that absorb wound exudate, and phenytoin, which is thought to promote wound healing through a variety of mechanisms.
- Biological agents include primarily cellular growth factors, most notably platelet-derived and fibroblast-derived growth factors.

Cointerventions were variably reported. In studies that did report them, cointerventions applied to intervention and comparator groups most often included debridement, saline cleansing, pressure-relieving surfaces, and repositioning.

The comparators in most studies of dressings and topical treatments were other dressings and/or topical treatments. Some studies used “usual” or “conventional” care as the comparison group, which typically included moist gauze dressings, but in some cases was not described. For most studies of biological agents, the comparison group received a placebo.

The outcomes reported in most studies included complete wound healing, time to complete healing, and/or reduction in wound surface area or volume. Few studies reported pain reduction or wound infection as an outcome, and no studies reported on infectious complications such as osteomyelitis or sepsis. Most studies did not report harms of treatment. Harms that were reported included dermatologic complications such as rash or skin maceration, hypergranulation, wound deterioration, and summative counts of overall adverse events. Some studies reported on costs of care, though the methods used to calculate costs were usually not well described. No studies reported on measures of utilization such as length of hospital or nursing home stay.

The timing of studies, in terms of median ulcer duration prior to intervention, was typically 3 weeks to 3 months, though some studies included ulcers with duration of 1 to 2 years. Most interventions lasted 3 to 12 weeks.

The setting for these studies included hospitals (n=37), long-term care facilities (n=23), wound care clinics (n=5), and patients’ homes (n=9). Some studies were implemented in a variety of settings. Most studies were conducted in the United States or Europe, although several studies were conducted in other parts of the world.

#### Key Points

##### Dressings

- Wound improvement was superior with hydrocolloid compared to gauze dressings (10 studies, strength of evidence: low).
- Wound improvement were similar with hydrocolloid and foam dressings (pooled relative risk (RR) 1.12; 95% confidence interval (CI), 0.88 to 1.41; I^2^=16.4%; p=0.301) (eight studies, strength of evidence: moderate).
- There was insufficient evidence regarding the comparative effectiveness of hydrogel, transparent film, silicone, and alginate dressings.
- Radiant heat dressings produced more rapid wound improvement than other dressings but were similar to other dressings in terms of complete wound healing (pooled RR 1.32, 95% CI, 0.88 to 1.98, I^2^=0.0% p=0.985) (four studies, strength of evidence: moderate).

##### Topical Therapies

- Evidence about the effectiveness of collagenase and other debriding enzymes was inconclusive due to differences in the enzymes studied and in outcomes measured (five studies, strength of evidence: insufficient).
- Three studies of the effectiveness of topical phenytoin used different comparators and produced inconsistent results (strength of evidence: insufficient).
- Dextranomer paste was inferior to wound dressings (alginate, hydrogel) in promoting wound area reduction (two studies, strength of evidence: low).
- Wound improvement was similar with topical collagen applications compared with hydrocolloid dressings or standard care (three studies, strength of evidence: low).
- There was insufficient evidence about the effectiveness of maggot therapy, based on three poor-quality observational studies (strength of evidence: insufficient).

##### Biological Agents

- Platelet-derived growth factor was superior to placebo in producing wound improvement in stage III and IV pressure ulcers (three studies, strength of evidence: low).
- There was insufficient evidence about the effectiveness of other biological agents used for the treatment of pressure ulcers due to limitations in the number, size, and quality of studies.

##### Harms of Local Wound Applications

- Harms reported with dressings and topical therapies for pressure ulcers most commonly included skin irritation and inflammation and tissue damage and maceration (31 studies, strength of evidence: moderate). Variability in study populations, interventions, adverse event measurement, and reporting precluded an estimate of adverse event rates for dressings and topical therapies.
- There was insufficient evidence as to whether specific dressing types or topical therapies are associated with fewer harms than others due to poor study quality and differential reporting of harms across studies (seven studies).

##### Subgroups

- Few harms were reported with biological agents but evidence did not allow an estimate of the incidence of harms, due to lack of precision across studies. (strength of evidence: insufficient).
- There was insufficient evidence about differences in the effectiveness or harms of wound dressings, topical treatments, or biological agents according to ulcer, patient, or setting characteristics.

#### Detailed Analysis

Our analysis is grouped by key question and placed in subgroups based on comparisons within and across the general categories of wound dressings, topical therapies, biological agents, and conventional care (most commonly gauze dressings).

##### Evidence About the Comparative Effectiveness of Local Wound Applications (Key Question 1)

###### Wound Dressings Compared With Conventional Care

Studies comparing wound dressings with conventional care are described below and in Tables 8–11.

Table 8 Local wound applications: Wound dressings compared with conventional care – hydrocolloid dressings

Author Year Study Type Quality Number Enrolled/Completed Setting | Pressure Ulcer Stage^a^ | Mean Age (Range) Sex Population | Followup | Wound Applications Compared | Outcomes Measured and Treatment Effect | Benefit: Wound Improvement
Alm 1989^73^ Trial Fair N=50/50 Hospitals | NR | 83 years (NR) Female: 75% Long-term ward patients | 6 weeks | A: Hydrocolloid B: Saline gauze | Complete wound healing: (remaining ulcer area at 6 weeks) A: 0% B: 31% (p=0.016) Harms: None | ++
Chang 1998^75^ Trial Poor N=34/34 Hospital | II, III | 58 years (20–85) Female: NR Neurological problems or cancer | 8 weeks | A: Hydrocolloid (DuoDerm) B: Saline gauze | No significant difference in surface area change (A, 34% reduction; B, 9% increase; p=0.23) No harms observed in A. One wound infection in B. | ~
Colwell 1993^76^ Trial Poor N=94/70 Hospital | II, III | 67 years (18–100) Female: 47% General | 14 months | A: Hydrocolloid (DuoDerm) B: Saline gauze | Complete wound healing: A: 22% B: 2% (p-value NR) Wound area reduction: A: 0.73 cm reduction B: 0.67 cm increase (NS; p-value NR) Harms: NR | ++
Gorse 1987^77^ Trial Poor N=52/52 Hospital | III, IV | 70 years (NR) Female: 0% > 70% nonambulatory | Days of followup: range: 5–40 days | A: Hydrocolloid (DuoDerm) B: Saline gauze + chloramine-T (Dakin’s solution) | Complete wound healing: (reports “healed or healing”) A: 87% B: 69% (p=0.026) Treatment days: A: 10.0 days B: 8.7 days (NS; p-value NR) Harms: No patients reported pain related to application and removal of A, but pain associated with B was a common complaint (data NR). | +
Hollisaz 2004^72^ Trial Good N=83/83 Nursing facility or home | I, II | 37 years (NR) Female: 0% Spinal cord injury | 8 weeks | A: Hydrocolloid B: Saline gauze C: Simple dressing | Complete wound healing: A: 74% B: 27% (p<0.01) Harms: NR | ++
Kim 1996^78^ Trial Poor N=44/44 Rehabilitation department | I, II | 49 years (NR) Female: 18% General | 3 weeks | A: Hydrocolloid (DuoDerm) B: Wet-to-dry gauze dressing, iodine | Complete healing A: 80% B: 78% (NS; p-value NR) Lower overall treatment cost in A. Harms: NR | ~
Mulder 1993^79^ Trial Poor N=67/60 Inpatients and outpatients at 3 sites | II, III | 59 years (23–86) Female: 15% General | 8 weeks | A: Hydrogel (Clearsite) B: Hydrocolloid (DuoDerm) C: Wet-to-moist gauze | No significant differences in weekly wound size change (p=0.89) Harms: inflammation and excoriation in A (12%); minor irritation and skin sensitivity in B (14%). | ~
Neill 1989^80^ Trial Poor N=65/65 Tertiary care facility | III | NR Female: NR General | 15 months | A: Hydrocolloid (Tegasorb) B: Saline gauze (WTD) | Complete wound healing: A: 50% B: 40% (NS; p-value NR) Wound size reduction (median): A: 46% B: 43% (NS; p-value NR) Harms (adverse reaction to dressing): A: 18% B: 2% (p<0.006) | +
Winter 1990^81^ Trial Poor N=114/46 Inpatient and outpatient | NR “Ordinary vs. difficult” ulcers | Median 74 years (25–93) Female: 67% General | 12 weeks | A: Hydrocolloid B: Paraffin gauze | Complete wound healing: A: 63% B:19% (p-value NR) Harms: NR | ++
Xakellis 1992^74^ Trial Fair N=39/39 Nursing facility | III | 81 years (NR) Female: 92% General | 6 months | A: Hydrocolloid B: Saline gauze | Complete wound healing: A: 89% B: 86% (p-value NR) Healing time: (median time to healing) A: 9 days B: 11 days (p=0.12) Harms: NR | ~

NPUAP = National Pressure Ulcer Advisory Panel; NR = not reported; NS = not significant

a Pressure ulcer stage indicates NPUAP staging unless otherwise stated. Non-NPUAP staging was converted to the equivalent NPUAP stage where possible.

++Complete wound healing.

+Some improvement in wound healing.

~No difference.

Table 9 Local wound applications: Wound dressings compared with conventional care – hydrogel dressings

Author Year Study Type Quality Number Enrolled/Completed Setting | Pressure Ulcer Stage^a^ | Mean Age (Range) Sex Population | Followup | Wound Applications Compared | Outcomes Measured and Treatment Effect | Benefit: Wound Improvement
Kaya 2005^83^ Trial Poor N=27/27 Hospital | I, II, III | 19 years (16–56) Female: 84% Spinal cord injury | 15 weeks | A: Hydrogel (Coloplast) B: Iodine gauze | Complete wound healing: A: 84% B: 54% (p=0.04) No difference between groups in healing rate (p=0.40) or healing time (p=0.06) Harms: NR | +
Matzen 1999^82^ Trial Poor N=32/12 Clinic | III, IV | 83 years (32–97) Female: 84% General | 12 weeks | A: Hydrogel (Coloplast) B: Saline gauze | Complete healing: A: 29% B: 0% (p-value NR) Lower ulcer volume (p<0.02) and less need for repeat debridement in A (p<0.03). Harms: NR | ~
Mulder 1993^79^ Trial Poor N=67/60 Inpatients and outpatients at 3 sites | II, III | 59 years (23–86) Female: 15% General | 8 weeks | A: Hydrogel (Clearsite) B: Hydrocolloid (DuoDerm) C: Wet-to-moist gauze | No significant differences in weekly wound size change (p=0.89). Harms: inflammation and excoriation in A (12%); minor irritation and skin sensitivity in B (14%). | ~
Parnell 2005^85^ Observational Poor N=10/7 Nursing facility | II, III | Age: NR Female: NR Nursing facility residents | 12 weeks | A: Post topical hydrogel with endopeptidase enzymes (Hydrovase) + gauze B: Before treatment | Complete wound healing: A: 50% B: 0% (p-value NR) Harms: Skin irritation and wound deterioration | ++
Thomas 1998^84^ Trial Poor N=41/30 Community | II, III, IV | 77 years (35–97) Female: 54% General | 10 weeks | A: Topical hydrogel dressing B: Saline gauze | Complete wound healing: A: 63% B: 64% (NS, p-value NR) Mean time to healing: A: 5.3 weeks B: 5.2 weeks (p=0.87) Harms: (worsening of ulcer) A: 6% B: 7% | ~

NPUAP = National Pressure Ulcer Advisory Panel; NR = not reported; NS = not significant

a Pressure ulcer stage indicates NPUAP staging unless otherwise stated. Non-NPUAP staging was converted to the equivalent NPUAP stage where possible.

++Complete wound healing.

+Some improvement in wound healing.

~No difference.

Table 10 Local wound applications: Wound dressings compared with conventional care – foam dressings

Author Year Study Type Quality Number Enrolled/Completed Setting | Pressure Ulcer Stage^a^ | Mean Age (Range) Sex Population | Followup | Wound Applications Compared | Outcomes Measured and Treatment Effect | Benefit: Wound Improvement
Kraft 1993^88^ Trial Poor N=38/38 Hospital | II, III | 56 years (28–78) Female: NR Geriatric and spinal cord injury | 24 weeks | A: Polyurethane foam (Epi-Lock) B: Saline gauze | Complete wound healing: A: 42% B: 21% (p-value NR) Lower calculated cost in A. Harms: NR | ++
Payne 2009^87^ Trial Poor N=36/27 Inpatient, outpatient, long-term care | II | 73 years (NR) Female: 39% General | 4 weeks | A: Polyurethane foam B: Saline gauze | Median time to healing: 28 days in both groups). Lower overall cost in A. Harms: NR | ~
Yastrub 2004^86^ Trial Poor N=50/44 Nursing facility | II | NR (>65) Female: NR Elderly | 4 weeks | A: Polymer membrane dressing B: Dry clean dressing (gauze + antibiotic ointment | Complete wound healing: NR Improvement in wound healing: A: 87% B: 65.2% Harms: NR | +

NPUAP = National Pressure Ulcer Advisory Panel; NR = not reported

a Pressure ulcer stage indicates NPUAP staging unless otherwise stated. Non-NPUAP staging was converted to the equivalent NPUAP stage where possible.

++Complete wound healing.

+Some improvement in wound healing.

~No difference.

Table 11 Local wound applications: Wound dressings compared with conventional care – transparent film dressings

Author Year Study Type Quality Number Enrolled/Completed Setting | Pressure Ulcer Stage^a^ | Mean Age (Range) Sex Population | Followup | Wound Applications Compared | Outcomes Measured and Treatment Effect | Benefit: Wound Improvement
Kurzuk-Howard 1985^90^ Trial Poor N=43/43 Hospital | I–IV | 77 years (36–94) Female: 70% General | 20 days | A: Transparent film (Op-Site) B: Usual care (variable) | Complete wound healing: 14/43 overall (33%); no analysis between groups. No difference between groups on other measures. Harms NR | ~
Oleske 1986^91^ Trial Poor N=16/15 Hospital | I, II | 69 years (52–93) Female: NR General | 10 days | A: Transparent film (Op-Site) B: Saline gauze | Wound surface area reduction: A: 43% B: 3% (p-value NR) Harms NR | +
Sebern 1986^89^ Sebern 1989 Trial Poor N=48/48 Community | III | 74 years (NR) Female: NR Chronic illness, SCI, Neurological disorders | 8 weeks | A: Transparent moisture vapor permeable dressing (MVP) B: Saline gauze | Complete wound healing (Grade II ulcers; N=34): A: 64% B: 0% (p<0.01) Wound area reduction (median improvement): A: 100% B: 52% (p<0.05) No differences between groups for Grade III ulcers (N=14) Harms: (wound deterioration or discontinued, Grade II ulcers) A: 14% B: 58% (p<0.01) | ++

MVP = moisture vapor permeable; NPUAP = National Pressure Ulcer Advisory Panel; NR = not reported; SCI = spinal cord injury

a Pressure ulcer stage indicates NPUAP staging unless otherwise stated. Non-NPUAP staging was converted to the equivalent NPUAP stage where possible.

++Complete wound healing.

+Some improvement in wound healing.

~No difference.

###### Hydrocolloid Dressings

Ten trials, one good quality,72 two fair quality,73,74 and seven poor quality,75–81 including a total of 670 patients compared hydrocolloid with gauze dressings, typically saline gauze. Overall, wound improvement was better with hydrocolloid, though several studies found no statistically significant differences in outcomes between intervention and control groups. We attempted to meta-analyze results from the seven trials reporting complete wound healing as an outcome, but statistical heterogeneity precluded quantitative pooling of results. The single good-quality study reported better rates of complete wound healing with hydrocolloid compared with saline gauze (74 percent vs. 27 percent) over an 8-week timeframe among patients with stage I and II ulcers.72 The two fair-quality studies included 105 patients and were conducted in hospitals73 and a long-term care facility.74 The former study, which included shallow ulcers, found significantly more complete wound healing after 6 weeks with hydrocolloid (see Table 8 below). The latter study, which included stage III ulcers, found no significant difference in complete healing or time to healing between hydrocolloid and saline gauze dressings. Results were similarly mixed in the poor-quality studies, with one77 reporting significantly better wound improvement with hydrocolloid in patients with stage III and IV ulcers.

###### Hydrogel Dressings

Four poor-quality trials79,82–84 compared hydrogel dressings with gauze. The poor quality and inconsistency of results across studies limited the ability to draw conclusions. Complete wound healing was significantly better with hydrogel than gauze with iodine (84 percent vs. 54 percent) in one study of hospitalized patients with stage I, II, and III ulcers.83 The other three studies reported no significant difference.

###### Foam Dressings

Three poor-quality studies provided insufficient evidence about the effectiveness of foam vs. gauze dressings. One poor-quality study among patients with stage II ulcers found greater improvement in Pressure Ulcer Scale for Healing (PUSH) scores with a polymeric foam dressing compared with dry gauze with antibiotic ointment.86 Two poor-quality trials comparing polyurethane foam dressings to gauze found no significant differences in time to healing87 or complete wound healing.88 Both studies reported lower overall costs with foam dressings, attributable to fewer dressing changes and consequently less personnel time.

###### Transparent Film Dressings

Three poor-quality trials provided inconsistent results about the effectiveness of transparent film dressings. In one 8 week trial,89 more complete wound healing was found in a transparent moisture vapor permeable (MVP) dressing compared with saline gauze (64 percent vs. 0 percent). The benefits of the MVP dressing were observed only in less advanced ulcers (Shea grade II but not III). Two studies90,91 found no significant differences between transparent film (Op-Site) dressings and gauze.

###### Comparisons of Different Wound Dressings

Comparisons of different wound dressings are described below and in Table 12–16.

Table 12 Local wound applications: Comparisons of different wound dressings – hydrocolloids vs. other dressings

Author Year Study Type Quality Number Enrolled/Completed Setting | Pressure Ulcer Stage a | Mean Age (Range) Sex Population | Followup | Wound Applications Compared | Outcome Measures and Treatment Effect | Benefit: Wound Improvement
Hydrocolloid vs. Hydrocolloid
Day 1995^92^ Trial Fair N=103/96 Hospital (acute care) | II, III | 75 years (NR) Female: 49% Elderly, poor health | 10 days (mean) | A: Hydrocolloid triangle dressing B: Hydrocolloid oval | Complete wound healing: A: 36% B: 22% (p=0.17) Wound area reduction (width): A: 32% B: 17% (p=0.034) Wound area reduction (length): A: 28% B: 24% (NS; p-value NR) Reduction in pain: (baseline vs. final) A: 47% vs. 18% B: 39% vs. 32% Pain higher at final assessment in B (p=0.04) Harms (wound deterioration): A: 4% B: 31% (p<0.05) (erythema, severe pain, increase in necrotic tissue, wound size, and depth): A: 4% B: 31% | + (triangle dressing superior)
Hydrocolloid vs. Hydrogel
Darkovich 1990^93^ Trial Poor N=90/90 Acute care and nursing facility | II Stage I, II (Enis & Sarmieti) | 75 years (30–98) Female: 55% General | 60 days | A: Hydrogel (BioFilm) B: Hydrocolloid | Complete wound healing: A: 43% B: 24% Healing time: (mean treatment days) A: 12 B: 11.3 Wound area reduction: A: 68% B: 40% Harms: (wound deterioration) A: 1.5% B: 10% (p-values NR) | ++
Motta 1999^94^ Trial Poor N=10/10 Setting | II, III | 60 years (NR) Female: 50% General | 8 weeks | A: Hydrogel polymer (Flexigel) B: Hydrocolloid (DuoDerm) | Complete wound healing: 40% in both No differences in wound improvement or healing rate Fewer dressing used (with lower total cost) in A Harms: NR | ~
Mulder 1993^79^ Trial Poor N=67/60 Inpatients and outpatients at 3 sites | II, III | 59 years (23–86) Female: 16% General | 8 weeks | A: Hydrogel (Clearsite) B: Hydrocolloid (DuoDerm) C: Wet-to-moist gauze | No significant differences in weekly wound size change (p=0.89). Harms: inflammation and excoriation in A (12%); minor irritation and skin sensitivity in B (14%). | ~
Hydrocolloid vs. Transparent Film
Brown-Etris 2008^95^ Trial Fair N=72/72 Wound care clinic, home, nursing facility | II, III | 75 years (NR) Female: 56% General | 8 weeks | A: Acrylic (Tegaderm) B: Hydrocolloid (DuoDerm) | No difference in complete wound healing (60% in both arms; p=0.96). Harms: None | ~
Hydrocolloid vs. Foam
Bale 1997^96^ Trial Fair N=51/50 NR | II–III (Stirling) | 74 years (NR) Female: 55% general | 30 days | A: Polyurethane foam B: Hydrocolloid | Complete wound healing: A: 24% B: 16% (p-value NR) Harms: One case of rash in group A. No harms observed in group B. | ~
Bale 1998^102^ Trial Poor N=32/32 Community | II, III | 76 years (NR) Female: 77% General | 8 weeks | A: Hydrocolloid dressing B: Hydrocellular dressing | Complete wound healing: A: 59% B: 27% (p-value NR) Harms: NR | ++
Banks 1994a99 Trial Poor N=40/28 Community dwelling patients | II, III | 72 years (40–100) Female: 48% General | 6 weeks | A: Polyurethane membrane (Spyrosorb) B: Hydrocolloid (Granuflex) | No difference in complete wound healing A: 60% B: 50% (p-value NR) Harms (all in B): Overgranulation (10%), discomfort (10%), wound deterioration (10%) | ~
Banks 1994b100 Trial Poor N=29/29 Hospital | II, III | Median 74 (40–95) years Female: 60% Elderly | 6 weeks | A: Semi-permeable polyurethane B: Hydrocolloid | Complete wound healing: A: 77% B: 70% (p-value NR) Harms: NR | ~
Brod 1990^101^ Trial Poor N= 43/38 Nursing facility | II, III | Median 86/82 years (NR) Female: NR Elderly | 16 weeks | A: Poly-hema B: Hydrocolloid (DuoDerm) | Complete wound healing: A: 52% B: 62% (p=0.54) Wound healing time: (median) A: 32 days B: 42 days (p=0.54) Harms: NR | ~
Honde 1994^97^ Trial Fair N=168/129 Hospitals | III, IV | 82 years (63–101) Female: 72% Elderly | 8 weeks | A: Amino acid copolymer membrane (Inerpan) B: Hydrocolloid (Comfeel) | Complete wound healing A: 39% B: 26% (p=0.89) Median healing time (range) A: 32 (13–59) days B: 38 11–63) days (p=0.044) Harms: NR | +
Seeley 1999^98^ Trial Fair N=40/39 Outpatient wound clinic | II, III | 76 years (NR) Female: 54% General, diabetic and wound clinic patients | 8 weeks | A: Hydrocellular dressing B: Hydrocolloid dressing | Complete wound healing: A: 40% B: 40% Wound area reduction: A: 50% B: 52% (p=0.31) Harms (Wound deterioration): A: 1% B: 0.5% (infection, rash or maceration): A: 0.5% B: 1% | ~
Thomas 1997^103^ Trial Poor N=99^b^ Community | II, III (Stirling ) | 77 years (overall), 79 years (pressure ulcers); ranges NR Female: 70% (overall), 69% (pressure ulcers) | 15 days | A: Hydropolymer dressing B: Hydrocolloid dressing | Complete wound healing: A: 33% B: 20% Improved, not healed: B: 47% B: 58% Harms (adverse events including bleeding, excess granulation, and wound dehydration): A: n=10 B: n=7 (p-values NR) | ~
Hydro-Colloid vs. Alginate
Belmin 2002^105^ Trial Fair N=110/77 Hospitals | III, IV | 84 years (NR) Female: 71% Population: Elderly | 8 weeks | A: Calcium alginate (UrgoSorb) × 4 weeks then hydrocolloid (Algoplaque) × 4 weeks B: Hydrocolloid (DuoDerm) × 8 weeks | Complete wound healing: A: 5% B:15% (p=0.162) Wound surface area reduction A: 69% B: 43% (p<0.0001) Harms (excessive granulation): A: 11% B: 9% | + (alginate then HC superior to HC alone)

NA = not applicable; NPUAP = National Pressure Ulcer Advisory Panel; NR = not reported; NS = not significant

a Pressure ulcer stage indicates NPUAP staging unless otherwise noted. Non-NPUAP staging was converted to the equivalent NPUAP stage where possible.

b Pressure ulcers only. Including venous ulcers, n=99.

++Complete wound healing.

+Some improvement in wound healing.

~No difference.

Table 13 Local wound applications: Comparisons of different wound dressings – within-category comparisons

Author Year Study Type Quality Number Enrolled/Completed Setting | Pressure Ulcer Stage^a^ | Mean Age (Range) Sex Population | Followup | Wound Applications Compared | Outcome Measures and Treatment Effect | Benefit: Wound Improvement
Alginate vs. Alginate
Meaume 2005^106^ Trial Fair N= 28/28 b Multicenter (Hospitals) | III, IV | 77 years (NR) Female: 59% vs. 69% Population: general | 4 weeks | A: Silver release hydroalginate dressing (Silvercel) B: Calcium alginate dressing (Algosteril) | Wound area reduction: A: 32% B:14% (p-value NR separately for pressure ulcers) Healing rate (cm2/day): A: 0.26 B: 0.03 (p-value NR separately for pressure ulcers) Harms: NR separately for pressure ulcers | + (silver alginate superior)
Hydrogel vs. Hydrogel
Bale 1998^104^ Trial Poor N=50/42 Hospital and community settings | II–IV | 78 years (20–99) Female: 62% Population: general | 4 weeks | A: Amorphous hydrogel (Sterigel) B: Amorphous hydrogel (Intrasite) | No differences between groups in improvement in wound pain (p=0.55) Harms: Maceration in 38% (group A) vs. 53% (group B) (p-value NR) | ~

NPUAP = National Pressure Ulcer Advisory Panel; NR = not reported; NS = not significant

a Pressure ulcer stage indicates NPUAP staging unless otherwise noted. Non-NPUAP staging was converted to the equivalent NPUAP stage where possible.

b Pressure ulcers only. Including venous ulcers, n=199.

++Complete wound healing.

+Some improvement in wound healing.

~No difference.

Table 14 Local wound applications: Comparisons of different wound dressings – foam compared with silicone

Author Year Study Type Quality Number Enrolled/Completed Setting | Pressure Ulcer Stage^a^ | Mean Age (Range) Sex Population | Followup | Wound Applications Compared | Outcome Measures and Treatment Effect | Benefit: Wound Improvement
Meaume 2003^107^ Trial Fair N=38/38 Nursing facility | II | 83 years (66–92) years Female: 84% Elderly | 8 weeks | A: Hydropolymer foam dressing B: Silicone dressing | Complete wound healing A: 50% B: 44% (p-value NR) Harms (adverse events): A:15% B: 6% More tissue damage, maceration, leakage in A | ~
Viamontes 2003^108^ Observational Poor N=1891/1891 Nursing facility | NR | 83 years (29–106) Female: NR General | Mean 71 days | A: Hydrocellular foam dressing B: Silicone dressing | Complete wound healing: A: 53% B: 50% (NS; p-value NR) Infection: A: 3% B: 9% (NS) Harms – skin stripping: A: < 1% B: 2% | ~

NA = not applicable; NPUAP = National Pressure Ulcer Advisory Panel; NR = not reported; NS = not significant

a Pressure ulcer stage indicates NPUAP staging unless otherwise stated. Non-NPUAP staging was converted to the equivalent NPUAP stage where possible.

++Complete wound healing.

+Some improvement in wound healing.

~No difference.

Table 15 Local wound applications: Comparisons of different wound dressings – radiant heat

Author Year Study Type Quality Number Enrolled/Completed Setting | Pressure Ulcer Stage^a^ | Mean Age (Range) Sex Population | Followup | Wound Applications Compared | Outcome Measures and Treatment Effect | Benefit: Wound Improvement
Kloth 2002^111^ Trial Fair N= 53/40 Hospital and 7 nursing facilities | III and IV | 78 years (NR) Female: 63% General | 4 weeks | A: Semi-occlusive heated dressing B: Standard care | Complete wound healing: A: 48% B: 36% (p-value NR) Reduction in mean surface area: A: 69% B: 50% (p=0.11) Healing rate: A: 0.52 cm^2^ per week B: 0.23 cm^2^ per week (p<0.02) Harms: NR | +
Price 2000^110^ Trial Good N=58/50 Multiple (hospital, nursing facility, community) | (Bergstrom stage 3, 4) | 73 years (NR) Female: 64% General | 6 weeks | A: Radiant heat dressing B: Standard care | Complete wound healing: A: 12% B: 8% (NS; p-value NR) Wound surface area reduction: (% of initial area) A: 75% B: 40% (p=0.078) Time to reduce wound size to 25% of original area: A: 33 days B: 38 days (p=0.058). No difference between groups in pain scores at weeks 1 or 6. Harms: No evidence that heat therapy was linked with deterioration in skin condition. | ~
Thomas 2005^109^ Trial Good N=41/39 Nursing facility | (III, IV; Lazarus 1994) | 76 years (NR) Female: 32% General | 12 weeks | A: Radiant heat dressing B: Hydrocolloid | Complete wound healing: A: 57% B: 44% (p=0.46) Harms: NR | ~
Whitney 2001^112^ Trial Fair N=40/29 Multiple: (acute care, community, and nursing facility) | III, IV | 58 years (NR) Female: 38 % Mixed (Diabetes, SCI) | 8 weeks | A: Noncontact normothermic wound therapy (heated dressing) B: Standard care | Complete wound healing: A: 53% B: 43% (p-value NR) Linear rate of healing (mean): A: 0.012 cm^2^ per day B: 0.004 cm^2^ per day (p=0.01) | +

NPUAP = National Pressure Ulcer Advisory Panel; NR = not reported; NS = not significant

a Pressure ulcer stage indicates NPUAP staging unless otherwise noted. Non-NPUAP staging was converted to the equivalent NPUAP stage where possible.

++Complete wound healing.

+Some improvement in wound healing.

~No difference.

Table 16 Local wound applications: Comparisons of different wound dressings – other comparisons

Author Year Study Type Quality Number Enrolled/Completed Setting | Pressure Ulcer Stage^a^ | Mean Age (Range) Sex Population | Followup | Wound Applications Compared | Outcome Measures and Treatment Effect | Benefit: Wound Improvement
Bito 2012^113^ Trial Good N=66/64 Hospitals | II–III | 81 years (NR) Female: 52% General, 50 years or older | 8 weeks | A: Wrap therapy (food wrap or polyethylene sheets) B: Usual care (hydrocolloid, hydrogel, foam dressings) | Complete wound healing: A: 52% B: 46% (p-value NR) Time to healing: A: 60 days B: 58 days (no statistical difference) Harms: Skin complications in both groups. 17% with wrap therapy, incidence NR with usual care. | ~
Kerihuel 2010^114^ Trial Good N=60/39 Hospitals (inpatients and outpatients) | III (Yarkony IIc, IV) | 81 years (NR) Female: 76% General | 4 weeks | A: Charcoal (Actisorb) B: Hydrocolloid (DuoDerm) | Wound area reduction: A: 27% B: 19% (NS, p-value NR) Harms: A: 7% (infection, pruritus) B: 16% (maceration/exudation, infection, wound aggravation, overgranulation, eczema) | ~
Small 2002^115^ Trial Fair N=58/41 Community | (Stirling scale, Waterlow 1996 - II, III, IV) | Median 77 years (19–97) Female: 60% Population: NR | 6 weeks | A: Advanced wound care: Hydrogel dressing Foam dressing Transparent film dressing B: Standard care | Complete wound healing (all stage II ulcers): A: 54% B: 30% (p-value NR) Harms: None | ~
Yapucu Gunes 2007^116^ Trial Fair N=36/26 Hospital | II or III | 66 years (NR) Female: 35% General | 5 weeks | A: Honey dressing B: Exthoxy-diamino-acridine + nitrofurazone dressing | Complete wound healing: A: 20% B: 0% (p< 0.05 ) Mean decrease in ulcer size: A: 56% B:13% (p< 0.001 ) Harms NR | ++

NPUAP = National Pressure Ulcer Advisory Panel; NR = not reported; NS = not significant

a Pressure ulcer stage indicates NPUAP staging unless otherwise noted. Non-NPUAP staging was converted to the equivalent NPUAP stage where possible.

++Complete wound healing.

+Some improvement in wound healing.

~No difference.

###### Hydrocolloid Compared With Hydrocolloid

One fair-quality trial92 found more favorable reductions in wound area (32 percent vs. 17 percent) and pain with a triangular compared with oval hydrocolloid dressing in patients with stage II and III sacral ulcers.

###### Hydrocolloid Compared With Hydrogel

Three poor-quality trials compared hydrocolloid to hydrogel dressings and provided insufficient evidence to draw conclusions. One poor-quality trial93 reported better complete wound healing (43 percent vs. 24 percent) over 2 months, with hydrogel compared with hydrocolloid dressings in stage I and II ulcers. Two other poor-quality trials79,94 found no significant differences in outcomes comparing hydrocolloid and hydrogel dressings in stage II and III ulcers over 8 weeks.

###### Hydrocolloid Compared With Transparent Film

Only one trial, of fair quality,95 compared hydrocolloid and transparent film dressings and found no significant difference in complete wound healing (60 percent in both groups over 8 weeks) among patients with stage II and III ulcers.

###### Hydrocolloid Compared With Foam

Three fair-quality96–98 and five poor-quality99–103 trials compared hydrocolloid dressings with a variety of different polymeric or hydrocellular foam dressings. Overall the evidence suggested similar complete wound healing with these two dressing types. One fair-quality study reported similar healing outcomes at 8 weeks, but slightly faster time to healing (32 vs. 38 days) with an amino acid copolymer dressing compared with hydrocolloid in patients with stage III and IV ulcers.97 One poor-quality study reported better complete healing rates (59 percent vs. 27 percent) with a hydrocellular foam dressing compared with hydrocolloid.102 All other studies reported similar healing outcomes for both dressing types.

We conducted a meta-analysis of the eight studies comparing hydrocolloid with foam dressings. Complete wound healing was similar with foam compared with hydrocolloid dressings (pooled RR 1.12, 95% CI, 0.88 to 1.41, I2=16.4%, p=0.301) (Figure 5). An analysis excluding the four poor-quality trials produced similar results (pooled RR 1.25, 95% CI, 0.94 to 1.65, I2=0.0%, p=0.675).84,97–102,104

Figure 5 Hydrocolloid dressings compared with foam dressings: Pooled results

Figure 5 is a forest plot (i.e., a graph that depicts a meta-analysis plot) showing the individual and pooled relative risks and 95% confidence intervals (random effects model) from 7 trials for the comparison of pressure ulcer treatment with hydrocolloid dressings versus foam dressings. In the center of the graph is a solid vertical line corresponding to no effect. The individual studies are depicted at varying distances along this line as horizontal lines with a solid square in the middle. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The pooled effect is represented by a diamond at the bottom of the graph. Based on trials that evaluated hydrocolloid versus foam dressing, complete wound healing was similar with foam compared with hydrocolloid dressings. Relative risk estimates ranged from 0.61 (95% confidence interval 0.31 to 1.21) to 2.21 (95% confidence interval 0.87 to 5.58). The pooled relative risk was 1.12, with a 95% confidence interval of 0.88 to 1.41. Heterogeneity was minimal, I-squared = 16.4%, p = 0.301.

###### Hydrocolloid Compared With Alginate

A single fair-quality trial105 compared a strategy of using a calcium alginate dressing for 4 weeks followed by a hydrocolloid dressing for 4 weeks with using the hydrocolloid dressing for all 8 weeks. Complete wound healing was similar across groups but wound area reduction was greater with the alginate/hydrocolloid strategy (69 percent vs. 43 percent). See Table 12.

###### Alginate Compared With Alginate

A single fair-quality trial comparing a silver hydroalginate to a calcium alginate dressing found more wound area reduction (32 percent vs. 14 percent) over 4 weeks and faster wound closure rates with the silver-based dressing (0.26 vs. 0.03 cm^2^ per day), though the study included multiple wound types and the significance of differences for pressure ulcers alone was not reported.106 Infection rates were similar with the two dressings (see Table 13).

###### Hydrogel Compared With Hydrogel

A single poor-quality trial comparing two types of amorphous hydrogel found no differences in the outcome of wound pain104 (see Table 13).

Foam compared with silicone. One fair-quality trial107 and one poor-quality cohort study108 compared a polymer or hydrocellular foam with a silicone dressing (see Table 14). Complete wound healing was similar for foam and silicone dressings in both studies.

###### Radiant Heat Compared With Other Dressings

Two good-quality trials109,110 and two fair-quality trials111,112 of patients with stage III or IV ulcers compared a radiant heat dressing to hydrocolloid dressings,109 alginate dressings,110 or “standard care,”111,112 which included a variety of other dressings, including gauze, alginates, foam, hydrocolloids, and hydrogels (see Table 15). Overall, these studies indicated that radiant heat dressings accelerate the rate of healing compared with other types of dressings. One good-quality and two fair-quality studies measured rates of wound closure and overall found faster healing rates with radiant heat over periods of 4 to 8 weeks. A meta-analysis of the three trials reporting complete wound healing results indicated similar outcomes with radiant heat compared with other dressings (pooled RR 1.32, 95% CI, 0.88 to 1.98, I^2^ = 0.0% p=0.985) (Figure 6).

Figure 6 Radiant heat compared with other dressings: Pooled results

Figure 6 is a forest plot (i.e., a graph that depicts a meta-analysis plot) showing the individual and pooled relative risks and 95% confidence intervals (random effects model) from 4 trials for the comparison of pressure ulcer treatment with hydrocolloid dressings versus heat therapy. In the center of the graph is a solid vertical line corresponding to no effect. The individual studies are depicted at varying distances along this line as horizontal lines with a solid square in the middle. The size of the square varies in relation to the size of the study and the weight of the individual study in the overall analysis. The pooled effect is represented by a diamond at the bottom of the graph. Based on the trials that evaluated hydrocolloid dressings versus heat therapy, results indicated similar outcomes with radiant heat compared to other dressings. pooled RR 1.32, 95% CI, 0.88 to 1.98, I2=0.0% p=0.985).

###### Other Comparisons

Several studies evaluated dressings that did not fall into the general dressing categories listed above. A good-quality trial113 compared wrap therapy – dressing stage II–III ulcers with food wrap or polyethylene sheets – to usual care, which typically involved the use of hydrocolloid, hydrogel, or foam dressings. Complete wound healing and time to healing were similar in both groups. Another good-quality trial114 compared an activated charcoal dressing with a hydrocolloid dressing and found no significant difference in healing outcomes among patients with stage III ulcers. A fair-quality trial115 compared “advanced” wound dressings, including hydrogel, foam, or transparent film, with “standard” dressings, including gauze, alginates, or hydrocolloids. Specific dressings were chosen based on ulcer characteristics. In 58 community-dwelling patients, complete healing was 54 percent in the advanced dressing group and 30 percent in the standard group, though this difference was not significant. A fair-quality trial116 compared a honey dressing with a bactericidal dressing and found significantly more complete healing (20 percent vs. 0 percent) and better PUSH scores with the honey dressing over a 5-week period (see Table 16).

###### Topical Therapies

Comparisons of topical therapies are described below and in Tables 17–23.

Table 17 Local wound applications: Topical therapies – enzymes

Author Year Study Type Quality Number Enrolled/Completed Setting | Pressure Ulcer Stage^a^ | Mean Age (range) Sex Population | Followup | Wound Applications Compared | Outcomes Measured and Treatment Effect | Benefit: Wound Improvement
Agren 1985^122^ Trial Poor N=28/28 Multiple (Hospitals/outpatient) | III | Median 84 years (46–92) Female: 71% Elderly | 8 weeks | A: Streptokinase/streptodornase B: Zinc oxide | Complete wound healing: NR Disappearance of necrotic tissue: A: 43% B: 50% (p-value NR) Wound area reduction (median): A:18.7% B: 2.4% (p-value NR) Harms: Streptokinase/streptodornase treatment discontinued in 3 patients due to toxic skin reaction, necrosis, or infection | ~
Alvarez 2000^120^ Trial Fair N=22/21 Nursing facility | Partial thickness-II: 1 vs. 2 Full thickness-III–IV | Median 82 years (53–90) Female: 57% Elderly | 4 weeks | A: Collagenase debriding ointment B: Papain urea debriding ointment | Overall wound response (0=wound deteriorated, 1=no change, 2=minimal change, 3=average improvement, 4=significant improvement, 5=necrotic tissue resolved) A: 1.1 B: 4.5 (p<0.01) Healing time (mean time to 50% granulation): A: 28 days B: 6.8 days (p-value NR) Reduction in wound area from baseline: A: 33.9% B: 55.4% (NS; p-value NR) Harms (bacterial count at 4 weeks): A: log 5.0 CFU/mL B: log 4.6 CFU/mL (NS, p>0.05) | + (papain superior)
Burgos 2000^117^ Trial Good N=43/37 Hospitals | III | 80 years (55–96) Female: 54% Over 55 | 12 weeks | A: Collagenase ointment B: Hydrocolloid | Complete wound healing: A: 17% B: 16% (p=0.45) Wound area reduction: A: 44% B: 28% (p=0.37) Pain improved more with A (p=0.001) No significant difference in bacterial colonization or total cost. Harms: A: 6% (dermatitis) B: 5% (erythema) | ~
Muller 2001^121^ Trial Poor N=24/23 Hospital | (Grade IV, method NR) | 73 years (65–79) Female: 100% Post-hip surgery | 16 weeks | A: Collagenase ointment B: Hydrocolloid (DuoDerm) | Complete wound healing: A: 92% B: 64% (p<0.005) Mean time to wound healing with collagenase: A: 10 weeks B: 14 weeks (p<0.005) Harms: NR | ++
Pullen 2002^119^ Trial Fair N=135/78 Hospital | I, II, IV | 79 years (NR) Female: 48% Elderly | 4 weeks | A: Collagenase B: Fibrinolysin and deoxyribonuclease (DNAse) | Wound debridement (decrease in necrotic wound area): A: 46.7% B: 36.1% (p=0.11) Harms: no adverse events evaluated as related to study medication | ~

NPUAP = National Pressure Ulcer Advisory Panel; NR = not reported; NS = not significant

a Pressure ulcer stage indicates NPUAP staging unless otherwise noted. Non-NPUAP staging was converted to the equivalent NPUAP stage where possible.

++Complete wound healing.

+Some improvement in wound healing.

~No difference.

Table 18 Local wound applications: Topical therapies – phenytoin

Author Year Study Type Quality Number Enrolled/Completed Setting | Pressure Ulcer Stage^a^ | Mean Age (Range) Sex Population | Followup | Wound Applications Compared | Outcomes Measured and Treatment Effect | Benefit: Wound Improvement
Hollisaz 2004^72^ Trial Good N=83/83 Nursing facility or home | I, II | 37 years (NR) Female: 0% Spinal cord injury | 8 weeks | A: Hydrocolloid B: Phenytoin cream C: Saline gauze | Complete wound healing: A: 74% B: 40% C: 27% (p<0.01) A > B and C for stage I and gluteal A > C for stage II and ischial No difference for sacral Harms: NR | –
Rhodes, 2001^124^ Trial Poor N=47/39 Nursing facility | II | 78 years (60–101) Female: 8% Elderly | 8 weeks or complete wound healing | A: Topical Phenytoin B: Collagen Dressing (DuoDerm) C: Triple antibiotic ointment | Mean time to complete wound healing: Shorter for A compared with B or C (p=0.005) A: 35 days (p=0.011 vs. C; p=0.020 vs. B) B: 52 days C: 54 days Harms: None | +
Subbanna 2007^123^ Trial Good N=28/26 Hospital | II | 33 Years (10–55) Female: 12% Spinal cord injury | 15 days | A: Phenytoin solution B: Sterile gauze | Complete wound healing: NR Reduction in ulcer size: A: 47.8% B: 36.0% (p=0.13) Harms: None | ~

NPUAP = National Pressure Ulcer Advisory Panel; NR = not reported

a Pressure ulcer stage indicates NPUAP staging unless otherwise noted. Non-NPUAP staging was converted to the equivalent NPUAP stage where possible.

++Complete wound healing.

+Some improvement in wound healing.

~No difference.

Table 19 Local wound applications: Topical therapies – dextranomer

Author Year Study Type Quality Number Enrolled/Completed Setting | Pressure Ulcer Stage^a^ | Mean Age (Range) Sex Population | Followup | Wound Applications Compared | Outcomes Measured and Treatment Effect | Benefit: Wound Improvement
Colin 1996^126^ Trial Poor N=135/135 Six centers | All stages | 79 years (25–98) Female: 54% General | 3 weeks | A: Hydrogel (IntraSite) B: Dextranomer paste (Debrisan) | Median reduction in wound area: A: 35% B: 7% (p=0.03) Harms: 1 report of pain in B | +
Sayag 1996^125^ Trial Good N=92/60 Nursing facility and dermatology centers | III, V | 81 years (60–96) Female: 74% Elderly, limited mobility | 8 weeks | A: Calcium alginate B: Dextranomer | Complete wound healing: NR >75% reduction in wound area: A: 32% B:13% (p-value NR) Minimum 40% reduction in wound area: A: 74% B: 42% (p=0.002) Mean wound surface area reduction: A: 2.39 cm^2^ B: 0.27 cm^2^ (p<0.0001) Harms: Local adverse events A: 8% B: 33% | –

NPUAP = National Pressure Ulcer Advisory Panel; NR = not reported

++Complete wound healing.

+Some improvement in wound healing.

~No difference.

Table 20 Local wound applications: Topical therapies – collagen

Author Year Study Type Quality Number Enrolled/Completed Setting | Pressure Ulcer Stage^a^ | Mean Age (range) Sex Population | Followup | Wound Applications Compared | Outcomes Measured and Treatment Effect | Benefit: Wound Improvement
Graumlich 2003^127^ Trial Good N=65/54 Nursing facility | II, III | 81 years (NR) Female: 63% Elderly | 8 weeks | A: Topical collagen B: Hydrocolloid | Complete wound healing: A: 51% B: 50% (p=0.89) Mean area healed per day: A: 6 mm^2^ B: 6 mm^2^ (p=0.94) Harms: None | ~
Nisi 2005^129^ Trial Poor N=80/80 Hospital, plastic surgery unit | II, III, IV | 45 years (35–86) Female: 34% General | 2–8 weeks | A: Protease modulating matrix (collagen + cellulose: Promogran) B: Daily iodine and saline wash, petrolatum-soaked gauze | Complete wound healing: A: 90% B: 70% (p=0.59) Length of hospitalization A:360 days B:1164 days (p-value NR) Harms: None | ~
Zeron 2007^128^ Trial Poor N=24/24 Hospital | NR | 79 years (65–90) Female: 21% Elderly | 3 weeks | A: Collagen-polyvinylpyrrolidone (clg-pvp) B: Placebo | Mean reduction in ulcer size: A: 3.4 to 1.14 cm (58.5%) B: 2.9 to 1.58 cm (45.5%) (NS; p-value NR) Harms: NR | ~

NPUAP = National Pressure Ulcer Advisory Panel; NR = not reported; NS = not significant

a Pressure ulcer stage indicates NPUAP staging unless otherwise noted. Non-NPUAP staging was converted to the equivalent NPUAP stage where possible.

++Complete wound healing.

+Some improvement in wound healing.

~No difference.

Table 21 Local wound applications: Topical therapies – antimicrobials

Author Year Study Type Quality Number Enrolled/Completed Setting | Pressure Ulcer Stage^a^ | Mean Age (Range) Sex Population | Followup | Wound Applications Compared | Outcomes Measured and Treatment Effect | Benefit: Wound Improvement
Chuangsuwanich 2011^131^ Trial Fair N=40/40 Hospital | II or IV | 66 years (NR) Female: 58% Mixed (inpatients and outpatients) | 8 weeks | A: Silver mesh dressing B: Silver sulfadiazine cream | Complete wound healing: NR Wound surface area at 8 weeks: A: 7.96 cm^2^ B: 18.22 cm^2^ (p=0.09) Healing rate: A: 37% B: 25% (p=0.51) Harms: NR | ~
Gerding 1992^130^ Trial Poor N=74/74 Nursing facility | I or II (Shea) | Age: NR Female: NR Population: frail, elderly, chronically ill | 28 days or until wound resolution | A: Oxyquinoline-containing ointment (DermaMend) B: Vitamin A&D ointment | Complete wound healing: A: Stage I: 58.5% Stage II: 44.5% B: Stage I: 57.1% Stage II: 21.8%, (p<0.03 ) Healing time (days to resolution): A: Stage I: 6.2 Stage II: 7.8 B: Stage I: 7.3 Stage II: 13.0 (p<0.05) Harms: NR | ++

NPUAP = National Pressure Ulcer Advisory Panel; NR = not reported.

a Pressure ulcer stage indicates NPUAP staging unless otherwise noted. Non-NPUAP staging was converted to the equivalent NPUAP stage where possible.

++Complete wound healing.

+Some improvement in wound healing.

~No difference.

Table 22 Local wound applications: Topical therapies – maggot therapy

Author Year Study Type Quality Number Enrolled/Completed Setting | Pressure Ulcer Stage^a^ | Mean Age (Range) Sex Population | Followup | Wound Applications Compared | Outcomes Measured and Treatment Effect | Benefit: Wound Improvement
Sherman 1995^132^ Observational Poor N=8/8 Setting NR | II–IV | 58 years (44–68) Female: 0% Spinal cord injury | 3 to 4 weeks | A: Maggot therapy B: Usual care (premaggot therapy) | Wound surface area: A: 22% reduction B: 22% increase (p<0.001) Harms: No infection or discomfort with maggot therapy | +
Sherman 2002^133^ Observational Poor N=103/67 Hospital | III–IV | 64 years (26–91) Female: NR General | 2 to 19 weeks | A: Maggot therapy B: Usual care | Complete wound healing: A: 39% B: 21% (p=0.058) Wound surface area: A: 33% reduction B: 45% increase (p<0.05) Harms: Pain reported in 2 of 50 patients treated with maggots. | +
Wang 2010^134^ Observational Poor N=18/18 Hospital | NR | 48 years (32–55) Female: 33% spinal cord injury | 2 to 6 months | A: Maggot therapy B: Usual care | Time to complete wound healing: A: 19 days B: 31 days (p=0.04) Harms: NR | +

NPUAP = National Pressure Ulcer Advisory Panel; NR = not reported

a Pressure ulcer stage indicates NPUAP staging unless otherwise noted. Non-NPUAP staging was converted to the equivalent NPUAP stage where possible.

++Complete wound healing.

+Some improvement in wound healing.

~No difference.

Table 23 Local wound applications: Topical therapies – plant-derived and other nonpharmaceutical treatments

Author Year Study Type Quality Number Enrolled/Completed Setting | Pressure Ulcer Stage^a^ | Mean Age (Range) Sex Population | Followup | Wound Applications Compared | Outcomes Measured and Treatment Effect | Benefit: Wound Improvement
Felzani 2011^141^ Trial Poor N=59/50 Hospital | (EPUAP I–III) | 56 years (NR) Female: 58% Inpatients | 15 days | A: Lysine hyaluronate acid B: Sodium hyaluronate acid | Complete wound healing: Stage I (n=20) A: 90% B: 70% (p<0.05) Stage II (n=20) A: 70% B: 40% (p<0.02) Stage III (n=10; 14 ulcers) A: 71% B: 29% (p<0.01) Harms: NR | ++ (lysine superior)
Guthrie 1989^136^ Trial Fair N=128/105 Nursing facility | I–IV (Shea I–IV) | 78 years (NR) Female: 81% Population: general | 6 weeks | A: Dermagran spray B: Dermagran ointment C: Dermagran spray + ointment D: Placebo | Wound area reduction: A: 7% B: 26% C: 91% D: 5% (p<0.05) Harms: None | +
Hsu 2000^140^ Trial Poor N=32/32 Hospital | Grade 2 or higher (Shea) | 72 years (NR) Female: 59% Mixed, general, dementia, spinal cord injury | 3 weeks | A: Sheng-Ji-San formula and routine medical care B: Routine medical care | Complete wound healing: A: 1/24 (4%) B: 0/8 Change in wound surface area: A: −33.8% (p<0.005) B: +2.9% (NS; p-value NR) Harms: NR | ~
Kuflik 2001^137^ Trial Poor N=19/18 NR | I, II | Age: NR Female: NR Elderly, immobile | 6 weeks | A: Resurfix ointment B: Petrolatum ointment | Complete wound healing: A: 50% B: 22% (p-value NR) Harms: None | ~
LeVasseur 1991^138^ Trial Poor N=34/21 Hospital and nursing facility | I, II (Shea) | 82 years (NR) Female: 52% Elderly | 6 weeks | A: F14001 (active based cream) B: Placebo (nonactive based cream) | Complete wound healing: NR (unclear) Healing time A: 18 days B: 29 days (p=0.08) Significant reduction in ulcer size in both groups but no difference between groups. Harms: NR | ~
Narayanan 2005^143^ Observational Fair N=861/861 Nursing facility | I and II | 10% under 60 years; 10% 60–69 years; 22% 70–79 years; 36% 80–89 years; 21% 90 years or older Female: 67% General | 4 weeks | A: BCT ointment (hydrogenated castor oil and trypsin) B: BCT ointment + other C: Other (includes another topical wound dressing or prescriptive product) | Complete wound healing, adjusted (95% CI) A: 58.6% (45.8 to 71.4) B: 42.8% (35.0 to 50.7) C: 37.1% (33.2 to 41.0) (p<0.05 for A vs. B or C) Findings similar, but NS, when Stage I or II ulcers analyzed separately. Harms: NR | ++
Shamimi Nouri 2008^139^ Trial Poor N=18/18 Hospital | NR | 47 years (NR) Female: 22% Mixed, inpatients | 2 months | A: Topical semelil B: Conventional treatment | Wound area reduction: A: 78.3% B: 6.3% (p<0.001) Harms: None | +
Sipponen 2008^135^ Trial Poor N=37/22 Hospital | (Grade system NR: II–IV) | 77 years (58–98) Female: 59% General | 6 months | A: Resin Salve (Norway spruce) B: Hydrofiber bandage | Complete wound healing: A: 92% B: 44% (p=0.003) Harms: MRSA (1 patient in each group) | ++
Tytgat 1988^142^ Trial Poor N=16/16 NR | NR | 59 years (36–75) Female: 50% Multiple sclerosis | 3 weeks | A: Ketanserin 2% B: Placebo | Reduction in wound area: A: 81% B: 16% (“significant”, p-value NR) Harms: None | +

MRSA = methicillin-resistant Staphylococcus aureus; NPUAP = National Pressure Ulcer Advisory Panel; NR = not reported; NS = not significant

a Pressure ulcer stage indicates NPUAP staging unless otherwise noted. Non-NPUAP staging was converted to the equivalent NPUAP stage where possible.

++Complete wound healing.

+Some improvement in wound healing.

~No difference.

###### Enzymes

Five trials – one good-quality, two fair-quality, and two poor-quality – evaluated topical debriding enzymes and found that enzymes, particularly collagenase, are associated with improved wound improvement and possibly reduced pain. A good-quality trial117 compared collagenase ointment with a hydrocolloid dressing in patients with stage III ulcers and found no significant difference in ulcer healing, but improved pain in the collagenase group. In a fair-quality trial,118 the same investigators found similar healing outcomes for collagenase applied every 24 hours compared with every 48 hours, though pain outcomes were better with the every 24 hour application. Another fair-quality trial compared collagenase with fibrinolysin plus DNAase and found a nonsignificant difference favoring collagenase in necrotic wound area reduction (47 percent vs. 36 percent).119 A fair-quality trial120 found no significant differences in complete wound healing or wound area reduction when comparing topical collagenase with papain/urea, but necrotic tissue debridement was better with papain/urea. A poor-quality trial121 reported shorter healing times and more complete healing (92 percent vs. 64 percent) with collagenase compared with hydrocolloid after 16 weeks. A poor-quality trial122 found nonsignificant differences in wound area reduction when comparing Varidase (streptokinase and streptodornase) with zinc oxide (19 percent vs. 2 percent) over 8 weeks.

###### Phenytoin

Three studies (two good, one poor) comparing topical phenytoin to other local wound applications provided inconsistent evidence on the effectiveness of phenytoin. A good-quality trial72 found more complete healing of stage I and II ulcers after 8 weeks with hydrocolloid compared with phenytoin (74 percent vs. 40 percent); this effect was seen primarily in the stage I ulcers. Another good-quality trial123 reported nonsignificant differences in PUSH scores and wound volume reduction (48 percent vs. 36 percent) with phenytoin solution compared to saline gauze in stage II ulcers. One poor-quality trial124 found shorter time to complete wound healing for stage II ulcers with phenytoin compared with either a hydrocolloid dressing or topical antibiotic ointment (35 vs. 52 vs. 54 days).

###### Dextranomer

Two trials, one good and one poor quality, provided evidence that dextranomer paste may be inferior to other local wound applications. A good-quality trial125 comparing dextranomer paste to a calcium alginate dressing measured partial healing and wound area reduction after 8 weeks in patients with stage III and IV ulcers and found significantly faster wound surface area reduction with alginate. A poor-quality study126 found greater wound area reduction with a hydrogel dressing compared with dextranomer paste (35 percent vs. 7 percent) after 3 weeks.

###### Collagen

Evidence from three trials (one good, two poor) provided evidence that topical collagen is not superior to other local wound applications. A good-quality trial127 comparing topical collagen to a hydrocolloid dressing found similar complete wound healing for both treatments (51 percent vs. 50 percent) for stage II and III ulcers over 8 weeks. One poor-quality trial128 of 24 patients found no significant difference in wound area reduction over 3 weeks between topical collagen and placebo (59 percent vs. 46 percent). Another poor-quality trial comparing a collagen and cellulose matrix (Promogran) to petrolatum gauze showed no significant difference in complete wound healing between treatments (90 percent vs. 70 percent) over 8 weeks.129

###### Antimicrobials

Although topical antimicrobials are commonly used in pressure ulcer treatment, we found few studies in the post-1985 time frame comparing antimicrobials to placebos or other interventions. The three studies we identified evaluated different antimicrobial formulations and provided insufficient evidence to draw conclusions about effectiveness. One poor-quality trial124 found similar time to stage II ulcer healing with a triple antibiotic ointment compared with a hydrocolloid dressing (54 vs. 52 days), but inferior to topical phenytoin (35 days) (see Table 18). A poor-quality trial130 with stage I and II ulcers found more complete healing over 4 weeks with oxyquinoline ointment compared with A&D ointment, though this benefit was seen only with stage II ulcers (45 percent vs. 22 percent). A fair-quality trial131 found no significant differences in ulcer healing when comparing silver sulfadiazine cream to a silver mesh dressing (Table 21).

###### Maggot Therapy

Three poor-quality observational studies132–134 evaluating maggot therapy for the debridement and healing of pressure ulcers provide insufficient evidence regarding the effectiveness of this treatment due to poor study quality. All studies found benefits for maggot therapy, including greater wound area reduction132,133 and faster time to complete wound healing,134 when comparing healing in patients receiving maggot therapy either to healing during a period of usual care before maggot therapy was implemented, or to patients not receiving maggot therapy. None of the studies adequately accounted for selection bias or potential confounders.

###### Other

Several topical therapies were evaluated in single trials that provided insufficient evidence to draw conclusions about effectiveness. One poor-quality trial135 found more complete wound healing over 6 months in 22 patients treated with resin salve compared with a hydrocolloid dressing (92 percent vs. 44 percent). A fair-quality trial found greater wound area reduction with a combination of a zinc-based ointment and vitamin A-based spray (Dermagran) compared with either the ointment or spray alone, or to placebo (91 percent vs. 26 percent vs. 7 percent vs. 5 percent), in stage I–IV ulcers over 6 weeks.136 We identified several single-study evaluations of plant-derived and other nonpharmaceutical topical treatments,137–140 but all were small and poor quality. Similarly, evaluations of hyaluronate141 and ketanserin142 were limited to single, poor-quality trials, and evaluation of hydrogenated castor oil, and balsam peru castor oil trypsin (BCT) ointment143 was limited to a single, retrospective cohort study.

###### Biological Agents

Comparisons of different biological agents are described below and in Tables 24–26.

Table 24 Local wound applications: Biological agents – platelet-derived growth factor

Author Year Study Type Quality Number Enrolled/Completed Setting | Pressure Ulcer Stage^a^ | Mean Age (Range) Sex Population | Followup | Wound Applications Compared | Outcome Measures and Treatment Effects | Benefit: Wound Improvement
Mustoe 1994^147^ Trial Poor N=52/41 Nursing facility, hospitals | III, IV | 72 years (NR) Female: 66% Elderly | 28 days (5-month followup) | PDGF spray A: 100 mg/mL 1× daily B: 300 mg/mL 1× daily C: Placebo | Complete wound healing at 5 months: A: 38% B: 21% C:14% (NS; p-value NR) Wound volume reduction at 4 weeks: A: 71% B: 26%; C: 17% (p=0.056) Harms (1 event each): tunneling of ulcer, exuberant granulation tissue, erythema with purulent drainage in A; infection in B. | +
Rees 1999^144^ Trial Fair N=124/124 Multi-center | III, IV | 49 years (NR) Female: 16% General | 16 weeks | PDGF (Becaplermin gel) A:100 mg/g 1× daily + placebo 1× daily B: 300 mg/g 1× daily + placebo 1× daily C: 100 mg/g 2× daily D: Placebo 2× daily | Complete wound healing: A: (23%, B: (19%) C: (3%) D: (0%) (p=0.005 and 0.008 for A and B vs. placebo) 90% wound healing significant for A and B vs. placebo (p=.0021 and 0.014) Harms: Similar in all groups (worsening ulcer, infection, sepsis) | ++
Robson 1992a;146 Robson 1992b145 Trial Poor N=20/20 Hospital | III, IV | 33 (22–35) years Female: NR Spinal cord injury | 28 treatment days (29 day trial) | A: Platelet derived recombinant growth factor BB (rPDGF-BB) 1 μg/ml 1× daily B: rPDGF-BB10 μg/ml 1× daily, C: 100 μg/ml rPDGF-BB 1× daily D: Placebo | Complete wound healing: NR Ulcer depth reduction: C:14.1% of day 0 depth D:34.9% of day 0 depth (p<0.05) Wound volume reduction: C: (6.4% of day 0 volume) D: 21.8% of day 0 volume (p=0.16) Harms: None | +
Scevola 2010^148^ Trial Poor N=13/11 Hospital | III, IV | NR Female: 23% Spinal cord injury | 14 weeks | A: Allogeneic platelet gel 2× weekly for 8 weeks B: Usual care (iodine or alginate + zinc oxide or silver sulfadiazine) | No significant differences in ulcer volume reduction (p=0.76) or infection (p-value NR). Harms: None (HCV, HBV, HIV infection) observed | ~

HBV = hepatitis B virus; HCV = hepatitis C virus; NPUAP = National Pressure Ulcer Advisory Panel; NR = not reported; NS = not significant; PDGF = platelet-derived growth factor

a Pressure ulcer stage indicates NPUAP staging unless otherwise noted. Non-NPUAP staging was converted to the equivalent NPUAP stage where possible.

++Complete wound healing.

+Some improvement in wound healing.

~No difference.

Table 25 Local wound applications: Biological agents – other growth factors

Author Year Quality Study Type Number Enrolled/Completed Setting | Pressure Ulcer Stage^a^ | Mean Age (Range) Sex Population | Followup | Wound Applications Compared | Outcome Measures and Treatment Effects | Benefit: Wound Improvement
Hirshberg 2001^152^ Trial Poor N=14/8 Wound care clinic | III, IV | 44 years (NR) Female: 43% General | 16 weeks | TGF-beta gel A:1.0 μg/cm^2^ 1× daily B: 2.5 μg/cm^2^ 1× daily C: Placebo gel 1× daily | No significant differences in ulcer size, volume, or closure. Harms: NR | ~
Landi 2003^149^ Trial Good N=38/36 Nursing facility | II, III, IV | 80 years (73–93) years Female: 72% General | 6 weeks | A: Nerve growth factor (murine) 1× daily B: Placebo 1× daily | Complete wound healing: A: 44% B: 6% (p=0.009) Ulcer area reduction: A: 73% B: 48% (p=0.022) Harms: None | ++
Payne 2004^150^ Trial Good N=34/10 (34 analyzed) Multi-center | III | 69 years (NR) Female: 32% General | 24 weeks | A: Fibroblast-derived dermal replacement (Dermagraft) up to 2× weekly and conventional therapy B: Conventional therapy with no dermal replacement | Complete wound healing (week 24): A: 11% B: 13% (NS; p-value NR) Ulcer area reduction (week 12): A: 50% B: 34% (NS; p-value NR) Ulcer volume reduction (at study discontinuation) : A: 41% B: 17% (NS; p-value NR) Wound infections: A: 17% B: 19% (NS; p-value NR) Harms: Similar adverse event rates in A (42%) vs. B (58%). | ~
Robson 1992c151 Trial Poor N=50/49 Hospital | III, IV | 38 years (NR) Female 20% Spinal cord injury | 30 days | A: Recombinant basic fibroblast growth factor (bFGF) 1 μg/cm^2^ 1× daily B: bFGF 10 μg/cm^2^ 1× daily C: bFGF 5 μg/cm^2^ 1× daily D: Placebo 1× daily | Complete wound healing: NR > 70% decrease in wound volume: A,B,C: 60% D: 29% (p<0.05) No significant differences between different bFGF dosage groups. Harms: None | +
Robson 1994^155^ Trial Poor N=26/24 Hospital | III, IV | NR (18 and over) Female: NR Spinal cord pathology | 29 days | A: Interleukin 1b (IL-1b) 0.01 μg/cm^2^/day B: IL-1b 0.1 μg/cm^2^/day C: IL-1b 1.0 μg/cm^2^/day D: Placebo | Wound volume reduction: No significant differences across comparison groups. Harms: NR | ~
Robson 2000;^153^ Payne 2001^154^ Trial Poor N=61/61 Hospital | III, IV | 50 years (NR) Female: NR Spinal cord injury | 35 days (1 year followup) | A: GM-CSF 1× daily B: bFGF 1× daily C: GM-CSF 1× daily for 10 days, then bFGF 1× daily for 25 days D: Placebo 1× daily | Complete wound healing at 35 days: A: 67% B: 75% C: 68% D: 71% (p=0.69) Complete wound healing at 1 year: NS >85% healing at 35 days (p-value vs. placebo): Any cytokine therapy: p=0.03 A: p=0.22 B: p=0.02 C: p=0.10 Ulcer volume reduction: A: 63% B: 75% C: 68% D: 71% (NS) Harms: NR | ~

bFGF = basic fibroblast growth factor; GM-CSF = granulocyte-macrophage colony-stimulating factor; TGF- beta = transforming growth factor beta; NPUAP = National Pressure Ulcer Advisory Panel; NR = not reported; NS = not significant

a Pressure ulcer stage indicates NPUAP staging unless otherwise noted. Non-NPUAP staging was converted to the equivalent NPUAP stage where possible.

++Complete wound healing.

+Some improvement in wound healing.

~No difference.

Table 26 Local wound applications: Biological agents – macrophage suspensions

Author Year Quality Number Enrolled/Completed Setting | Pressure Ulcer Stage^a^ | Mean Age (Range) Sex Population | Followup | Wound Applications Compared | Outcome Measures and Treatment Effects | Benefit: Wound Improvement
Danon 1997^157^ Observational Poor N=199/199 Hospital | All stages | 80 years (NR) Female: 53% Elderly | 12 months | A: Macrophages (1× application) B: Usual care (variable dressings and topical applications) | Complete wound healing: A: 27% B: 6% (p<0.001) Harms: NR | ++
Zuloff-Shani 2010^156^ Observational Poor N=104/100 Hospital | III, IV (EPUAP | 78 years (NR) Female: 56% Elderly | 12 months | A: Activated macrophage suspension (AMS) as needed according to wound condition B: Standard of care | Complete wound healing (all patients): A: 70% B: 13% (p<0.001) Complete wound healing (leg ulcer subset): A: 70% B: 18% (p<0.001) No significant difference in healing time between treatments. Harms: None | ++

NPUAP = National Pressure Ulcer Advisory Panel; NR = not reported

a Pressure ulcer stage indicates NPUAP staging unless otherwise noted. Non-NPUAP staging was converted to the equivalent NPUAP stage where possible.

++Complete wound healing.

+Some improvement in wound healing.

~No difference.

###### Platelet-Derived Growth Factor

Four studies (one fair, three poor) compared platelet-derived growth factor (PDGF) or platelet gel compared with placebo and provided evidence of better wound improvement with PDGF for stage III and IV ulcers. One fair-quality trial144 comparing PDGF to placebo in stage III and IV ulcers found higher rates of complete wound healing over 16 weeks (23 percent vs. 0 percent). A poor-quality trial found greater wound depth reduction over 4 weeks (86 percent vs. 65 percent) with PDGF.145,146 One poor-quality trial147 found better ulcer volume reduction (71 percent vs. 17 percent), but no significant difference in complete wound healing (38 percent vs. 14 percent) with PDGF. Comparison of different doses indicated that 100 mcg/g per day produced similar or better results than higher or lower doses. A poor-quality trial of platelet gel for stage III and IV ulcers showed no significant difference in ulcer volume reduction over 14 weeks compared with usual care with alginate or topical antimicrobials.148

###### Other Growth Factors

Other growth factors were evaluated in single studies that provided insufficient evidence to draw conclusions about effectiveness. A good-quality trial found better complete wound healing in stage II, III, and IV ulcers with nerve growth factor compared with placebo (44 percent vs. 6 percent) over 14 weeks.149 A good-quality trial comparing a fibroblast-derived dermal replacement system (Dermagraft) to no dermal replacement found no significant difference in complete wound healing (11 percent vs. 13 percent), ulcer area or volume reduction, or wound infection in stage III ulcers over 24 weeks.150 A poor-quality trial of fibroblast growth factor did find better partial (> 70 percent) wound healing compared with placebo (60 percent vs. 29 percent) in stage III and IV ulcers over 1 month.151 Another poor-quality trial found no significant difference in complete wound healing (75 percent vs. 71 percent) or ulcer volume reduction with fibroblast growth factor compared with placebo. Studies of TGF-beta and GM-CSF were limited to single, poor-quality studies.152–154 A poor-quality trial comparing varying doses of interleukin 1b to placebo found no differences in wound volume reduction over 29 days.155

###### Macrophage Suspension

Two poor-quality cohort studies provided insufficient evidence to judge the effectiveness of macrophage suspensions in the treatment of pressure ulcers (see Table 26). One study comparing injected macrophage suspension to standard care (as prescribed by a wound care team) for stage III and IV ulcers found more complete wound healing in the macrophage-treated group (70 percent vs. 13 percent) with a median healing time of 87 days.156 The other poor-quality cohort study also found more complete wound healing (27 percent vs. 6 percent) with macrophage treatment compared with usual care over 12 months.157

##### Evidence About the Comparative Effectiveness of Local Wound Applications by Subgroup-Analysis (Key Question 1a, 1b, and 1c)

Few studies conducted subgroup analyses by ulcer characteristics. A fair-quality trial of transparent MVP dressings found that the benefit of those dressings over gauze in patients with stage III ulcers was seen only in the less severe ulcers within that stage.89 A good-quality study demonstrated better outcomes with hydrocolloid compared with gauze for gluteal and ischial, but not sacral ulcers.72 In that same study, hydrocolloid was superior to phenytoin in stage I but not stage II ulcers, and in gluteal but not other ulcers.72 Another fair-quality study found faster healing with phenytoin compared with hydrocolloid in stage II ulcers. A fair-quality study found that the benefit of radiant heat dressings compared with standard care, in terms of rate of healing, was more prominent with larger (> 5 cm^2^) wounds.111 Another fair-quality trial found that the benefit of radiant heat over other dressings was observed for both stage III and IV ulcers.158 A poor-quality study found that the benefit of oxyquinoline ointment over A&D ointment was seen in stage II but not stage I ulcers130

A poor-quality study comparing macrophage treatment to standard care found similar benefits for macrophage treatment in the entire study sample, those with diabetes, and those with ulcers of the leg compared with other locations.156

Indirect comparisons across studies to evaluate the possibility that treatment effectiveness is modified by ulcer, patient, or setting characteristics are limited by the fact that there were relatively few studies evaluating any given treatment comparison and by the fact that aside from ulcer stage and location, patient age and gender, and study setting, few variables were reported consistently across studies. In the 10 studies comparing hydrocolloid with gauze dressings, there was no clear pattern to suggest variation in findings by ulcer, patient, or setting characteristics. The same is true for other treatment comparisons, all of which had fewer studies.

##### Local Wound Applications: Harms (Key Question 2)

Harms of local wound applications for pressure ulcers were measured in 36 studies. Since most studies were small, the rates of harms reported in studies that did measure them and statistical comparisons of harms across treatment groups were not reported. Harms commonly measured and reported included skin irritation and inflammation, as well as tissue damage and maceration. Commonly measured, but infrequently occurring, harms included infection, pain, bleeding, tissue overgranulation, and wound deterioration.

###### Wound Dressings

###### Hydrocolloid

Harms were measured in 14 studies evaluating hydrocolloid dressings in samples ranging from 7 to 199 patients.73,75,79,92,93,98,99,103,105,114,117,127,159,160 Commonly reported harms included skin reactions (inflammation, erythema), maceration, pain, wound deterioration, and overgranulation, with rates of harms ranging from 0 to 16 percent. In a fair-quality study comparing a triangular with oval hydrocolloid dressing in 96 patients, wound deterioration and skin reactions were observed in 4 percent with the triangular dressing and 31 percent with the oval dressing over 10 days.92

###### Hydrogel

Harms measured in five studies of hydrogel dressings in samples ranging from 10 to 135 patients79,84,85,93,126 occurred in 0 to 12 percent of patients and included skin irritation and wound deterioration.

###### Foam

Harms of foam dressings measured in four trials (five publications) with sample sizes ranging from 40 to 199 patients76,98,99,103,107 occurred in 1 to 30 percent and included bleeding, overgranulation, wound deterioration, maceration, and tissue damage. A large, poor-quality cohort study of 1,891 patients with 3,969 ulcers reported a 3 percent infection rate and less than 1 percent rate of skin stripping with foam dressings.108

###### Transparent Film

Harms were measured for transparent film dressings in two studies with sample sizes ranging from 72 to 77 patients.89,95 One study reported no harms95 while the other reported a 14 percent rate of wound deterioration.89

###### Alginate

Harms of alginate dressings measured in four studies with sample sizes ranging from 7 to 110 patients105,106,110,125,161 occurred in 0 to 11 percent of patients and included infection, overgranulation, skin irritation, maceration, bleeding, and wound deterioration.

###### Silicone

In a large poor-quality cohort study of 1,891 patients with 3,969 ulcers, infections were reported in 9 percent of patients and skin stripping occurred in 2 percent of patients managed with silicone dressings.108

###### Radiant Heat

One study including 50 patients reported on skin condition after use of radiant heat dressings.110 Inflammation occurred in 11 percent and maceration in 4 percent, though similar rates were observed with the use of alginate dressings in that study.

###### Comparative Harms

In most studies reporting harms of dressings, rates were qualitatively similar between treatment arms; most studies were small and did not report statistical testing of differences in harms. A poor-quality study comparing hydrocolloid with hydrogel in 90 patients reported wound deterioration in 10 percent and 1.5 percent respectively,93 although another poor-quality study reported similar rates of skin complications comparing hydrocolloid to hydrogel dressings (12 percent vs. 14 percent).79 A poor-quality study with 40 patients found no harms with hydrocolloid but six adverse outcomes among 20 patients (30 percent) with a polyurethane foam dressing.99 However, a fair-quality study with 40 patients found similar rates of harms (0.5 to 1 percent) comparing a hydrocolloid with a hydrocellular foam dressing.98 A fair-quality trial with 38 patients found more tissue damage and maceration with a polymeric foam dressing compared with a silicone dressing.107 However, a large cohort study with 1891 patients found no significant differences in infection or skin stripping with foam compared with silicone.108 A study of radiant heat compared with alginate dressings found no significant differences in skin complications.110

###### Topical Therapies

###### Enzymes

One good-quality, one fair-quality, and one poor-quality study evaluating collagenase with sample sizes ranging from 37 to 135 patients reported harms – primarily pain, skin inflammation and necrosis – in 0 to 6 percent of patients.117,120,162 Harms occurred at the same rate in a study comparing collagenase applied every 24 hours with every 48 hours.118 A single, fair-quality study evaluating fibrinolysin plus DNAase found no harms attributable to the treatment.119 A poor-quality study reported discontinuation of topical streptokinase/streptodornase in 3 of 14 patients due to skin reactions, necrosis, or infection.122

###### Phenytoin

One good-quality and one poor-quality study including a total of 71 patients reported no adverse effects from topical phenytoin.123,124

###### Dextranomer

In a good-quality trial with 92 patients,125 harms occurred in 22 percent of patients treated with dextranomer paste and included infection, bleeding, overgranulation, and skin irritation, though most adverse reactions were considered minor and did not necessitate stopping treatment.

###### Collagen

One good-quality and one poor-quality study with 145 patients reported no adverse events with topical collagen.127,129

###### Antimicrobials

A fair-quality trial with 45 patients124 found no adverse events associated with triple antibiotic ointment. A poor-quality series163 reported no adverse effects of silver sulfadiazine cream in 21 patients.

###### Biological Agents

###### Platelet-Derived Growth Factor

One fair-quality and one poor-quality study with 137 patients reported on harms (systemic or local infection, or worsening ulcer) of PDGF and platelet gel and found no significant differences compared with placebo.144,148

###### Other Growth Factors

No systemic or local harms were observed in a good-quality study of nerve growth factor with 37 patients.149 No significant differences were found in overall adverse events in a study of 34 patients comparing fibroblast-derived dermal replacement with usual care.150 Harms were not measured in studies of other growth factors.

###### Macrophage Suspension

A poor-quality cohort study of macrophage suspension including 100 patients reported no adverse events attributable to treatment.156

##### Evidence About the Harms Related to Local Wound Applications by Subgroups According to Pressure Ulcer Characteristics (Key Question 2a), Patient Characteristics (Key Question 2b), or Setting (Key Question 2c)

No studies reported subgroup analyses to evaluate harms by ulcer, patient, or setting characteristics. Indirect comparisons across studies to evaluate differential rates of harm by ulcer, patient, or setting characteristics were not possible due to the inconsistency of harm reporting and the infrequent occurrence of specific adverse events.

### Effectiveness of Surgery

Pressure ulcers that have progressed to advanced stages often become chronic and do not completely heal with conservative measures. Surgical debridement and vascularized soft-tissue reconstructions are commonly used when nonhealing is observed or the wound has progressed to an advanced stage despite appropriate conservative management. Frail and debilitated elders and patients with sensory and motor deficits are at greatest risk for developing such advanced grade pressure ulcers. Surgical intervention is generally conducted by plastic and reconstructive surgeons and range from local debridement of necrotic and nonviable tissue in the wound bed to direct closure, skin grafting, and closure with soft tissue flaps. The flap is a section of soft tissue that is placed over the open wound and may be harvested from skin (cutaneous), fascia (fasciocutaneous), or muscle (myocutaneous) from nonaffected parts of the body. Direct closure is rarely indicated due to high risk of failure from increased tension at the closure site.164 Skin grafting is generally used for shallow nonhealing ulcers that have a well-vascularized wound bed. This procedure is also rarely used due to high risk of failure from mechanical strain.164 Most commonly, soft tissue flaps are harvested and used to surgically close the wound. Ideally, the tissue chosen should have adequate blood supply for healing and adequate thickness to meet the need of the surgical site.164

#### Description of Studies

To determine the effectiveness of surgery in the treatment of pressure ulcers we included controlled trials, observational studies with at least two comparative groups, and intervention series if the population was large and the study was conducted at multiple sites. We found one poor-quality trial165 and one fair-quality retrospective intervention series that met our inclusion criteria.166 Given the paucity of evidence, we expanded our inclusion to retrospective series from a single site if the population was large and provided comparative data. We found an additional three fair-quality studies, one with two publications.167–170 The total number of included studies was five, including one trial and four observational studies.

Details extracted from intervention series studies are included in Table 27 and the trial details are included in the evidence tables (see Appendix H, Table H-7). The assessments of the quality rating criteria used for each study are provided in Appendix H, Table H-8.

Table 27 Surgery: Comparative effectiveness of intervention series

Author Year Study Type Quality N Patients/nPU Setting | Pressure Ulcer Stage^a^ | Mean Age (Range) Sex Population | Followup | Surgical Intervention | Outcomes Measured^a^ and Treatment Effect^a^
Foster 1997^170^ Observational Fair N=87;/nPU=112 Hospital | Stage III–IV ischial | 49 years (16–90) Female: 26% General (90% spinal cord injury) | 11 months (1 month to 9 years) | Myocutaneous flap Fasciocutaneous flap | Healed wound by 1-month post surgery: inferior gluteus maximus island flap 32/34 (94%) vs. inferior gluteal thigh flap 25/27 (93%) vs. V-Y hamstring 7/12 (58%) vs. tensor fascia latae 6/12 (50%) Harms (n): Complications in 37%: Slight wound edge dehiscence (16); partial flap necrosis (10); wound infection (5); wound dehiscence requiring reoperation (5); aspiration pneumonia (1); intraoperative myocardial infarction (1); deep venous thrombosis (1)
Foster 1997^169^ Observational Fair N=201/nPU=280 Hospital | Stage III–IV pelvic and trochanteric | 50 years (16–90) Female: 35% General (90% spinal cord injury) | 12 months (1 month to 9 years) | Myocutaneous flap Fasciocutaneous flap | Healed wound by 1-month post surgery) 248/280 (89%) Ischial: 94/113 (83%) Sacral: 86/94 (91%) Trochanter 68/73 (93%) Complications: Iscial: 47/113 (42%) Sacral: 19/94 (20%) Trochanter: 11/73 (15%)
Kierney1998^166^ Observational Fair N=158/nPU=268 Hospital | Stage III–IV pelvic and trochanteric | 35 years (NR) Female: 22% General (84% spinal cord injury/spina bifida) | 3.7 years (1 month to 15.5 years) | Primary closure split-thickness skin graft Cutaneous flap Limberg flap Fasciocutaneous flap Myocutaneous flap Other | Recurrence rates: Overall patient: 25% Overall pressure ulcer: 19% Sacral: 12% Ischial: 21%, Trochanter: 22% FLAPS: Cutaneous 12/44 (27%) Limberg 2/11 (18%) Fasciocutaneous 8/54 (15%) Myocutaneous 13/99 (13%) Spinal cord injured/spina bifida: 20–24% vs. others: 5% Harms: NR
Schryvers 2000^168^ Observational Fair N=168/nPU=598 Hospital | Stage III–IV (communicate with muscle, bone, or joint) pelvic and trochanteric | 41 years (16–91) Female: 22% Spinal cord injury | 1976–1996 (length of time from surgery to recurrence ranged from 2 months to 3 years) | Primary closure vs. fasciocutaneous vs. myocutaneous flap closure | Complete healing, days from surgery: primary closure: n=65, 67.3 days cutaneous/fasciocutaneous: n=237, 59.1 days myocutaneous: n=86, 82.2 days Recurrence rates: Ischial 84/249 (34%) Sacral 24/82 (29%) Trochanteric 16/90 (18%) Complications: (suture line dehiscence) in 31% overall Ischial: 30% Sacral: 30% Trochanteric: 35% Primary closure: 25/75 (34%) Cutaneous flap: 66/253 (26%) Myocutaneous flap: 39/93 (42%)
Yamamoto 1997^167^ Observational Fair N=53/nPU=69 Hospital | NR pelvic | 50 years (17–75) Female: 9% Paraplegic | 3 years 6 months (range 4 months to 5 years 4 months) | Fasciocutaneous vs. myocutaneous flap | Recurrence rates: Ischial: 22/45 (48.9%) fasciocutaneous 27.8% vs. myocutaneous 63% Sacral: 5/24 (20.8%) fasciocutaneous 17.4% vs. myocutaneous 1/1 (100%) Percent PUFS: at 36 months: overall: sacral 70% vs. ischial 50% (p=0.28) Ischial: fasciocutaneous 67.5% vs. myocutaneous 42.5%, p=0.055 No comparison of sacral sores by muscle flap group due to small sample size Harms: NR

NPUAP = National Pressure Ulcer Advisory Panel; NR = not reported; PUFS = pressure ulcer free survival

a Pressure ulcer stage indicates NPUAP staging unless otherwise noted. Non-NPUAP staging was converted to the equivalent NPUAP stage where possible.

The single trial was small (n=60), whereas on average the retrospective studies were of moderate size, ranging from 59 to 201 patients and accounting for 69 to 380 pressure ulcers. The retrospective studies ranged from 5 to 20 years of followup.

The populations in studies of surgical interventions for pressure ulcers included elderly nursing home patients and spinal cord injured or neurologically impaired younger adults (mean ages 34–50). All studies enrolled patients with advanced pressure ulcers, stage III or IV NPUAP equivalent.

The intervention for all patients was some form of surgical repair of the pressure ulcer, either through primary closure, or soft tissue flap (cutaneous, fasciocutaneous, or myocutaneous ). The one trial compared the use of CO_2_ laser with knife or electric knife for wound closure by local transposition of tissue or skin graft.165 One study only considered patients with ischial pressure ulcers.170 For other intervention series, different approaches were compared.

The outcomes for the trial were operative time, blood loss, infection rate, hospitalization days, and failure rate.165 The outcomes for intervention series were wound healing, recurrence rates.

The harms for intervention series studies included wound dehiscence, infection, reoperative rates, and other complications of the surgery.

The settings were hospitals or rehabilitation centers. The single trial was conducted in Argentina. The intervention series were from the United States, Canada, Australia, and Japan.

#### Key Points

- Evidence was inconclusive to determine if one approach to closure of stage III to IV pressure ulcers is superior to another due to quality of the studies and heterogeneity in patient populations and surgical procedures (strength of evidence: insufficient).
- Sacral pressure ulcers have lower recurrence rates after surgery than ischial pressure ulcers (strength of evidence: low).
- Spinal cord injured patients had higher rates of recurrent pressure ulcer after surgical flap closure than other patients with pressure ulcers (strength of evidence: low).
- Reoperation due to recurrence or flap failure ranged from 12 to 24 percent (strength of evidence: low).
- Wound dehiscence is more common if bone is removed at time of surgical procedure (strength of evidence: low).
- Complication rates after surgery are higher for ischial ulcers than for sacral or trochanteric ulcers (strength of evidence: low).

#### Detailed Analysis

##### Evidence About the Comparative Effectiveness of Surgery (Key Question 1)

Determining the effectiveness of surgical techniques for treatment of pressure ulcers was limited to poor-quality intervention series. One poor-quality trial and four fair-quality intervention series including a total of 620 patients accounting for 1,057 pressure ulcers provided evidence on the effectiveness of surgical techniques to treat stage III or IV pressure ulcers. Overall sacral pressure ulcers have lower recurrence rates than ischial pressure ulcers and spinal cord injured patients are at the greatest risk of recurrence. Evidence is inconclusive to determine optimal types of soft tissue flap or how this might vary depending on the anatomical site of the pressure ulcer.

We found only one, poor-quality randomized trial (n=60) comparing one surgical technique with another.165 CO_2_ laser was compared with knife or electric knife for wound closure by local transposition of tissue or skin graft.165 The study reported significant reduction in operative blood loss (2.1 +/− 0.1 cm^3^/cm^2^ vs. 2.6 +/− 0.1 cm^3^/cm^2^), operative time (39+/−5 minutes vs. 45 +/− 7 minutes), hospital days (68 percent fewer days), and infection rate (11/30, 37 percent vs. 14/30, 47 percent) with laser surgery. Although the study was poor quality, it suggested a laser knife may be superior to standard wound closure. Further studies would be needed to determine if this is accurate.

We found five retrospective series, all rated fair quality, evaluating long-term results of surgeries performed for patients with advanced (primarily stage III–IV) pressure ulcers (n=560, nPU=997).166–170 Two were conducted at multiple sites166,167 and two were conducted at single sites.168–170 The combined results provide low strength of evidence that sacral pressure ulcers have lower recurrence rates than ischial pressure ulcers and insufficient evidence to determine optimal surgical procedure.

The smallest retrospective series (n=53, nPU=69) conducted in Japan analyzed outcomes of paraplegic patients, mean age 50 years, treated with fasciocutaneous or myocutaneous flaps over an average followup period of 44 months.167 It was unclear if the study included all surgically treated patients with ischial or sacral pressure ulcers during the five years of chart review.167 There was a trend toward greater recurrence rate in ischial compared with sacral pressure ulcers (50 percent vs. 70 percent) and toward better 36-month pressure ulcer free survival rates with fasciocutaneous compared with myocutaneous flaps (68 percent vs. 43 percent), although the difference was not significant.

Two of the three larger retrospective studies reported on recurrence rate and found overall pressure ulcer recurrence rates of 19 percent166 and 33 percent.168 The publication by Kierney, et al. was a retrospective study of patients from two centers treated with surgical repair of stage III or IV pressure ulcers between October 1977 and December 1989. They reported on 158 patients with 268 pressure ulcers, mean age 35 years, with mean followup of 3.7 years. They found that cutaneous flaps had the highest recurrence (12/44, 27 percent), compared with fasciocutaneous (8/54, 15 percent) and myocutaneous flaps (13/99, 13 percent).166 Sacral sites had the least recurrence (8/69, 12 percent) with similar recurrence rates in ischial and trochanteric sites (32/15, 21 percent and 11/49, 22 percent respectively).166

Schryvers, et al. conducted a single center retrospective study of patients treated with surgical repair of stage III to IV pressure ulcers between 1976 and 1996, with mean followup of 5.3 years for patients with more than three ulcers and 9.3 years for patients with one ulcer.168 They reported 380 pressure ulcers in 148 patients, mean age 41 years (range: 16–91). The overall ulcer recurrence rate was 33 percent, greatest with ischial ulcers (84/249, 34 percent). Trochanteric ulcers were the slowest to heal (97–105.6 days). Time to complete healing was similar between the different surgical procedures (primary closure 52–97 days, fasciocutaneous flap 52–100 days, myocutaneous 44–105 days).

Foster, et al. evaluated fasciocutaneous and different types of myocutaneous flaps in 201 patients with 280 pressure ulcers, age 50 (range: 16–90), considered healing at 1 month to be flap success and reported overall flap success of 89 percent (248/280). In patients treated for ischial ulcers, they found that gluteal thigh (fasciocutaneous) and inferior gluteus maximus island (myocutaneous) flaps demonstrated the best healing at 93 and 94 percent while V-Y hamstring and tensor fascia latae flaps (both myocutaneous) had the least success at 58 and 50 percent respectively (Table 27).169,170

##### Evidence About the Comparative Effectiveness of Surgery by Subgroups According to Pressure Ulcer Characteristics (Key Question 1a)

Three retrospective studies considered site of ulcer as risk for recurrence and found that regardless of surgical repair technique, recurrence occurred more commonly in ischial pressure ulcers compared with sacral ulcers.166–168 There was conflicting evidence on trochanteric ulcers with one study finding a similar recurrence rate as ischial ulcers (22 percent vs. 21 percent)166 and one study finding a lower recurrence rate (18 percent vs. 34 percent).168 Two studies reported on post-surgical healing with one finding that trochanteric surgeries were the slowest to heal168 and one finding that healing at one month post-surgery was best for trochanteric ulcers (93 percent) compared with sacral or ischial ulcers (83 percent and 91 percent).169 One study evaluating ischial pressure ulcers considered size of the wound at surgery170 and found that smaller sized ulcers (average 59.6 cm^2^) were less likely to be fully healed at 1 month compared with larger sized ulcers (average 82.9 cm^2^). However, the authors were uncertain if this was related to sample size differences per group (21 vs. 91) or other risk factors for pressure ulcers. They noted that 71 percent of patients with small ulcers had more than one risk factor for pressure ulcers, but did not report this result for patients in the group with large ulcers.169,170

##### Evidence About the Comparative Effectiveness of Surgery by Subgroups According to Patient Characteristics (Key Question 1b)

Most studies enrolled neurologically compromised patients—primarily spinal cord injured through trauma, tumor, or congenitally— with the average age of 34 to 50 years. One study compared recurrence rates between patients with spinal cord impairment and other patients, and found no significant difference between paraplegia (38/160, 24 percent), quadriplegia (7/35, 20 percent), and spina bifida (3/13, 23 percent). However, spinal cord injured patients had a higher risk of recurrence compared with patients with multiple sclerosis (0/9, 0 percent) or other conditions causing immobility (3/51, 6 percent).166

##### Evidence About the Comparative Effectiveness of Surgery by Subgroups According to Settings (Key Question 1c)

One study (n=158, nPU=268) reported long-term data on pressure ulcer recurrence when surgical debridement and closure are supplemented with patient rehabilitation and education.166 The investigators provided a complete perioperative rehabilitation program that included nutrition, social work, physical therapy, wheelchair and mechanical device maintenance, and detailed skin care education. Pressure ulcer recurrence rates were lower than similar long-term studies (19 percent vs. 33 percent to 39 percent), however no study directly compared patients who received this treatment with those who did not.

##### Surgery: Harms (Key Question 2)

Three retrospective observational studies, one with two publications, reported on harms associated with surgical techniques for the treatment of pressure ulcers.168–171 One of the studies examined a subset of patients with ischial pressure ulcers also included in the larger study.169,170 Two of the studies reported overall complication rate ranging from 28 to 37 percent.168,169 The most common harm was wound dehiscence. One study (n=148, nPU=380) was a 20-year chart review of all patients treated at a single center with wound closure or flap procedure for advanced pressure ulcers.168 The mean followup ranged from 5.3 years for those with more than three admissions to 9.3 years of followup for those with one admission. The overall dehiscence rate was 31 percent. The type of procedure influenced the occurrence of wound dehiscence, with myocutaneous flaps causing the greatest incidence of dehiscence at each site (trochanter 17/43, 41 percent; sacral 5/7, 71 percent; ischial 17/43, 39 percent). Rates of dehiscence were higher when bone was excised due to osteomyelitis detected at surgery, most notably at the trochanteric (16/22, 73 percent) and sacral sites (8/14, 57 percent).168 One 16-year chart review at a single center (n=201, nPU=280) also reported on wound dehiscence but separated those with slight dehiscence in which the wound had complete healing within 1 month of surgery and those with significant dehiscence that affected the ability for the wound to heal.169 The review reported 10 percent slight dehiscence (27/280) and 3 percent significant dehiscence (9/280) but did not report analysis based on site or surgical procedure. A subset from this study of repairs to ischial pressure ulcers, the type most commonly associated with recurrence, were analyzed in a different report (n=87, nPU=112).169 In this smaller cohort there was 14 percent slight dehiscence (16/112) and 4 percent significant dehiscence (5/112).169 Partial flap necrosis was found in 10 patients (9 percent) who had myocutaneous flaps using tensor fascia latae, gracilis, or V-Y hamstring grafts.169 Need for reoperation from the other studies ranged from 12 to 16 percent but these other studies did not analyze based on surgical intervention.168,169 Other harms associated with primary closure or flap repair included osteomyelitis or infection (5 percent to 16 percent),168,169 donor site graft loss (2 percent),169 and one case each of intraoperative myocardial infarction, aspiration pneumonia, and deep vein thrombosis.169

In summary, there was moderate evidence that complications associated with primary closure or flap repair of advanced pelvic pressure ulcers are common, ranging from 28 to 37 percent, with wound dehiscence being the most common. Wound dehiscence may be more common if bone is removed at the time of surgery. Evidence was inconclusive to determine if one type of repair performs better or worse than another or how this is related to site of ulcer given the quality of the studies and the heterogeneity of the populations and surgical procedures. Reoperation due to recurrence or flap failure ranged from 12 to 24 percent.

##### Evidence About the Harms Related to Surgery by Subgroups According to Pressure Ulcer Characteristics (Key Question 2a), Patient Characteristics (Key Question 2b), or Setting (Key Question 2c)

All of the studies reporting on harms associated with surgical techniques for the treatment of pressure ulcers enrolled patients with advanced, stage III–IV, pressure ulcers with a scarcity of evidence on comparative features of the pressure ulcers. One study considered site of pressure ulcer and type of surgical procedure and found greater dehiscence at trochanteric sites (31/90, 35 percent) compared with sacral or ischial sites (25/82, 30 percent and 74/249, 30 percent respectively).168 The study also considered dehiscence if bone was excised at the time of surgery (indicative of osteomyelitis), and found that rates of dehiscence were higher, most notably at the trochanteric (16/22, 73 percent) and sacral sites (8/14, 57 percent).168 One study examining a subset of patients with ischial pressure ulcers found that the overall complication rate, as well as wound dehiscence and partial flap necrosis, were all greater than the overall population.169,170

No studies reported on differences in harms according to patient characteristics, patient care settings, or features of patient care settings.

### Effectiveness of Adjunctive Therapies

Adjunctive therapies refer to pressure ulcer interventions used in addition to standard wound care, where standard care includes pressure relief and local wound applications. The term adjunctive suggests that these are secondary treatments used to complement or enhance the effect of a primary therapeutic modality. Although many of the therapies described as adjunctive are used as standalone treatments, all are used in conjunction with standard wound care including dressings and standard pressure ulcer relief practices. We use the term adjunctive because it has become the standard label for this group of treatments among researchers and clinicians. Adjunctive therapies include electrical stimulation, electromagnetic therapy, light therapy, laser therapy, hydrotherapy, vibration, shock wave, and hyperbaric oxygen.

#### Description of Studies

We found six systematic reviews (SR) which were used only as background, 34 trials (three good-quality trials, 29 fair-quality trials, and two poor-quality trials), and five observational studies (two fair-quality and three poor-quality studies) evaluating adjunctive therapies that met our inclusion criteria. Poor-quality studies were considered only if there was a paucity of evidence from higher-quality studies and none met this requirement.172–175

Sample sizes in the trials ranged from 6 to 198 patients and study duration from 7 days to 16 weeks.

Details extracted from each study are included in the evidence tables (see Appendix H, Table H-9). The assessments of the quality rating criteria used for each study are provided in Appendix H, Table H-10.

The populations varied with many enrolling an elderly general population and others a younger neurologically compromised group. Sizes and stages of pressure ulcers varied across studies. (See Appendix C for NPUAP scale equivalents.)

Interventions included electrical stimulation (12 studies including one study with two publications, one SR), electromagnetic therapy (four studies, two SRs), therapeutic ultrasound (four studies, one SR), negative pressure wound therapy (five studies, two SRs), light therapy (six studies), laser therapy (three studies plus one direct study included in ultrasound), hydrotherapy (two studies), vibration (one study with two publications), shock wave therapy (one study), and hyperbaric oxygen (one study). Interventions varied in treatment dose, frequency, duration, and set up. All used standard wound care in conjunction with the adjunctive therapy.

The comparator was either sham treatment (placebo) or standard care.

The outcomes varied across studies, but most evaluated the percent change in wound surface area, complete wound healing, or time to healing as primary or secondary outcomes. Some studies used scales such as the Pressure Ulcer Scale for Healing (PUSH) and Pressure Sore Status Tool.176

Study settings included hospitals and rehabilitation centers, with fewer outpatient clinics and home health. The studies were conducted in the United States, Nigeria, India, Israel, Canada, Scandinavia, Serbia, Greece, Netherlands, and Switzerland.

Direct evidence comparing one intervention with another was limited. Our ability to derive indirect evidence from comparisons across studies was also limited due to variability in study population, design, outcomes measured, and sample size. Study data and the quality assessment of each study are presented in evidence tables (see Appendix H, Evidence Table H-10)

#### Key Points

##### Key Question 1

###### Electrical Stimulation

- Electrical stimulation was beneficial in accelerating the rate of healing of stage II, III, and IV pressure ulcers based on one good-quality and eight fair-quality randomized trials (strength of evidence: moderate).
- Evidence about the effect of electrical stimulation on complete wound healing was inconclusive due to heterogeneous findings across studies (strength of evidence: insufficient).

###### Electromagnetic Therapy

- Wound improvement of stage II, III, or IV pressure ulcers was similar with electromagnetic therapy compared to sham treatment based on four randomized trials. (strength of evidence: low).

###### Therapeutic Ultrasound

- Wound improvement was similar with ultrasound compared to standard care or sham treatment based on three randomized trials (strength of evidence: low).

###### Negative Pressure Wound Therapy

- Wound improvement was similar with negative pressure wound therapy compared to standard care over 4 to 6 weeks of therapy based on two randomized trials and one observational study (strength of evidence: low).

###### Light Therapy

- Light therapy was similar to sham light therapy in producing complete wound healing, based on two randomized trials (strength of evidence: low).
- Light therapy reduces wound surface area more than standard care or sham light therapy based on four randomized trials and one observational study (strength of evidence: low).

###### Laser Therapy

- Wound improvement was similar with laser therapy compared to sham treatment or standard care based on four randomized trials (strength of evidence: low).

###### Hydrotherapy

- Evidence on the effectiveness of hydrotherapy was insufficient based on two randomized trials evaluating different treatment modalities (one of whirlpool therapy and one of pulsatile lavage) (strength of evidence: insufficient)

##### Key Question 2

###### Harms of Adjunctive Therapies

- The most common adverse effect of electrical stimulation was local skin irritation (strength of evidence: low).
- There is a lack of studies evaluating harms of electromagnetic therapy, ultrasound, negative pressure wound therapy, and hydrotherapy.
- Light therapy caused no significant adverse events based on four randomized studies (strength of evidence: low).
- Short-term use of laser therapy caused no significant adverse events based on three randomized studies (strength of evidence: low).

###### Subgroups

- Frail elderly patients experience more adverse events with electrical stimulation compared with a younger population (strength of evidence: low).

#### Detailed Analysis

##### Evidence About the Comparative Effectiveness of Adjunctive Therapies (Key Question 1)

###### Electrical Stimulation

Electrical stimulation therapy is the delivery of direct electric current through the wound bed using surface electrodes. All equipment is designed to provide high-voltage pulsed currents with variable intensity (voltage) and frequency (pulses per second or Hz). The electrodes either surround the wound or one electrode is placed directly on the wound and a second placed at a distant site. Electrical stimulation is believed to promote cell growth and differentiation.

We found no direct evidence comparing electrical stimulation to other interventions for the treatment of pressure ulcers. Nine randomized trials, one good quality177 and eight fair quality,178–185 provided evidence regarding the effect of direct electrical stimulation compared with sham treatments. Overall, electrical stimulation increased the rate of healing in stage II, III, and IV pressure ulcers. However, the evidence was insufficient to determine its effect on complete wound healing, due to heterogeneity of findings across studies.

Sample sizes ranged from 7 to 80 patients, accounting for 16 to 192 pressure ulcers. Most were of a duration ranging from 20 days to 16 weeks. One 8-week study followed patients to day 147^179^ whereas the rest did not follow patients beyond the study duration. Each study enrolled patients with different sizes and stages of pressure ulcers. One study did not report ulcer stage181 and one reported ulcers as stage II or III but did not report the scale being used.185 Age and comorbid conditions varied from young paraplegics to frail elders. Interventions varied in treatment dose, frequency, duration, and set up but all used electrical stimulation sham as the comparator. Most studies evaluated the percent change in wound surface area as the primary outcome. A trend of greater reduction in wound surface area in the treatment group was seen across studies except for one study that found no significant difference.181 In the one study that followed patients for an additional 90 days after treatment, this trend was lost after day 45 and no significant differences were noted at the end of followup179 (Table 28).

Table 28 Adjunctive therapies: Electrical stimulation

Author Year Study Type Quality Number Enrolled/Completed Setting | Pressure Ulcer Stage^a^ | Mean Age (Range) Sex Population | Followup | Outcomes Measured and Treatment Effect | Benefit: Wound Improvement
Adegoke 2001^178^ Trial Fair N=7/6 Hospital | Stage IV | 44 years (22–60) Female: NR Spinal cord injury | 4 weeks | Wound surface area percent change: 22.2% vs. 2.6% (p-value not reported) Harms: NR | +
Adunsky 2005^179^ Trial Fair N=63/38 Hospital | Stage III | 71 years (NR) Female: 35% 86% elderly, 14% spinal cord injury | 8 weeks/day 147 | Complete healing day 147: 25.7% vs. 35.7%, (p=0.39) Mean time to complete closure: 67 vs. 102 days (p=0.16) Harms: excessive granulation (2). No serious adverse events related to treatment. | ~
Ahmad, 2008^180,188^ Trial Fair N=60 NR | Stage II | 39 years (NR) Female: 53% NR | 5 weeks | Wound surface area percent change: 91% vs. 25–28% (p<0.001) Harms: NR | +
Baker 1996^181^ Trial Fair N=80 nPU=192/185 Hospital and outpatient | NR | 36 years (19–76) Female: 18% Spinal cord injury | 4 weeks | Wound surface area percent change per week: Active A: 36.4 Active B: 29.7 Sham: 32.7% (NS; p-value NR) Harms: NR | ~
Gentzkow 1991^182^ Trial Fair N=39 nPU=49/40 Hospital and home | Stage III – IV | 63 years (29–91) Female: 45% General | 4 weeks/8 weeks for safety | Complete healing percent: 49.8% vs. 23.4% (p=0.042) Harms: None | ++
Griffin 1991^183^ Trial Fair N=20/17 Hospital rehabilitation center | Stage II, III, IV | Age: 29 years (10–74) Female: 0% Spinal cord injury | 20 days | Wound surface area median percent change: 80% vs. 52% (p=0.05) Complete healing: Stage II: 2/2 vs. 2/2 Stage III: 1/5 vs. 0/6 Stage IV: 0/1 vs. 0/1 (p-values NR) Harms: NR | +
Houghton 2010^177^ Trial Good N=34 Home care | Stage II, III, IV | Age: 50 years (23–79) Female: 41% Spinal cord injury | 3 months | Wound surface area percent change: 70% vs. 36% (p=0.048) Complete healing: Stage II: complete healing in both groups at 3 months Stage III, IV< or X: 5/15 (33.3%) vs. 1/14 (7.1%, p=0.55) Harms: persistent red area or burn under active electrode after treatment. | +
Kloth 1988^184^ Trial Fair N=16 NR | Stage IV | Age: 66 years (20–89) Female: NR Intact nervous system | 4–16 weeks (mean 7 weeks) | Wound surface area percent change per week: 44.8% decrease vs. 11.6% increase (p-value NR) Complete healing: 100% vs. 0% (p-value NR) Harms: NR | ++
Wood 1993^185^ Trial Fair N=71 nPU=74 Acute care or rehabilitation centers | Stage II or III | Age: 75 years (25–99) Female: 42% General | 8 weeks | Wound surface area more than 80% decrease: 72.9% vs. 12.9% (p<0.0001 for decrease in surface area) Complete healing: 58% vs. 3% (p-value NR) | ++

NPUAP = National Pressure Ulcer Advisory Panel; NR = not reported; NS = not significant

a Pressure ulcer stage indicates NPUAP staging unless otherwise noted. Non-NPUAP staging was converted to the equivalent NPUAP stage where possible.

++Complete wound healing.

+Some improvement in wound healing.

~No difference.

Six studies of electrical stimulation evaluated complete wound healing as either a primary or secondary outcome.177,179,182–185 We did not pool the findings of these six studies using meta-analysis because of statistical heterogeneity of results and inconsistent direction of the estimated effect measures across studies. A small good-quality study of patients with stage II, III, IV, or unstageable ulcers found no significant difference in complete wound healing at 3 months.177 All stage II ulcers (treatment n=4, sham n=1) completely healed at 3 months. For all other ulcers, there was an increase in the percentage of ulcers completely healed in the treatment group (5/15, 33.3 percent) compared with the sham group (1/14, 7.1 percent), but no statistical difference between groups.177 Two fair-quality studies also found no significant difference in complete healing.179,183 Three fair-quality studies enrolling elderly patients found an increase in complete wound healing in the electrical stimulation group compared with the sham treatment at 4–8 weeks (14/49 [28.9 percent] vs. 11/49 [23.4 percent], 9/9 [100 percent] vs. 0/7 [0 percent], and 25/43 [58 percent] vs. 1/31 [3 percent] respectively).177,182,184,185 Two of these studies found a high percentage of completely healed ulcers in the treatment group compared with a very low percentage in the sham group, inconsistent with the results of other trials. Notably, the duration of active treatment for most studies (20 days to 90 days) may not have been long enough to allow for complete healing. One methodologically fair-quality study186 reported on healing rate without providing appropriate primary data or statistical analysis and did not add to the body evidence.

In summary, studies did not demonstrate an effect of electrical stimulation on complete wound healing compared with sham treatment, but indicated that electrical stimulation may be superior to sham treatment in accelerating the rate of wound healing. These findings are consistent with the findings of two prior systematic reviews of electrical stimulation for pressure ulcers.10,187

###### Electromagnetic Therapy

Electromagnetic therapy (EMT) is the delivery of energy composed of an electric field and a magnetic field without direct contact on the skin surface. It is theorized that the electromagnetic field alters the cell membrane, potentially promoting transport across the cell membrane, which is thought to promote healing.189

We found no direct evidence comparing electromagnetic therapy with other interventions for the treatment of pressure ulcers. We identified four fair-quality randomized controlled trials assessing the effectiveness of EMT compared with no EMT or sham EMT in the treatment of stage II – IV pressure ulcers.189–192,193

A trend in the direction of improvement with EMT was found but the significance is called into question. Two studies found a trend toward benefit for EMT in complete wound healing of stage II–III pressure ulcers (85 percent vs. 0 percent190 and 87 percent vs. 67 percent192) but, the difference was not statistically significant (RR 10.00 [95% CI, 0.70 to 143.06] and 7.00 [95% CI, 0.41 to 12016] respectively. Two small, fair- quality studies reported a lower time to complete healing with EMT. One study enrolled stage II and III ulcers and found healing in all stage II ulcers and only those treated with EMT in stage III ulcers (stage II ulcers: 13 days vs. 31.5 days; stage III ulcers: 43 days vs. no complete healing).192 The other study reported a significant difference in the average healing time for stage III–IV ulcers (10.80+/− 4.06 days vs. 18.85 +/− 9.75 days). However their success in completely healing all of these advanced ulcers calls into question their results.193 The rate of healing is dependent on the initial size of the ulcer, which was not balanced between the active and control groups. Differences in baseline wound area may have introduced bias for this outcome. One fair-quality randomized trial191 enrolled 12 patients (nPU=24) with neurologic disorders and stage III or IV pressure ulcers and compared EMT with sham EMT over an average of 30 sessions. No significant difference in improvement of ulcer stage was found between the two groups at the completion of the study (p=0.649).

Our findings of no significant difference in wound improvement despite a trend toward improvement with EMT are consistent with a prior Cochrane review on the topic of electromagnetic therapy for the treatment of pressure ulcers194 However, two additional systematic reviews report on the trend toward improvement with EMT without statistical analysis of the data.10,189 The clinical significance of this trend remains unknown.

###### Therapeutic Ultrasound

Therapeutic ultrasound is the generation of low-frequency sound waves transmitted through soft tissue and created when electrical energy causes deformation of a piezoelectric crystal located in a transducer. The ability of the sound waves to travel through tissue depends on characteristics of the ultrasound and the tissues through which it travels. Both thermal and nonthermal effects of ultrasound are theorized to improve wound healing based primarily on in- vitro studies.195

We found two randomized trials comparing the effectiveness of ultrasound with sham ultrasound (US)196–198 and one randomized trial comparing the combination of ultrasound and ultraviolet light with laser therapy or standard wound care.199

Limited evidence found no significant difference in complete wound healing, although a trend toward improvement with US was seen. All trials were small, had different treatment regimens, and different followup periods. The fair-quality randomized study comparing the combination of ultrasound and ultraviolet-C (UVC) light with laser therapy or standardized wound care enrolled 20 patients comprising 22 wounds and analyzed 16 patients comprising 18 wounds.199 All patients received standard wound care. Six wounds per group were analyzed after receiving either alternating days of ultrasound or UVC 5 days per week, laser therapy 3 days per week, or no additional intervention. For the outcome of complete wound healing, the US/UVC group showed the fastest healing, averaging 4 weeks (range 2–6 weeks) compared with the control group that averaged 7 weeks (range 4–13) and the laser group that averaged 11 weeks (range 3–20). The mean percentage change per week in wound surface area was 53.5 percent for the US/UVC group, 32.4 percent for the control group, and 23.7 percent for the laser group. Although there was a trend toward benefit with ultrasound, no significant difference in complete wound healing was found between US/UV therapy and laser therapy. Given that there is only one small, underpowered study assessing this comparison, there is insufficient evidence to determine if a difference exists in the comparative effectiveness of the combination of US/UVC compared with laser therapy.

Of the two randomized studies (n=128) comparing ultrasound with sham ultrasound, neither study found a significant difference in the complete healing of wounds (76 percent vs. 47 percent196 and 40 percent vs. 44 percent197) and rate of healing. One small pilot study randomized six stage III or IV pressure ulcers in five patients to receive either ultrasound or sham ultrasound.200 They reported a decrease in wound size in the ultrasound group with no change in the sham group, but did not provide specific data to allow comparative analysis for an effect size and therefore do not add to the body of evidence. Our finding of no benefit in wound improvement with therapeutic ultrasound for pressure ulcers is consistent with two prior systematic reviews.10,201

###### Negative Pressure Wound Therapy

Negative pressure wound therapy (NPWT) involves the use of devices that provide a vacuum seal to a wound producing a negative pressure.202 This causes the wound to contract in size while maintaining a moist environment designed to optimize wound healing.202 The negative pressure applied to the wound removes excess interstitial fluid which reduces concentrations of inhibitory factors while increasing blood flow. This effect, as well as the actual disruption of the extracellular matrix of the wound, is believed to promote wound healing.202 The devices include a vacuum pump, drainage tubing, and foam or gauze dressings that are sealed with an adhesive film.

We found evidence on the effectiveness of NPWT from two fair-quality trials and one observational study. There was no evidence of benefit in wound improvement with NPWT.

We found direct evidence from one 6-week, fair-quality trial comparing negative pressure wound therapy to a system of wound gel products in 28 patients.203 Six patients did not complete the study and were not included in analysis. No significant difference was found in complete healing at 6 weeks (NPWT, 2/20 [10 percent] and topical gel, 2/15 [13 percent]). No significant difference was found in reduction of ulcer volume at 6 weeks (NPWT 52 percent and topical gel 42 percent).203 We found no other direct evidence comparing vacuum assisted devices to other interventions for the treatment of pressure ulcers.

One fair-quality randomized trial204 and one fair-quality retrospective cohort study205 compared NPWT with standard wound care in patients with spinal cord injuries and stage III or IV pressure ulcers. The trial randomized 24 patients and analyzed 22 patients and found no significant difference in mean time to 50 percent reduction in wound volume (NPWT 27 days [standard deviation (SD)=10 days]; control 28 days, [SD=10 days], p=0.9).204 The retrospective cohort study used data collected on U.S. veterans. Patients treated with NPWT were matched with patients treated with standard wound care within each participating site based on demographic variables and ulcer surface area on day 1. Ulcers were classified as healing if the wound surface area decreased and as nonhealing if the wound surface area increased. No significant differences were found in percentage of patients demonstrating healing (NPWT 70 percent vs. standard care 67 percent) or nonhealing (NPWT 30 percent vs. standard care 33 percent). No significant difference was found for percentage of reduction in wound surface area in those classified as healing (NPWT 43 +/− 22 percent vs. standard care 50 +/− 26 percent).

Based on these three studies, there was low evidence that negative pressure wound therapy provides no benefit in wound improvement over 4–6 weeks. There was insufficient evidence to determine if NPWT provides any benefit in healing over a longer duration due to short duration of studies. These findings are consistent with a prior systematic review.10

###### Light Therapy

Light therapy involves the delivery of electromagnetic energy to the wound surface to promote healing. In the treatment of pressure ulcers, light therapy involves the delivery of energy from the infrared, visible (wavelength 380–760 nm), and ultraviolet spectrums. There are three types of ultraviolet radiation based on the wavelength of the light transmitted. Ultraviolet-A is the longest wavelength and has the ability to penetrate the deepest. It is the most common type of ultraviolet radiation transmitted to the earth’s surface and is responsible for immediate tanning effect. Ultraviolet-B is the medium wavelength radiation, able to penetrate to more superficial layers of the skin and is most associated with burning and the development of skin cancers. The shortest wavelength radiation is derived from ultraviolet-C light and is considered the most damaging.206 Polarized light involves the use of a crystal that causes the visible electromagnetic wave to vibrate in one direction only. A laser is a device that amplifies light and is notable for its high degree of spatial and temporal coherence.207 We have grouped polarized, infrared, and ultraviolet light, and classified these as light therapy. We have considered laser therapy as an independent class.

We found no direct evidence comparing light therapy with other adjunctive interventions in the treatment of pressure ulcers. We found four fair-quality randomized trials208–212 and one fair-quality observation study198 comparing light therapy with either sham light therapy or standard care in patients with pressure ulcers of the pelvis or lower extremity. Patients were of a general population and had stage I–IV pressure ulcers. Studies were 2–12 weeks in duration. All five studies evaluated change in wound surface area or ulcer size while two studies also measured complete healing and time to complete healing.208,209

We found low-strength evidence of a reduction in wound surface area in pressure ulcers receiving light therapy but no evidence of benefit in complete wound healing. Three trials (n=262) and one observational study (n=55) found a significant difference in reduction in ulcer size208–210,212 while one trial (n=164) found no significant difference. Both studies that measured complete healing of patients with stage II–IV ulcers (n=327) found no significant difference between those receiving light therapy compared with sham light therapy (44 percent vs. 40 percent208 and 54 percent vs. 60 percent209). Similarly, no significant difference was found in time to complete healing in either study (see Table 29).

Table 29 Adjunctive therapies: Light therapy compared with standard wound care or sham light therapy

Author Year Study Type Quality Number Enrolled/Completed Setting | Pressure Ulcer Stage^a^ | Mean age (Range) Sex Population | Followup | Outcomes Measured and Treatment Effect | Benefit: Wound Improvement
Dehlin 2003^208^ Trial Fair N=198/164 8 geriatric centers inpatient/outpatient | Stage II–IV | 84 years (65–105) Female: 65% General | 12 weeks | Complete healing: 44% vs. 40%, p=0.93 Reduction ulcer size: p=0.18 Time until total healing: p=0.93 Harms related or possibly related to treatment: tingling (1); pain (2); bleeding (1); redness (1) | ~
Dehlin 2007^209^ Trial Fair N=181/163 8 geriatric centers inpatient/ outpatient | Stage III | 84 years (65–105) Female: 61% General | 12 weeks | Normalized reduction in ulcer size at week 12: 0.79 vs. 0.50 (p=0.039) Normalized weekly reduction in ulcer size over time 15.1% vs. 10.9% (p-value not reported) Rate of normalized reduction in PU size (p=0.12) Percent totally healed ulcers: 54.4% vs. 59.5%, (p=0.52) Time to totally healed ulcers (p=0.58) Harms possibly related to treatment: 9 patients in each group had skin symptoms (mainly tingling) | +
Durovic 2008^210^ Trial Fair N=48/40 NR | Stage I–III | 65 years (NR) Female: 45% General | 4 weeks | Wound surface area change: 4.29 cm^2^ reduction (p=0.01) vs. 3.82 cm^2^ increase (p=0.001) Harms : NR | +
Iordanou 2002^211^ Observational Fair N=55 Hospital | Stage I–IV | Age: 67 years (37–85) Sex: NR General | 2 weeks | Wound surface area change: 0.58 cm^2^ reduction (p≤0.001) vs. 0.06 cm^2^ reduction (p≤0.007) Harms not reported | +
Schubert 2001^212^ Trial Fair N=67 / 59 Hospital | Stage II–III | Age: 85 years (NR) Female: 64% General | 10 weeks | Wound surface area per week: 29.8% vs. 20.0%; Healing rate: 49% higher for active group (p<0.05). Harms: None | +

NPUAP = National Pressure Ulcer Advisory Panel; NR = not reported; NS = not significant; PU = pressure ulcer

a Pressure ulcer stage indicates NPUAP staging unless otherwise noted. Non-NPUAP staging was converted to the equivalent NPUAP stage where possible.

++Complete wound healing.

+Some improvement in wound healing.

~No difference.

###### Laser Therapy

We found one randomized trial comparing laser therapy with another adjunctive therapy for the treatment of pressure ulcers199 and three randomized trials comparing laser therapy with standard wound care, to standard wound care alone, or sham laser therapy (Table 30).213–215 Trials included 16–86 patients, lasted 5–16 weeks, and used different treatment regimens. Two studies enrolled an elderly population with stage III ulcers213,214 and two enrolled a younger population with spinal cord injuries and stage II–IV pressure ulcers.199,215

Table 30 Adjunctive therapies: Laser therapy compared with standard wound care or sham laser therapy

Author Year Study Type Quality Sample Size Setting | Pressure Ulcer Stage^a^ | Mean Age (Range) Sex Population | Followup | Outcomes Measured and Treatment Effect | Benefit: Wound Improvement
Lucas 2000^213^ Trial Fair N=16 Nursing facility | Stage III pelvic and lower extremity | 88 years (72–95) Female: 88% General population | 6 weeks | Wound surface area median percent change: 83% vs. 95%, NS Harms: None | ~
Lucas 2003^214^ Trial Fair N=86 Nursing facility | Stage III pelvic and lower extremity | 82 ) years (49–100 Female: 63% General population | 6 weeks | Absolute and relative reduction in wound size: NS (p=0.23, p=0.42) Complete wound healing: 18/36 (50%) vs. 15/43 (35%) Wound surface area change: 6/36 (17%) vs. 2/43 (5%) Developed stage IV ulcer: 3/37 (8%) vs. 5/44 (11%), p=0.72 Harms: None | ~
Taly 2004^215^ Trial Good N subjects=35, N pressure ulcers=64 Hospital rehabilitation ward | Stage II–IV pelvic and lower extremity (2 elbow) | 32 years 8–65) Female: 23% Patients with spinal cord injury | 5 weeks | Complete healing: 18/35 pressure ulcers vs. 14/29 pressure ulcers (p=0.80) Time to complete healing: 2.45 weeks vs. 1.78 weeks (p=0.33) Harms: None | ~

NPUAP = National Pressure Ulcer Advisory Panel; NR = not reported; NS = not significant

a Pressure ulcer stage indicates NPUAP staging unless otherwise noted. Non-NPUAP staging was converted to the equivalent NPUAP stage where possible.

++Complete wound healing.

+Some improvement in wound healing.

~No difference.

We found low-strength evidence that laser therapy did not produce wound improvement. The fair-quality randomized study comparing the combination of ultrasound and UVC light with laser therapy or standardized wound care enrolled 20 patients and found faster healing in the US/UVC group (4 weeks) compared with standard therapy (7 weeks) or laser treatment (11 weeks). The mean percentage change per week in wound surface area was 54 percent with US/UVC, 32 percent with standard care, and 24 percent with laser treatment.199 Although a trend toward benefit with ultrasound, at 12 weeks, no significant difference in complete wound healing was found between US/UV therapy and laser therapy (RR=1.44, 95% CI, 0.85 to 2.64).216

Two studies (n=102) found no significant difference in reduction in wound size between treatment groups.213,214 Two studies (n=124/nPU=143) found no significant difference in complete wound healing.214,215 One study found no significant difference in time to complete healing.215

Our findings are consistent with those of a prior systematic review that found no improvement in wound healing with the use of laser therapy to treat pressure ulcers.217

###### Hydrotherapy

Hydrotherapy uses water with or without additives to cleanse the wound and to promote healing. It is frequently provided in the form of whirlpool therapy whereby the body or body part is immersed in the pool avoiding direct contact of the jet stream on the wound so as not to disturb granulation tissue. Pulsatile lavage is a form of hydrotherapy in which a gentle stream of normal saline is applied to the wound directly. The treatment uses a device with a disposable tip for each treatment to minimize risk of contamination.

We found evidence on hydrotherapy from two fair-quality trials, one on whirlpool therapy218 and one on pulsatile lavage.219 Both studies enrolled patients with stage III–IV pressure ulcers. The whirlpool study was set at an acute care facility and enrolling a general population and the pulsatile lavage study set at a rehabilitation center and enrolling men with spinal cord injuries. Only the pulsatile lavage study was able to compare to a sham treatment and both studies considered change in wound size over time as the outcome of interest. The hydrotherapy group from both studies showed a trend toward greater wound improvement over time (whirlpool 58.33 vs. 27.78 percent; p<0.05; −0.33 cm^3^/week in wound volume with pulsatile lavage vs. sham) however none reported on complete wound healing. Given the paucity of evidence and the heterogeneity of the available studies, the evidence is insufficient to draw any conclusions of the effectiveness of hydrotherapy on the treatment of pressure ulcers.

###### Other Adjunctive Therapies

Evidence was limited to a single study on vibration therapy therapy,220,221 extracorporeal shock wave therapy,222 and hyperbaric oxygen.223 Due to study quality, size, and duration, evidence was insufficient to report on comparative effectiveness of these treatments. We elected to perform an additional search specifically on hyperbaric oxygen at the recommendation of our technical expert panel given that this has been an adjunctive therapy commonly used in the treatment of wounds. Our search revealed no additional studies that met our inclusion criteria. The single study on hyperbaric oxygen from our original search was designed to determine if a synergistic effect occurred with electrical stimulation by comparing hyperbaric oxygen alone with the combination of hyperbaric oxygen and electrical stimulation on the healing rates of stage III or IV pressure ulcers.223 Subjects were assigned to receive either hyperbaric oxygen alone twice daily or hyperbaric oxygen twice daily and electrical stimulation five days per week. All wounds diminished in size over time, with no significant difference between the two groups.

##### Evidence About the Comparative Effectiveness of Adjunctive Therapies by Subgroups According to Pressure Ulcer Characteristics (Key Question 1a), Patient Characteristics (Key Question 1b), or Setting (Key Question 1c)

###### Electrical Stimulation

Most studies of electrical stimulation enrolled patients with pelvic and lower extremity pressure ulcers and did not perform subgroup analysis to determine if a difference existed in treatment effectiveness based on anatomic site. Comparison of the results of electrical stimulation studies by ulcer stage (II, III, and IV) and by patients enrolled did not provide evidence of differential effectiveness by ulcer stage.177–180,183,184

Most studies enrolled a general population and did not perform subgroup analysis to allow comparison of treatment effectiveness based on unique patient characteristics. Four trials enrolled only patients with spinal cord injuries and the results were consistent with the overall body of evidence.177,178,181,183 We found similar results in studies that enrolled a younger population (mean age ≤ 51 years)177,180,181,183 compared with an older population (mean age >51 years).178,179,182,184,185

Most studies were conducted in a hospital or rehabilitation center,178,179,183,185 with one study conducted in a home care setting177 and the others in a combination of settings181,182 or not reported.180,184 Findings did not differ based on setting. See Table 30.

###### Electromagnetic Therapy

One trial of EMT (n=30) randomized patients based on baseline stage of ulcer (II or III) to receive either EMT or sham. There was no significant difference in outcomes between the groups, based on baseline ulcer stage.192 The two trials of EMT enrolled different patient populations in different settings, but both had similar findings of no significant effect of EMT.190,192

###### Therapeutic Ultrasound

The two randomized trials comparing ultrasound with sham therapy included a mixed population of hospitalized and nursing facility patients of varying stages of pressure ulcers without subgroup analysis to determine if a difference exists based on features of the pressure ulcer, patient, or care setting.196,197

###### Negative Pressure Wound Therapy

There was a lack of studies evaluating the comparative effectiveness of NPWT according to features of the pressure ulcers or characteristics of the patient resulting in insufficient evidence to draw any conclusions. One retrospective cohort study reported on the effectiveness of patients being treated with NPWT compared with standard wound care in the home care setting.224 The Outcome Concepts System was used to identify patients being treated at home for pressure ulcers and the study considered the outcomes of acute care hospitalization and emergent care rates between January 1, 2003, and December 31, 2004. Patient characteristics were similar in both groups. Sixty patients were treated with NPWT while 2,288 patients were treated with standard wound care.224 Of this small group treated with NPWT, a significantly lower percentage of NPWT patients were hospitalized (35 percent vs. 48 percent, p<0.05), fewer required emergent care services (0 percent vs. 8 percent, p<0.01), and fewer required hospitalization for a wound-related problem (5 percent vs. 14 percent, p<0.01).224 No other study evaluated the outcomes of hospitalization or emergent care needs. Given the small sample size in the NPWT group and given that outcomes of wound healing were not assessed, there was insufficient evidence that NPWT in the home setting provided significant benefit.

###### Light Therapy

Few studies performed subgroup analysis to determine if treatment strategies differed according to features of the pressure ulcers, patient characteristics, or patient care settings. Two studies performed subgroup analysis to determine if differences in outcomes existed based on body mass index.208,209 One study of patients with stage III-IV NPUAP ulcers found a larger reduction in ulcer size for patients with a body mass index <20 (3.3 cm^2^ vs. 2.5 cm^2^, p<0.01)208 but a subsequent study of stage III NPUAP ulcers found no significant difference in this subgroup.209

###### Laser Therapy

No studies performed subgroup analysis to determine if treatment strategies differed according to features of the pressure ulcers, patient characteristics, or patient care settings. Two studies (n=51/nPU=80) enrolled younger patients with spinal cord injuries and found no evidence of benefit in complete wound healing. This was consistent with the overall body of evidence that included a mixed population.199,215

##### Adjunctive Therapies: Harms (Key Question 2)

We found 14 trials and two observational studies evaluating the harms of adjunctive therapies (electrical stimulation [three studies], electromagnetic therapy [one study], ultrasound [three studies], negative pressure [two studies], light therapy [four studies], and laser therapy [three studies]). We found no direct evidence comparing one intervention to another and reporting on comparative harms. Indirect evidence of comparative harms was difficult to derive due to variability in study population, study design, outcomes measured, and sample size.

###### Electrical Stimulation

Three studies reported on harms associated with the use of direct electrical current in the treatment of pressure ulcers compared with sham electrical stimulation.177,179,182 Overall withdrawal was high in the Adunsky study, which enrolled hospitalized frail elders with stage III pressure ulcers in Israel (overall withdrawal 25/63, 40 percent). Fifteen patients withdrew due to adverse events, (11 of 15 [73 percent] in the treatment group), mostly due to clinical (8/15) or ulcer deterioration (4/15). In two other studies, however, withdrawal occurred in only one spinal cord injured patient.177,182 The most commonly reported adverse event was skin irritation. Adunsky reported two cases of excessive granulation (5.2 percent) and two cases of a local irritation when the current was combined with topical sulphadiazine ointment on the wound, believed to be due to the effect of electrical stimulation on the silver ions in the ointment.179

###### Electromagnetic Therapy

One small randomized study (n=30) reported no adverse effects.192

###### Therapeutic Ultrasound

Three studies reported on overall withdrawal, which ranged from 12.5 percent to 32.5 percent, mostly due to death or discharge from the care setting and not related to the intervention.196,198,199 One study reported that 2 of 45 patients in the ultrasound group (4.4 percent) complained of pain associated with ultrasound but no other adverse events were reported.198

###### Negative Pressure Wound Therapy

No controlled studies comparing NPWT to standard care reported on harms. One intervention series of 17 patients with sacral ulcers, stage unknown, reported an overall withdrawal of eight (47 percent), three (18 percent) due to death not attributed to the intervention and five (29 percent) due to need for surgery due to incomplete healing. One retrospective cohort study compared patients being treated with NPWT with patients being treated with standard wound care in the home care setting224 and reported on emergent care or hospitalization for wound infection, deteriorating wound status, or new lesion/ulcer.224 Compared with patients receiving standard care, a significantly lower percentage of NPWT patients were hospitalized for wound related issues (3/60 [5 percent] vs. 310/2288 [14 percent], p<0.01) or required emergent care for wound related issues (0/60 [0 percent] vs. 189/2288 [8 percent], p<0.01).224 Of note, the U.S. Food and Drug Administration reclassified nonpowered devices intended for NPWT as a class II (special controls) device to ensure safety and effectiveness in administration due to reported risk of infection and bleeding. No harms were reported in the one study evaluated on NPWT in the pressure ulcer population.225

###### Light Therapy

Four studies reported on overall withdrawal from studies of light therapy, ranging from 17 to 19 percent, with none believed to be directly related to the treatment.208–210,212 Two studies specifically evaluated adverse events,208,209 with similar number of events occurring in both the light therapy and the sham light therapy groups, and considered unrelated to the treatment. The most common reported adverse event was tingling or pain in or around the wound (n=12 of 327 patients, 3.7 percent). One patient had bleeding in the wound and one patient reported redness.208

###### Laser Therapy

Four studies compared laser therapy with either standard care or sham laser therapy in the treatment of stage II-IV pressure ulcers.199,213–215 No treatment-related adverse events were reported in three studies199,213,214 and one study reported excessive granulation tissue in one of 64 ulcers, the only treatment-related adverse event that was observed.215 One study evaluated the progression to stage IV ulcers in patients with stage III ulcers and found that during the 6-week study, no significant differences existed between groups in the development of stage IV ulcers (5/44 [11 percent] vs. 337 [8 percent], p=0.72).214

##### Evidence About the Harms Related to Adjunctive Therapies by Subgroups According to Pressure Ulcer Characteristics (Key Question 2a), Patient Characteristics (Key Question 2b), or Setting (Key Question 2c)

There was insufficient evidence due to a lack of reporting to determine if differences in harms of any adjunctive therapies exist based on features of the pressure ulcers.

One study of electrical stimulation enrolled hospitalized frail elders with stage III pressure ulcers in Israel and had a high rate of overall withdrawal (25/63, 40 percent) and a high rate of withdrawal due to adverse events (15/63, 24 percent).179 The two other studies reporting on harms associated with electrical stimulation enrolled younger patients, many of whom had spinal cord injuries, and found a very low overall withdrawal or withdrawal due to adverse events.177,182 This difference may be due to the patient age and comorbid features. However, there may have been other differences in treatment delivery, patient populations, or harms assessment that accounted for the observed differences across studies.

There was insufficient evidence to determine if differences existed in harms of any adjunctive therapies based on patient care settings.