# References

1 Bergstrom N, Bennett MA, Carlson CE, et al. Pressure Ulcer Treatment Clin Pract Guidel Quick Ref Guide Clin. 1994;15.
2 Graves N, Birrell F, Whitby M. Effect of pressure ulcers on length of hospital stay. Infect Control Hosp Epidemiol. 2005;26(3):293-7. [pmid: 15796283].
3 Vangilder C, Macfarlane GD, Meyer S. Results of nine international pressure ulcer prevalence surveys: 1989 to 2005. Ostomy Wound Manage. 2008;54(2):40-54. [pmid: 18382042].
4 Lyder CH. Pressure ulcer prevention and management. JAMA. Jan. 8. 2003;289(2):223-6. [pmid: 12517234].
5 NPUAP. Pressure Ulcer Prevention and Treatment: Clinical Practice guidline. National Pressure Ulcer Advisory Panel and European Pressure Ulcer Advisory Panel. 2009.
6 Thomas DR, Rodeheaver GT, Bartolucci AA, et al. Pressure ulcer scale for healing: derivation and validation of the PUSH tool. The PUSH Task Force Adv Wound Care. 1997;10(5):96-101. [pmid: 9362591].
7 Bates-Jensen BM, Vredevoe DL, Brecht ML. Validity and reliability of the Pressure Sore Status Tool. Decubitus. Nov. 1992;5(6):20-8. [pmid: 1489512].
8 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(12)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. April. 2012. Chapters available at: www.effectivehealthcare.ahrq.gov.
9 Institute of Medicine. Finding What Works in Health Care: Standards for Systematic Reviews. Washington, DC. The National Academy of Sciences. 2011.
10 Reddy M, Gill SS, Kalkar SR, et al. Treatment of pressure ulcers: a systematic review. JAMA. Dec. 10. 2008;300(22):2647-62. [pmid: 19066385].
11 Downs SH, Black N. The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions. JECH. 1998;52(6):377-84. [pmid: 9764259].
12 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
13 USPSTF. US Preventive Services Task Force Procedures Manual. 2008 July 2008; No. 08-05118-EF:Section 4: Evidence Report Development.
14 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. Jun. 15. 2002;21(11):1539-58. [pmid: 12111919].
15 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. Sep. 1986;7(3):177-88. [pmid: 3802833].
16 Atkins D, Chang S, Gartlehner G, et al. Assessing applicability when comparing medical interventions: Agency for Healthcare Research and Quality and the Effective Health Care Program. J Clin Epidemiol. 2011;64(11):1198-207. [pmid: 21463926].
17 NPUAP, Panel NPUA. Pressure Ulcer Prevention and Treatment: Clinical Practice guidline. Ver. 01/29/2007 ed. National Pressure Ulcer Advisory Panel. 2007.
18 Russell L, Reynolds TM, Carr J, et al. Randomised controlled trial of two pressure-relieving systems. J Wound Care. Feb. 2000;9(2):52-5. [pmid: 11933280].
19 Russell L, Reynolds T, Carr J, et al. A comparison of healing rates on two pressure-relieving systems. Br J Nurs. Dec 8–2001 Jan 10. 2000;9(22):2270-80. [pmid: 12271193].
20 Evans D, Land L, Geary A. A clinical evaluation of the Nimbus 3 alternating pressure mattress replacement system. J Wound Care. Apr. 2000;9(4):181-6. [pmid: 11933303].
21 Land L, Evans D, Geary A, et al. A clinical evaluation of an alternating-pressure mattress replacement system in hospital and residential care settings. J Tissue Viability. Jan. 2000;10(1):6-11. [pmid: 10839090].
22 Mecocci P, von Strauss E, Cherubini A, et al. Cognitive impairment is the major risk factor for development of geriatric syndromes during hospitalization: results from the GIFA study. Dement Geriatr Cogn Disord. 2005;20(4):262-9. [pmid: 16103670].
23 Devine B. Alternating pressure air mattresses in the management of established pressure sores. J Tissue Viability. 1995;5(3):94-8.
24 Izutsu T, Matsui T, Satoh T, et al. Effect of rolling bed on decubitus in bedridden nursing home patients. Tohoku J Exp Med. Feb. 1998;184(2):153-7. [pmid: 9605022].
25 Clark M, Donald I. A randomised controlled trial comparing the healing of pressure sores upon two pressure-redistributing seat cushions. Proceedings of the 7th European European Conferences on Advances in Wound Management. 18–20, November. Harrogate, UK. 1998:122-5.
26 Caley L, Jones S, Freer J, et al. Randomized Prospective Trial: Treatment Outcomes and Cost-Effectiveness of Two Types of Low-Air-Loss Therapy. 9th Annual Clinical Symposium on Pressure Ulcer and Wound Management. Nashville, TN. October 1994. 1-2.
27 Day A, Leonard F. Seeking quality care for patients with pressure ulcers. Decubitus. Jan. 1993;6(1):32-43. [pmid: 8427642].
28 Flemming K, Cullum N. Therapeutic ultrasound for pressure sores. Cochrane Database Syst Rev. 2000;(4):CD001275. [pmid: 11034707].
29 Mulder G, Taro N, Seeley J, et al. A study of pressure ulcer response to low air loss beds vs. conventional treatment. J Geriatr Dermatol. 1994;2(3):87-91.
30 Warner DJ. A clinical comparison of two pressure-reducing surfaces in the management of pressure ulcers. Decubitus. May. 1992;5(3):52-5. 8. 60. 2. 4. [pmid: 1596352].
31 Groen HW, Groenier KH, Schuling J. Comparative study of a foam mattress and a water mattress. J Wound Care. Jul. 1999;8(7):333-5. [pmid: 10776222].
32 Branom R, Rappl LM. “Constant force technology” versus low-air-loss therapy in the treatment of pressure ulcers. [Erratum appears in Ostomy Wound Manage 2001 Nov;47(11):6]. Ostomy Wound Manage. Sep. 2001;47(9):38-46. [pmid: 11889743].
33 Keogh A, Dealey C. Profiling beds versus standard hospital beds: effects on pressure ulcer incidence outcomes. J Wound Care. Feb. 2001;10(2):15-9. [pmid: 12964222].
34 Rosenthal MJ, Felton RM, Nastasi AE, et al. Healing of advanced pressure ulcers by a generic total contact seat: 2 randomized comparisons with low air loss bed treatments. Arch Phys Med Rehabil. Dec. 2003;84(12):1733-42. [pmid: 14669176].
35 Russell L, Reynolds TM, Towns A, et al. Randomized comparison trial of the RIK and the Nimbus 3 mattresses. Br J Nurs. Feb 27–Mar 12. 6. 2003;12(4):254-9. [pmid: 12671572].
36 Nixon J, Nelson EA, Cranny G, et al. Pressure relieving support surfaces: a randomised evaluation. Health Technol Assess. Jul. 2006;10(22):iii-iv. ix. x. 1. 163. [pmid: 16750060].
37 Thompson P, Anderson J, Langemo D, et al. Support Surfaces: Definitions and Utilization for Patient Care. Adv Skin Wound Care. 2008;21(6):264-6. [pmid: 18525248].
38 Makhsous M, Lin F, Knaus E, et al. Promote pressure ulcer healing in individuals with spinal cord injury using an individualized cyclic pressure-relief protocol. Adv Skin Wound Care. Nov. 2009;22(11):514-21. [pmid: 20026933].
39 Malbrain M, Hendriks B, Wijnands P, et al. A pilot randomised controlled trial comparing reactive air and active alternating pressure mattresses in the prevention and treatment of pressure ulcers among medical ICU patients. J Tissue Viability. Feb. 2010;19(1):7-15. [pmid: 20079647].
40 Valente SA, Greenough WB III, DeMarco SL, et al. More expensive surfaces are not always better. Kuwait Medical Journal. 2012;44(1):40-5.
41 Ochs RF, Horn SD, van Rijswijk L, et al. Comparison of air-fluidized therapy with other support surfaces used to treat pressure ulcers in nursing home residents. Ostomy Wound Manage. Feb. 2005;51(2):38-68. [pmid: 15699554].
42 Ferrell BA, Osterweil D, Christenson P. A randomized trial of low-air-loss beds for treatment of pressure ulcers. JAMA. 1993;269(4):494-7. [pmid: 8338511].
43 Allman RM, Walker JM, Hart MK, et al. Air-fluidized beds or conventional therapy for pressure sores. A randomized trial. Ann Intern Med. Nov. 1987;107(5):641-8. [pmid: 3310792].
44 Jackson BS, Chagares R, Nee N, et al. The effects of a therapeutic bed on pressure ulcers: an experimental study. J Enterostomal Ther. Nov–Dec. 1988;15(6):220-6. [pmid: 3204209].
45 Strauss MJ, Gong J, Gary BD, et al. The cost of home air-fluidized therapy for pressure sores. A randomized controlled trial. J Fam Pract. Jul. 1991;33(1):52-9. [pmid: 2056290].
46 Munro BH, Brown L, Heitman BB. Pressure ulcers: one bed or another?. Geriatr Nurs. 1989;10(4):190-2. [pmid: 2777121].
47 McInnes E. National Institite for Clinical E. The use of pressure-relieving devices (beds, mattresses and overlays) for the prevention of pressure ulcers in primary and secondary care. J Tissue Viability. Jan. 2004;14(1):4-6. 8. 10 passim. [pmid: 14768130].
48 McInnes E, Jammali-Blasi A, Bell-Syer SE, et al. Support surfaces for pressure ulcer prevention. Cochrane Database Syst Rev. 2011;4:CD001735. [pmid: 21491384].
49 Langemo D, Thompson P, Hanson D, et al. Topical anesthesia for pressure ulcer treatment. Adv Skin Wound Care. Aug. 2008;21(8):364-9. [pmid: 18679084].
50 Pinchcofsky-Devin GD, Kaminski MV. Correlation of pressure sores and nutritional status. J Am Geriatr Soc. 1986;34(6):435-40. [pmid: 3084610].
51 Allman RM, Laprade CA, Noel LB, et al. Pressure sores among hospitalized patients. Ann Intern Med. Sep. 1986;105(3):337-42. [pmid: 3740674].
52 European Pressure Ulcer Advisory Panel and National Pressure Ulcer Advisory Panel. Prevention and treatment of pressure ulcers: quick reference guide. Washington, DC. National Pressure Ulcer Advisory Panel. 2009.
53 Cereda E, Gini A, Pedrolli C, et al. Disease-specific, versus standard, nutritional support for the treatment of pressure ulcers in institutionalized older adults: a randomized controlled trial. J Am Geriatr Soc. Aug. 2009;57(8):1395-402. [pmid: 19563522].
54 Ter Riet G, Kessels AGH, Knipschild PG. Randomized clinical trial of ascorbic acid in the treatment of pressure ulcers. J Clin Epidemiol. 1995;48(12):1453-60. [pmid: 8543959].
55 Leigh B, Desneves K, Rafferty J, et al. The effect of different doses of an arginine-containing supplement on the healing of pressure ulcers. J Wound Care. 2012;21(3):150-6. [pmid: 22399084].
56 Meaume S, Kerihuel JC, Constans T, et al. Efficacy and safety of ornithine alpha-ketoglutarate in heel pressure ulcers in elderly patients: results of a randomized controlled trial. J Nutr Health Aging. Aug. 2009;13(7):623-30. [pmid: 19621198].
57 Van Anholt RD, Sobotka L, Meijer EP, et al. An arginine- and micronutrient-enriched nutritional supplement accelerates pressure ulcer healing and reduces wound care in non-malnourished patients. EWMA Journal. 2010 49. 2010;10(2):45.
58 Benati G, Delvecchio S, Cilla D, et al. Impact on pressure ulcer healing of an arginine-enriched nutritional solution in patients with severe cognitive impairment. Arch Gerontol Geriatr Suppl. 2001;7:43-7. [pmid: 11431045].
59 Desneves KJ, Todorovic BE, Cassar A, et al. Treatment with supplementary arginine, vitamin C and zinc in patients with pressure ulcers: a randomised controlled trial. Clin Nutr. Dec. 2005;24(6):979-87. [pmid: 16297506].
60 Lee SK, Posthauer ME, Dorner B, et al. Pressure ulcer healing with a concentrated, fortified, collagen protein hydrolysate supplement: a randomized controlled trial. Adv Skin Wound Care. Mar. 2006;19(2):92-6. [pmid: 16557055].
61 Myers SA, Takiguchi S, Slavish S, et al. Consistent wound care and nutritional support in treatment. Decubitus. Aug. 1990;3(3):16-28. [pmid: 2119183].
62 Ohura T, Nakajo T, Okada S, et al. Evaluation of effects of nutrition intervention on healing of pressure ulcers and nutritional states (randomized controlled trial). Wound Repair Regen. May–Jun. 2011;19(3):330-6. [pmid: 21539650].
63 Chernoff R. The effect of a high protein fomula (Replete) on decubitus ulcer healing in long term tube fed institutionalized patients. J Am Diet Assoc. 1990;90(130).
64 Spungen AM, Koehler KM, Modeste-Duncan R, et al. 9 clinical cases of nonhealing pressure ulcers in patients with spinal cord injury treated with an anabolic agent: a therapeutic trial. Adv Skin Wound Care. May–Jun. 2001;14(3):139-44. [pmid: 11905979].
65 Omote S, Sugama J, Sanada H, et al. Healing process of pressure ulcers after a change in the nutrition regimen of bedridden elderly: a case series. Jpn J Nurs Sci. 2005;2(2):85-93.
66 Breslow RA, Hallfrisch J, Guy DG, et al. The importance of dietary protein in healing pressure ulcers. J Am Geriatr Soc. 1993;41(4):357-62. [pmid: 8463519].
67 Brewer S, Desneves K, Pearce L, et al. Effect of an arginine-containing nutritional supplement on pressure ulcer healing in community spinal patients. J Wound Care. Jul. 2010;19(7):311-6. [pmid: 20616774].
68 Houston S, Haggard J, Williford J Jr, et al. Adverse effects of large-dose zinc supplementation in an institutionalized older population with pressure ulcers [4]. J Am Geriatr Soc. 2001;49(8):1130-2. [pmid: 11555083].
69 Yamamoto T, Fujioka M, Kitamura R, et al. Evaluation of nutrition in the healing of pressure ulcers: are the EPUAP nutritional guidelines sufficient to heal wounds. European Pressure Ulcer Advisory Panel. Wounds. 2009;21(6):153-7.
70 Barnes P Jr, Sauter TE, Zaheri S. Subnormal prealbumin levels and wound healing. Tex Med. Aug. 2007;103(8):65-8. [pmid: 19113064].
71 Frias Soriano L, Lage Vazquez MA, Maristany CP-P, et al. The effectiveness of oral nutritional supplementation in the healing of pressure ulcers. J Wound Care. Sep. 2004;13(8):319-22. [pmid: 15469215].
72 Hollisaz MT, Khedmat H, Yari F. A randomized clinical trial comparing hydrocolloid, phenytoin and simple dressings for the treatment of pressure ulcers [ISRCTN33429693]. BMC Dermatol. 2004;4(1):18. [pmid: 15601464].
73 Alm A, Hornmark AM, Fall PA, et al. Care of pressure sores: a controlled study of the use of a hydrocolloid dressing compared with wet saline gauze compresses. Acta Derm Venereol Suppl (Stockh). 1989;149:1-10. [pmid: 2694713].
74 Xakellis. Hydrocolloid versus saline-gauze dressings in treating pressure ulcers: a cost-effectiveness analysis. Arch Phys Med Rehabil. 1992;73:463-9. [pmid: 1580775].
75 Chang KW, Alsagoff S, Ong KT, et al. Pressure ulcers--randomised controlled trial comparing hydrocolloid and saline gauze dressings. Med J Malaysia. Dec. 1998;53(4):428-31. [pmid: 10971989].
76 Colwell JC, Foreman MD, Trotter JP. A comparison of the efficacy and cost-effectiveness of two methods of managing pressure ulcers. Decubitus. Jul. 1993;6(4):28-36. [pmid: 8297488].
77 Gorse GJ, Messner RL. Improved pressure sore healing with hydrocolloid dressings. Arch Dermatol. Jun. 1987;123(6):766-71. [pmid: 3555355].
78 Kim YC, Shin JC, Park CI, et al. Efficacy of hydrocolloid occlusive dressing technique in decubitus ulcer treatment: a comparative study. Yonsei Med J. Jun. 1996;37(3):181-5. [pmid: 8826783].
79 Mulder GD, Altman M, Seeley JE, et al. Prospective randomized study of the efficacy of hydrogel, hydrocolloid, and saline solution -- moistened dressings on the management of pressure ulcers. Wound Repair Regen. 1993;1(4):213-8. [pmid: 17166097].
80 Neill K, Conforti C, Kedas A, et al. Pressure sore response to a new hydrocolloid dressing. Wounds. 1989;1:173-85.
81 Winter A, Hewitt H. Testing a hydrocolloid. Nurs Times. Dec. 12–8. 1990;86(50):59-62. [pmid: 2255648].
82 Matzen S, Peschardt A, Alsbjorn B. A new amorphous hydrocolloid for the treatment of pressure sores: a randomised controlled study. Scand J Plast Reconstr Surg Hand Surg. Mar. 1999;33(1):13-5. [pmid: 10207960].
83 Kaya AZ, Turani N, Akyuz M. The effectiveness of a hydrogel dressing compared with standard management of pressure ulcers. J Wound Care. Jan. 2005;14(1):42-4. [pmid: 15656468].
84 Thomas DR, Goode PS, LaMaster K, et al. Acemannan hydrogel dressing versus saline dressing for pressure ulcers. A randomized, controlled trial. Adv Wound Care. Oct. 1998;11(6):273-6. [pmid: 10326343].
85 Parnell LKS, Ciufi B, Gokoo CF. Preliminary use of a hydrogel containing enzymes in the treatment of stage II and stage III pressure ulcers. Ostomy Wound Manage. Aug. 2005;51(8):50-60. [pmid: 16234576].
86 Yastrub DJ. Relationship between type of treatment and degree of wound healing among institutionalized geriatric patients with stage II pressure ulcers... reprinted with permission from the author and Nurse Practitioner Associates for Continuing Education. Care Manag J. 2004;5(4):213-8. [pmid: 16294574].
87 Payne WG, Posnett J, Alvarez O, et al. A prospective, randomized clinical trial to assess the cost-effectiveness of a modern foam dressing versus a traditional saline gauze dressing in the treatment of stage II pressure ulcers. Ostomy Wound Manage. Feb. 2009;55(2):50-5. [pmid: 19246785].
88 Kraft MR, Lawson L, Pohlmann B, et al. A comparison of Epi-Lock and saline dressings in the treatment of pressure ulcers. Decubitus. Nov. 1993;6(6):42-4. 6. 8. [pmid: 8286026].
89 Sebern MD. Pressure ulcer management in home health care: efficacy and cost effectiveness of moisture vapor permeable dressing. Arch Phys Med Rehabil. Oct. 1986;67(10):726-9. [pmid: 3533007].
90 Kurzuk-Howard G, Simpson L, Palmieri A. Decubitus ulcer care: a comparative study. West J Nurs Res. Feb. 1985;7(1):58-79. [pmid: 3850687].
91 Oleske DM, Smith XP, White P, et al. A randomized clinical trial of two dressing methods for the treatment of low-grade pressure ulcers. J Enterostomal Ther. May–Jun. 1986;13(3):90-8. [pmid: 3519718].
92 Day A, Dombranski S, Farkas C, et al. Managing sacral pressure ulcers with hydrocolloid dressings: results of a controlled, clinical study. Ostomy Wound Manage. Mar. 1995;41(2):52-4. 6. 8 passim. [pmid: 7598778].
93 Darkovich SL, Brown-Etris M, Spencer M. Biofilm hydrogel dressing: a clinical evaluation in the treatment of pressure sores. Ostomy Wound Manage. Jul–Aug. 1990;29:47-60. [pmid: 2202317].
94 Motta G, Dunham L, Dye T, et al. Clinical efficacy and cost-effectiveness of a new synthetic polymer sheet wound dressing. Ostomy Wound Manage. Oct. 4. 1999;45(10):41-6. 8. 9. [pmid: 10687651].
95 Brown-Etris M, Milne C, Orsted H, et al. A prospective, randomized, multisite clinical evaluation of a transparent absorbent acrylic dressing and a hydrocolloid dressing in the management of Stage II and shallow Stage III pressure ulcers. Adv Skin Wound Care. Apr. 2008;21(4):169-74. [pmid: 18385577].
96 Bale S, Squires D, Varnon T, et al. A comparison of two dressings in pressure sore management. J Wound Care. Nov. 1997;6(10):463-6. [pmid: 9455271].
97 Honde C, Derks C, Tudor D. Local treatment of pressure sores in the elderly: amino acid copolymer membrane versus hydrocolloid dressing. J Am Geriatr Soc. Nov. 1994;42(11):1180-3. [pmid: 7525682].
98 Seeley J, Jensen JL, Hutcherson J. A randomized clinical study comparing a hydrocellular dressing to a hydrocolloid dressing in the management of pressure ulcers. Ostomy Wound Manage. Jun. 1999;45(6):39-44. 6. 7. [pmid: 10655861].
99 Banks V, Bale SE, Harding KG. Comparing two dressings for exuding pressure sores in community patients. J Wound Care. 1994;3(4):175-8.
100 Banks V, Bale S, Harding K. The use of two dressings for moderately exuding pressure sores. J Wound Care. 1994;3(3):132-4.
101 Brod M, McHenry E, Plasse TF, et al. A randomized comparison of poly-hema and hydrocolloid dressings for treatment of pressure sores. Arch Dermatol. Jul. 1990;126(7):969-70. [pmid: 2193631].
102 Bale S, Hagelstein S, Banks V, et al. Costs of dressings in the community. J Wound Care. Jul. 1998;7(7):327-30. [pmid: 9791356].
103 Thomas S, Banks V, Bale S, et al. A comparison of two dressings in the management of chronic wounds. J Wound Care. Sep. 1997;6(8):383-6. [pmid: 9341430].
104 Bale S, Banks V, Haglestein S, et al. A comparison of two amorphous hydrogels in the debridement of pressure sores. J Wound Care. Feb. 1998;7(2):65-8. [pmid: 9543975].
105 Belmin J, Meaume S, Rabus M-T, et al. Sequential treatment with calcium alginate dressings and hydrocolloid dressings accelerates pressure ulcer healing in older subjects: a multicenter randomized trial of sequential versus nonsequential treatment with hydrocolloid dressings alone. J Am Geriatr Soc. Feb. 2002;50(2):269-74. [pmid: 12028208].
106 Meaume S, Vallet D, Morere MN, et al. Evaluation of a silver-releasing hydroalginate dressing in chronic wounds with signs of local infection. [Erratum appears in J Wound Care. 2005 Nov;14(10):479]. J Wound Care. Oct. 2005;14(9):411-9. [pmid: 16240620].
107 Meaume S, Van De Looverbosch D, Heyman H, et al. A study to compare a new self-adherent soft silicone dressing with a self-adherent polymer dressing in stage II pressure ulcers. Ostomy Wound Manage. Sep. 2003;49(9):44-51. [pmid: 14581709].
108 Viamontes L, Temple D, Wytall D, et al. An evaluation of an adhesive hydrocellular foam dressing and a self-adherent soft silicone foam dressing in a nursing home setting. Ostomy Wound Manage. Aug. 2003;49(8):48-52. 4. 6. 8. [pmid: 14631663].
109 Thomas DR, Diebold MR, Eggemeyer LM. A controlled, randomized, comparative study of a radiant heat bandage on the healing of stage 3–4 pressure ulcers: a pilot study. J Am Med Dir Assoc. Jan–Feb. 2005;6(1):46-9. [pmid: 15871870].
110 Price P, Bale S, Crook H, et al. The effect of a radiant heat dressing on pressure ulcers. J Wound Care. Apr. 2000;9(4):201-5. [pmid: 11933306].
111 Kloth LC, Berman JE, Nett M, et al. A randomized controlled clinical trial to evaluate the effects of noncontact normothermic wound therapy on chronic full-thickness pressure ulcers. Adv Skin Wound Care. Nov–Dec. 2002;15(6):270-6. [pmid: 12477979].
112 Whitney JD, Salvadalena G, Higa L, et al. Treatment of pressure ulcers with noncontact normothermic wound therapy: healing and warming effects. J Wound Ostomy Continence Nurs. Sep. 2001;28(5):244-52. [pmid: 11557928].
113 Bito S, Mizuhara A, Oonishi S, et al. Randomised controlled trial evaluating the efficacy of wrap therapy for wound healing acceleration in patients with NPUAP stage II and III pressure ulcer. 2012;2:e000371. [pmid: 22223842].
114 Kerihuel JC. Effect of activated charcoal dressings on healing outcomes of chronic wounds. J Wound Care. May. 10. 2010;19(5):208-2. 14. 5. [pmid: 20505594].
115 Small N, Mulder M, Mackenzie MJ, et al. A comparative analysis of pressure sore treatment modalities in community settings. Curationis. Feb. 2002;25(1):74-82. [pmid: 12096575].
116 Yapucu Gunes U, Eser I. Effectiveness of a honey dressing for healing pressure ulcers. J Wound Ostomy Continence Nurs. Mar–Apr. 2007;34(2):184-90. [pmid: 17413836].
117 Burgos A, Gimenez J, Moreno E, et al. Collagenase ointment application at 24- versus 48-hour intervals in the treatment of pressure ulcers. A randomised multicentre study. Clin Drug Investig. 2000;19(6):399-407.
118 Burgos A, Gimenez J, Moreno E, et al. Cost, efficacy, efficiency and tolerability of collagenase ointment versus hydrocolloid occlusive dressing in the treatment of pressure ulcers. A comparative, randomised, multicentre study. Clin Drug Investig. 2000;19(5):357-65.
119 Pullen R, Popp R, Volkers P, et al. Prospective randomized double-blind study of the wound-debriding effects of collagenase and fibrinolysin/deoxyribonuclease in pressure ulcers. Age Ageing. Mar. 2002;31(2):126-30. [pmid: 11937475].
120 Alvarez OM, Fernandez-Obregon A, Rogers RS, et al. Chemical debridement of pressure ulcers: a prospective, randomized, comparative trial of collagenase and papain/urea formulations. Wounds. 2000;12(2):15-25.
121 Muller E, van Leen MW, Bergemann R. Economic evaluation of collagenase-containing ointment and hydrocolloid dressing in the treatment of pressure ulcers. Pharmacoeconomics. 2001;19(12):1209-16. [pmid: 11772156].
122 Agren MS, Stromberg HE. Topical treatment of pressure ulcers. A randomized comparative trial of Varidase and zinc oxide. Scand J Plast Reconstr Surg. 1985;19(1):97-100. [pmid: 3895409].
123 Subbanna PK, Margaret Shanti FX, George J, et al. Topical phenytoin solution for treating pressure ulcers: a prospective, randomized, double-blind clinical trial. Spinal Cord. Nov. 2007;45(11):739-43. [pmid: 17279096].
124 Rhodes RS, Heyneman CA, Culbertson VL, et al. Topical phenytoin treatment of stage II decubitus ulcers in the elderly. Ann Pharmacother. Jun. 2001;35(6):675-81. [pmid: 11408983].
125 Sayag J, Meaume S, Bohbot S. Healing properties of calcium alginate dressings. J Wound Care. Sep. 1996;5(8):357-62. [pmid: 8954425].
126 Colin D, Kurring PA, Yvon C. Managing sloughy pressure sores. J Wound Care. Nov. 1996;5(10):444-6. [pmid: 9117814].
127 Graumlich JF, Blough LS, McLaughlin RG, et al. Healing pressure ulcers with collagen or hydrocolloid: A randomized, controlled trial. J Am Geriatr Soc. 2003;51(2):147-54. [pmid: 12558709].
128 Zeron HM, Krotzsch Gomez FE, Munoz REH. Pressure ulcers: a pilot study for treatment with collagen polyvinylpyrrolidone. Int J Dermatol. Mar. 2007;46(3):314-7. [pmid: 17343594].
129 Nisi G, Brandi C, Grimaldi L, et al. Use of a protease-modulating matrix in the treatment of pressure sores. Chir Ital. Jul–Aug. 2005;57(4):465-8. [pmid: 16060184].
130 Gerding GA, Browning JS. Oxyquinoline-containing ointment vs. standard therapy for stage I and stage II skin lesions. Dermatol Nurs. Oct. 1992;4(5):389-98. [pmid: 1482629].
131 Chuangsuwanich A, Charnsanti O, Lohsiriwat V, et al. The efficacy of silver mesh dressing compared with silver sulfadiazine cream for the treatment of pressure ulcers. J Med Assoc Thai. May. 2011;94(5):559-65. [pmid: 21675444].
132 Sherman RA, Wyle F, Vulpe M. Maggot therapy for treating pressure ulcers in spinal cord injury patients. J Spinal Cord Med. Apr. 1995;18(2):71-4. [pmid: 7640976].
133 Sherman RA. Maggot versus conservative debridement therapy for the treatment of pressure ulcers. Wound Repair Regen. Jul–Aug. 2002;10(4):208-14. [pmid: 12191002].
134 Wang S-y, Wang J-n, Lv D-c, et al. Clinical research on the bio-debridement effect of maggot therapy for treatment of chronically infected lesions. Orthop Surg. 2010;2(3):201-6. [pmid: 22009949].
135 Sipponen A, Jokinen JJ, Sipponen P, et al. Beneficial effect of resin salve in treatment of severe pressure ulcers: a prospective, randomized and controlled multicentre trial. Br J Dermatol. May. 2008;158(5):1055-62. [pmid: 18284391].
136 Guthrie M, Diakiw J, Zaydon AC, et al. A randomized double-blind clinical study of dermagran dual therapeutic system in the treatment of decubitus ulcers. Wounds. 1989;1(3):142-54.
137 Kuflik A, Stillo JV, Sanders D, et al. Petrolatum versus Resurfix ointment in the treatment of pressure ulcers. Ostomy Wound Manage. Feb. 2001;47(2):52-6. [pmid: 11235499].
138 LeVasseur SA, Helme RD. A double-blind clinical trial to compare the efficacy of an active based cream F14001 against a placebo non-active based cream for the treatment of pressure ulcers in a population of elderly subjects. J Adv Nurs. Aug. 1991;16(8):952-6. [pmid: 1779084].
139 Shamimi Nouri K, Karimian R, Nasli E, et al. Topical application of Semelil (ANGIPARS(trademark)) in treatment of pressure ulcers: A randomized clinical trial. Daru. 2008;16(SUPPL 1):54-7.
140 Hsu YC, Chang HH, Chen MF, et al. Therapeutic effect of sheng-ji-san on pressure ulcers. Am J Chin Med. 2000;28(3-4):391-9. [pmid: 11154053].
141 Felzani G, Spoletini I, Convento A, et al. Effect of lysine hyaluronate on the healing of decubitus ulcers in rehabilitation patients. Adv Ther. May. 2011;28(5):439-45. [pmid: 21499725].
142 Tytgat H, Van Asch H. Topical ketanserin in the treatment of decubitus ulcers: A double-blind study with 2% ketanserin ointment against placebo. Adv Ther. 1988;5(4):143-52.
143 Narayanan S, Van Vleet J, Strunk B, et al. Comparison of pressure ulcer treatments in long-term care facilities: clinical outcomes and impact on cost. J Wound Ostomy Continence Nurs. May–Jun. 2005;32(3):163-70. [pmid: 15931146].
144 Rees RS, Robson MC, Smiell JM, et al. Becaplermin gel in the treatment of pressure ulcers: a phase II randomized, double-blind, placebo-controlled study. Wound Repair Regen. May–Jun. 1999;7(3):141-7. [pmid: 10417749].
145 Robson MC, Phillips LG, Thomason A, et al. Platelet-derived growth factor BB for the treatment of chronic pressure ulcers. Lancet. Jan. 4. 1992;339(8784):23-5. [pmid: 1345953].
146 Robson MC, Phillips LG, Thomason A, et al. Recombinant human platelet-derived growth factor-BB for the treatment of chronic pressure ulcers. Ann Plast Surg. 1992;29(3):193-201. [pmid: 1524367].
147 Mustoe TA, Cutler NR, Allman RM, et al. A phase II study to evaluate recombinant platelet-derived growth factor-BB in the treatment of stage 3 and 4 pressure ulcers. Arch Surg. Feb. 1994;129(2):213-9. [pmid: 8304833].
148 Scevola S, Nicoletti G, Brenta F, et al. Allogenic platelet gel in the treatment of pressure sores: a pilot study. Int Wound J. Jun. 2010;7(3):184-90. [pmid: 20455960].
149 Landi F, Aloe L, Russo A, et al. Topical treatment of pressure ulcers with nerve growth factor: a randomized clinical trial. Ann Intern Med. Oct. 21. 2003;139(8):635-41. [pmid: 14568851].
150 Payne WG, Wright TE, Ochs D, et al. An exploratory study of dermal replacement therapy in the treatment of stage III pressure ulcers. J Appl Res. 2004;4(1):12-23.
151 Robson MC, Phillips LG, Lawrence WT, et al. The safety and effect of topically applied recombinant basic fibroblast growth factor on the healing of chronic pressure sores. Ann Surg. Oct. 1992;216(4):401-6. discussion 6–8. [pmid: 1417189].
152 Hirshberg J, Coleman J, Marchant B, et al. TGF-beta3 in the treatment of pressure ulcers: a preliminary report. Adv Skin Wound Care. Mar–Apr. 2001;14(2):91-5. [pmid: 11899912].
153 Robson MC, Hill DP, Smith PD, et al. Sequential cytokine therapy for pressure ulcers: clinical and mechanistic response. Ann Surg. Apr. 2000;231(4):600-11. [pmid: 10749622].
154 Payne WG, Ochs DE, Meltzer DD, et al. Long-term outcome study of growth factor-treated pressure ulcers. Am J Surg. Jan. 2001;181(1):81-6. [pmid: 11248182].
155 Robson LE. Safety and effect of topical recombinant human interleukin-1beta in the management of pressure sores. Wound Repair Regen. Jul. 1994;2(3):177-81. [pmid: 17156109].
156 Zuloff-Shani A, Adunsky A, Even-Zahav A, et al. Hard to heal pressure ulcers (stage III-IV): efficacy of injected activated macrophage suspension (AMS) as compared with standard of care (SOC) treatment controlled trial. Arch Gerontol Geriatr. Nov–Dec. 2010;51(3):268-72. [pmid: 20034682].
157 Danon D, Madjar J, Edinov E, et al. Treatment of human ulcers by application of macrophages prepared from a blood unit. Exp Gerontol. Nov–Dec. 1997;32(6):633-41. [pmid: 9785089].
158 Whitney J, Higa L, Savadalena G, et al. Effect of radiant heat treatment on pressure ulcer healing: preliminary findings. 31st Annual Wound, Ostomy and Continence Conference. 1999.
159 Meaume S, Ourabah Z, Charru P, et al. Optimizing wound care with a new lipido-colloid dressing (Urgotul Duo). Br J Nurs. Mar 22–Apr 11. 2007;16(6):S4. S6. S8 passim. [pmid: 17505400].
160 Stoker FM. A major contributor. Evaluation of Comfeel Pressure Relieving Dressing. Prof Nurse. Sep. 1990;5(12):644-53. [pmid: 2217219].
161 Moody M. Calcium alginate: a dressing trial. Nurs Stand. 1991;5(50):3-6. [pmid: 1911033].
162 Harding KG, Bale S, Stock J, et al. A multi-center comparison of a hydrocellular adhesive dressing and a hydrocolloid dressing in the management of stage II and III pressure ulcers. 9th Annual Symposium on Advanced Wound Care and 6th Annual Medical Research Forum on Wound Repair. 1996.
163 Hindryckx P, De Cuyper C, Hendrickx B, et al. The treatment of infected decubitus ulcers with 1% silver sulfadiazine cream. Curr Ther Res Clin Exp. 1990;48(3):535-9.
164 Sorensen JL, Jorgensen B, Gottrup F. Surgical treatment of pressure ulcers. Am J Surg. Jul. 2004;188(1A Suppl):42-51. [pmid: 15223502].
165 Juri H, Palma A, Obeide A. The CO2 laser in the treatment of decubitus ulcer. J Neurol Orth Med Surg. 1986;7(1):29-33. [pmid: 3683061].
166 Kierney PC, Engrav LH, Isik FF, et al. Results of 268 pressure sores in 158 patients managed jointly by plastic surgery and rehabilitation medicine. Plast Reconstr Surg. Sep. 1998;102(3):765-72. [pmid: 9727442].
167 Yamamoto Y, Tsutsumida A, Murazumi M, et al. Long-term outcome of pressure sores treated with flap coverage. Plast Reconstr Surg. Oct. 1997;100(5):1212-7. [pmid: 9326782].
168 Schryvers OI, Stranc MF, Nance PW. Surgical treatment of pressure ulcers: 20-year experience. Arch Phys Med Rehabil. Dec. 2000;81(12):1556-62. [pmid: 11128889].
169 Foster RD, Anthony JP, Mathes SJ, et al. Flap selection as a determinant of success in pressure sore coverage. Arch Surg. Aug. 1997;132(8):868-73. [pmid: 9267271].
170 Foster RD, Anthony JP, Mathes SJ, et al. Ischial pressure sore coverage: A rationale for flap selection. Br J Plast Surg. 1997;50(5):374-9. [pmid: 9245873].
171 Tavakoli K, Rutkowski S, Cope C, et al. Recurrence rates of ischial sores in para- and tetraplegics treated with hamstring flaps: an 8-year study. Br J Plast Surg. Sep. 1999;52(6):476-9. [pmid: 10673925].
172 Feedar JAK, LC. Acceleration of wound healing with high voltage pulsating direct current (abstract). Phys Ther. 1985;(65):741.
173 Stefanovska A. Treatment of chronic wounds by means of electric and electromagnetic fields. Part 2. Value of FES parameters for pressure sore treatment. Med Biol Eng Comput. May. 1993;31(3):213-20. [pmid: 8412373].
174 Onigbinde AT, Olafimihan KF, Ojoawo A, et al. The effect of ultraviolet radiation (type B) on decubitus ulcers. Internet J Allied Health Sci Pract. 2010;8(1):1-6.
175 Srivastava RN. An innovative, cost-effective, negative pressure device for management of bedsores in traumatic paraplegia. Spine J. 2010;10(9):86S-7S.
176 Berlowitz DR, Ratliff C, Cuddigan J, et al. The PUSH tool: a survey to determine its perceived usefulness. Adv Skin Wound Care. Nov–Dec. 2005;18(9):480-3. [pmid: 16365545].
177 Houghton PE, Campbell KE, Fraser CH, et al. Electrical stimulation therapy increases rate of healing of pressure ulcers in community-dwelling people with spinal cord injury. Arch Phys Med Rehabil. May. 2010;91(5):669-78. [pmid: 20434602].
178 Adegoke BO, Badmos KA. Acceleration of pressure ulcer healing in spinal cord injured patients using interrupted direct current. Afr J Med Med Sci. Sep. 2001;30(3):195-7. [pmid: 14510128].
179 Adunsky A, Ohry A, Group D. Decubitus direct current treatment (DDCT) of pressure ulcers: results of a randomized double-blinded placebo controlled study. Arch Gerontol Geriatr. Nov–Dec. 2005;41(3):261-9. [pmid: 15998547].
180 Ahmad ET. High voltage pulsed galvanic stimulation: effect of treatment durations on healing of chronic pressure ulcers. Indian J Physiother Occup Ther. 2008;2(3):1-5. [pmid: 21991123].
181 Baker LL, Rubayi S, Villar F, et al. Effect of electrical stimulation waveform on healing of ulcers in human beings with spinal cord injury. Wound Repair Regen. Jan–Mar. 1996;4(1):21-8. [pmid: 17129344].
182 Gentzkow GD, Pollack VP, Kloth LC, et al. Improved healing of pressure ulcers using Dermapulse, a new electrical stimulation device. Wounds. 1991;3(5):158-70.
183 Griffin JW, Tooms RE, Mendius RA, et al. Efficacy of high voltage pulsed current for healing of pressure ulcers in patients with spinal cord injury. Phys Ther. Jun. 1991;71(6):433-42. discussion 42–4. [pmid: 2034707].
184 Kloth LC, Feedar JA. Acceleration of wound healing with high voltage, monophasic, pulsed current. [Erratum appears in Phys Ther 1989 Aug;69(8):702]. Phys Ther. Apr. 1988;68(4):503-8. [pmid: 3258429].
185 Wood JM, Evans PE 3rd, Schallreuter KU, et al. A multicenter study on the use of pulsed low-intensity direct current for healing chronic stage II and stage III decubitus ulcers. Arch Dermatol. Aug. 1993;129(8):999-1009. [pmid: 8352625].
186 Ullah MO. A study to detect the efficacy of Micro-current Electrical Therapy on decubitus wound. J Med Sci. 2007;7(8):1320-4.
187 Gardner SE, Frantz RA, Schmidt FL. Effect of electrical stimulation on chronic wound healing: a meta-analysis. Wound Repair Regen. Nov–Dec. 1999;7(6):495-503. [pmid: 10633009].
188 Ahmad ET. High-voltage pulsed galvanic stimulation: effect of treatment duration on healing of chronic pressure ulcers. Ann Burns Fire Disasters. 2008;21(3):124-8. [pmid: 21991123].
189 McGaughey H, Dhamija S, Oliver L, et al. Pulsed electromagnetic energy in management of chronic wounds: a systematic review. Phys Ther Rev. 2009;14(2):132-46.
190 Comorosan S, Vasilco R, Arghiropol M, et al. The effect of diapulse therapy on the healing of decubitus ulcer. Rom J Physiol. Jan–Jun. 1993;30(1–2):41-5. [pmid: 7982015].
191 Gupta A, Taly AB, Srivastava A, et al. Efficacy of pulsed electromagnetic field therapy in healing of pressure ulcers: A randomized control trial. Neurol India. Sep–Oct. 2009;57(5):622-6. [pmid: 19934563].
192 Salzberg CA, Cooper-Vastola SA, Perez FJ, et al. The effects of non-thermal pulsed electromagnetic energy (DIAPULSE) on wound healing of pressure ulcers in spinal cord-injured patients: a randomized, double-blind study. Wounds. Jan–Feb. 1995;7(1):11-6.
193 Ozdemir F, Kasapoglu M, Oymak F, et al. Efficiency of magnetic field treatment on pressure sores in bedridden patients. Balkan Medical Journal. 2011;28(3):274-8.
194 Aziz Z, Flemming K, Cullum NA, et al. Electromagnetic therapy for treating pressure ulcers. Cochrane Database Syst Rev. 2010;11:CD002930. [pmid: 21069672].
195 Speed CAC. Therapeutic ultrasound in soft tissue lesions. Rheumatology (Oxford). 2001;40(12):1331-6. [pmid: 11752501].
196 McDiarmid T, Burns PN, Lewith GT, et al. Ultrasound and the treatment of pressure sores. Physiotherapy. 1985;71(2):66-70.
197 Ter Riet G, Kessels AGH, Knipschild P. Randomised clinical trial of ultrasound treatment for pressure ulcers. Br Med J. 1995;310(6986):1040-1. [pmid: 7728058].
198 Ter Riet G, Kessels AGH, Knipschild P. A randomized clinical trial of ultrasound in the treatment of pressure ulcers. Phys Ther. 1996;76(12):1301-12. [pmid: 8959999].
199 Nussbaum EL, Biemann I, Mustard B. Comparison of ultrasound/ultraviolet-C and laser for treatment of pressure ulcers in patients with spinal cord injury. Phys Ther. Sep. 1994;74(9):812-23. discussion 24–5. [pmid: 8066108].
200 Maeshige N, Fujiwara H, Honda H, et al. Evaluation of the combined use of ultrasound irradiation and wound dressing on pressure ulcers. J Wound Care. Feb. 2010;19(2):63-8. [pmid: 20216490].
201 Sari AA, Flemming K, Cullum NA, et al. Therapeutic ultrasound for pressure ulcers. Cochrane Database Syst Rev. 2009;(4).
202 Sullivan N, Snyder DL, Tipton K, et al. Negative Pressure Wound Therapy Devices. Technology Assessment Report. Rockville, Maryland. AHRQ. 2009:494.
203 Ford CN, Reinhard ER, Yeh D, et al. Interim analysis of a prospective, randomized trial of vacuum-assisted closure versus the healthpoint system in the management of pressure ulcers. Ann Plast Surg. Jul. 2002;49(1):55-61. discussion. [pmid: 12142596].
204 Wanner MB, Schwarzl F, Strub B, et al. Vacuum-assisted wound closure for cheaper and more comfortable healing of pressure sores: a prospective study. Scand J Plast Reconstr Surg Hand Surg. 2003;37(1):28-33. [pmid: 12625392].
205 Ho CH, Powell HL, Collins JF, et al. Poor nutrition is a relative contraindication to negative pressure wound therapy for pressure ulcers: preliminary observations in patients with spinal cord injury. Adv Skin Wound Care. Nov. 2010;23(11):508-16. [pmid: 20975334].
206 WHO. UV raditation. World Health Organization. 2012.
207 Wikipedia. Laser. Wikipedia. Wikipedia. 2012.
208 Dehlin O, Elmstahl S, Gottrup F. Monochromatic phototherapy in elderly patients: a new way of treating chronic pressure ulcers?. [Erratum appears in Aging Clin Exp Res. 2003 Dec;15(6):519]. Aging Clin Exp Res. Jun. 2003;15(3):259-63. [pmid: 14582689].
209 Dehlin O, Elmstahl S, Gottrup F. Monochromatic phototherapy: effective treatment for grade II chronic pressure ulcers in elderly patients. Aging Clin Exp Res. Dec. 2007;19(6):478-83. [pmid: 18172370].
210 Durovic A, Maric D, Brdareski Z, et al. The effects of polarized light therapy in pressure ulcer healing. Vojnosanit Pregl. Dec. 2008;65(12):906-12. [pmid: 19160985].
211 Iordanou P, Baltopoulos G, Giannakopoulou M, et al. Effect of polarized light in the healing process of pressure ulcers. [Erratum appears in Int J Nurs Pract 2002 Apr;8(2):116]. Int J Nurs Pract. Feb. 2002;8(1):49-55. [pmid: 11831427].
212 Schubert V. Effects of phototherapy on pressure ulcer healing in elderly patients after a falling trauma. A prospective, randomized, controlled study. Photodermatol Photoimmunol Photomed. Feb. 2001;17(1):32-8. [pmid: 11169174].
213 Lucas C, Coenen CHM, De Haan RJ. The effect of low level laser therapy (LLLT) on stage III decubitus ulcers (pressure sores); A prospective randomised single blind, multicentre pilot study. Lasers Med Sci. 2000;15(2):94-100. [pmid: 12928815].
214 Lucas C, van Gemert MJC, de Haan RJ. Efficacy of low-level laser therapy in the management of stage III decubitus ulcers: a prospective, observer-blinded multicentre randomised clinical trial. Lasers Med Sci. 2003;18(2):72-7. [pmid: 12928815].
215 Taly AB, Sivaraman Nair KP, Murali T, et al. Efficacy of multiwavelength light therapy in the treatment of pressure ulcers in subjects with disorders of the spinal cord: A randomized double-blind controlled trial. Arch Phys Med Rehabil. Oct. 2004;85(10):1657-61. [pmid: 15468027].
216 Akbari Sari A, Flemming K, Cullum NA, et al. Therapeutic ultrasound for pressure ulcers. Cochrane Database Syst Rev. 2009;(1). [pmid: 16855964].
217 Lucas C, Stanborough RW, Freeman CL, et al. Efficacy of low-level laser therapy on wound healing in human subjects: A systematic review. Lasers Med Sci. 2000;15(2):84-93.
218 Burke DT, Ho CHK, Saucier MA, et al. Effects of hydrotherapy on pressure ulcer healing. Am J Phys Med Rehabil. 1998;77(5):394-8. [pmid: 9798830].
219 Ho CH, Bensitel T, Wang X, et al. Pulsatile lavage for the enhancement of pressure ulcer healing: a randomized controlled trial. Phys Ther. 2012;92(1):38-48. [pmid: 21949432].
220 Arashi M, Sugama J, Sanada H, et al. Vibration therapy accelerates healing of Stage I pressure ulcers in older adult patients. Adv Skin Wound Care. Jul. 2010;23(7):321-7. [pmid: 20562541].
221 Arashi M, Sugama J, Sanada H. Vibration Therapy Accelerates Healing of Stage I Pressure Ulcers in Older Adult Patients. Journal of Wound, Ostomy & Continence Nursing. 2011:S8-S.
222 Larking AM, Duport S, Clinton M, et al. Randomized control of extracorporeal shock wave therapy versus placebo for chronic decubitus ulceration. Clin Rehabil. Mar. 2010;24(3):222-9. [pmid: 20156981].
223 Edsberg LE, Brogan MS, Jaynes CD, et al. Topical hyperbaric oxygen and electrical stimulation: exploring potential synergy. Ostomy Wound Manage. Nov. 2002;48(11):42-50. [pmid: 12426451].
224 Schwien T, Gilbert J, Lang C. Pressure ulcer prevalence and the role of negative pressure wound therapy in home health quality outcomes. Ostomy Wound Manage. Sep. 2005;51(9):47-60. [pmid: 16230764].
225 U.S. Food and Drug Administration. Medical devices; general and plastic surgery devices; classification of non-powered suction apparatus device intended for negative pressure wound therapy. Final rule. Federal Register. 2010/11/26 ed. 2010:70112-4.
226 Cullum N, Deeks JJ, Fletcher AW, et al. Effectiveness bulletin. Preventing and treating pressure sores. Qual Health Care. 1995;4(4):289-97. [pmid: 10156400].
227 Cullum N, Deeks J, Sheldon TA, et al. Beds, mattresses and cushions for pressure sore prevention and treatment. J Tissue Viability. Oct. 1999;9(4):138. [pmid: 10808844].
228 Cullum N, Nelson EA, Flemming K, et al. Systematic reviews of wound care management: (5) beds; (6) compression; (7) laser therapy, therapeutic ultrasound, electrotherapy and electromagnetic therapy. Health Technol Assess. 2001;5(9):1-221. [pmid: 11368833].
229 Langer G, Schloemer G, Knerr A, et al. Nutritional interventions for preventing and treating pressure ulcers. Cochrane Database Syst Rev. 2003;(4):CD003216. [pmid: 14583961].