# Methods

The methods for this comparative effectiveness review (CER) follow the methods suggested in the AHRQ “Methods Guide for Effectiveness and Comparative Effectiveness Reviews”8 and the standards suggested by the Institute of Medicine for conducting systematic reviews.9

## Topic Refinement and Review Protocol

The key questions for this CER were developed with input from Key Informants, representing clinicians, wound care researchers, and patient advocates, who helped refine key questions, identify important methodological and clinical issues, and define parameters for the review of evidence. The revised key questions were then posted to the Agency for Healthcare Research and Quality (AHRQ) public Web site for a four-week comment period. AHRQ and the Evidence-based Practice Center (EPC) agreed upon the final key questions after reviewing the public comments and receiving additional input from a Technical Expert Panel (TEP) convened for this report.

The protocol for the CER was reviewed by the TEP and is available from the AHRQ Web site: (www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?productid=838&pageaction=displayproduct).

A multidisciplinary group of clinicians, researchers, and patient advocates with expertise in pressure ulcer treatment and research was selected to serve on the TEP to provide high-level content and methodological expertise throughout the development of the review. Participants included leaders in the areas of pressure ulcer treatment and research, wound care and physical therapy, and plastic and reconstructive surgery, as well as patient safety advocates and United States National Pressure Ulcer Advisory Panel (NPUAP) members.

TEP members disclosed all financial or other conflicts of interest prior to participation. The AHRQ Task Order Officer and the authors reviewed the disclosures and determined the panel members had no conflicts of interest that precluded participation.

## Search Strategy

For the primary literature we searched (through June 2012) MEDLINE (Ovid), Embase (Elsevier), CINAHL (EBSCOhost), EBM Reviews (Ovid), Cochrane Central Register of Controlled Trials, Cochrane Database of Systematic Reviews, Database of Abstracts of Reviews of Effects, and Health Technology Assessment (see Appendix A for details). The most relevant evidence about modalities and procedures currently used for treating pressure ulcers is found in studies conducted within the last 25 years. For this reason we have set the search start date at 1985. This decision was affirmed by the Key Informants and TEP. Gray literature was identified by soliciting stakeholders, TEP recommendations, and searching relevant Web sites, including clinical trial registries (ClinicalTrials.gov, Current Controlled Trials, ClinicalStudyResults.org, and the World Health Organization International Clinical Trials Registry Platform), regulatory documents (Drugs@FDA and Devices@FDA), conference proceedings and dissertations (Conference Papers Index [ProQuest CSA]), Scopus (Elsevier), Dissertations & Theses (ProQuest UMI), and individual product Web sites. An additional, focused MEDLINE search on hyperbaric oxygen for the treatment of pressure ulcers was conducted at the recommendation of the TEP due to the paucity of evidence on this subject obtained from the original search.

Scientific information packets (SIPs) were requested from identified drug and device manufacturers, and a notice inviting submission of relevant scientific information was published in the Federal Register. All interested parties had the opportunity to submit data for this review using the AHRQ Effective Health Care publicly accessible online SIP portal (http://effectivehealthcare.ahrq.gov/index.cfm/submit-scientific-information-packets/). Reviewers evaluated the SIPs received for data relevant to our review.

Additional studies were identified by reviewing the reference lists of published clinical trials, systematic reviews, and review articles.

### Inclusion and Exclusion Criteria

The criteria for inclusion and exclusion of studies were based on the key questions and the populations, interventions, comparators, outcomes, timing, and setting (PICOTS) approach. We used the following inclusion criteria (See Appendix B for details):

Populations: Studies were limited to of adults age 18 years and older being treated for existing pressure ulcers. Subgroups were defined by age, sex, race/ethnicity, socioeconomic status, and diverse specific medical comorbidities (e.g., diabetes, end-stage renal disease, and dementia), and patients with specific known risk factors for pressure ulcers (e.g., nutritional status, incontinence, peripheral vascular disease, mobility limitations, and functional ability). Studies conducted in populations including children, adolescents, and patients with nonpressure-related ulcers, including, but not limited to, venous ulcers and diabetic foot ulcers, were excluded because treatment considerations for these patients may differ significantly from those for adults with pressure ulcers.

Interventions: For efficacy and effectiveness assessments, all studies of interventions for treatment of pressure ulcers meeting the requirements of the PICOTS and key questions were included. Treatments for pressure ulcers included, but were not limited to, support surfaces, nutritional supplementation, wound dressings, topical therapies, biological agents, and surgical repair. Adjunctive therapies included electrical stimulation, electromagnetic therapy, ultrasound, negative pressure wound therapy, light therapy, laser therapy, hydrotherapy, and hyperbaric oxygen therapy.

Comparators: Comparators included usual care, placebo or sham treatment, no treatment, or different treatment interventions. Studies with no comparator were not considered in our evaluation of comparative effectiveness. They were included for the assessment of harms if they reported on harms of treatments for which data on comparative effectiveness were available in other studies.

Outcomes: Studies reporting clinical outcomes of complete wound healing, wound size (surface area, volume, depth) reduction, pain, prevention of sepsis, prevention of osteomyelitis, recurrence rate, and harms of treatment (including but not limited to pain, dermatologic complications, bleeding, and infection) were included. Studies of nonpressure-related ulcers were not included. We excluded studies that only evaluated nonclinical outcomes including ease of use, comfort, or nursing time required to administer the intervention.

Timing: No minimum followup time was required. We limited our search to publications and investigations conducted from 1985 to June 2012.

Setting: We included studies conducted in patient-care settings such as home, nursing facility, or hospitals. We excluded studies in hospice settings if complete wound healing was not an outcome measured.

Study design: We included randomized trials, cohort studies, and case-control studies pertinent to all key questions. If such studies were not available, we included cross-sectional studies and intervention series studies. Systematic reviews were used as background information or to ensure completeness of the literature search. Case studies of only one patient were not included.

For studies of surgical interventions, we initially planned to include controlled trials, observational studies with at least two comparison groups, and noncomparative intervention series only if they were multicenter series with a population of 100 patients or more. An initial scan of the literature, however, revealed that studies of surgical interventions revealed primarily small series of specific surgical techniques performed at single centers. Because surgical outcomes are heavily influenced by individual surgeons, local practice patterns, and other contextual factors, the TEP raised concern that data from these small single-site studies (n< 50) would have limited generalizability and that they would not provide a sound basis for making indirect comparisons across studies. We therefore excluded small (n<50) single-site studies reporting the results of specific surgical techniques for pressure ulcer management, but expanded our inclusion criteria to include single-center intervention series reporting a large series (n≥50) of patients undergoing surgery for pressure ulcer. We included studies of any size that provided direct, head-to-head comparisons of different surgical techniques.

According to guidance from the European Pressure Ulcer Advisory Panel (EPUAP), and suggestions of literature from our Key Informants, the most relevant evidence about modalities and procedures for treating pressure ulcers used in clinical practice today comes from investigations conducted within the past 25 years. Therefore we limited the search to 1985 to present. Guidance from the TEP indicated that current literature (1985 to present) not only captures historically significant treatments and evidence, but also provides the most current information and treatments currently used in clinical practice. Non-English language studies were included in the abstract triage, but translation for full-text review was not feasible. Gray literature including unpublished data, abstracts, dissertations, and SIPs were reviewed to determine if they added additional and meaningful data beyond the literature included in this review and should also be included.

## Study Selection

To calibrate reviewer agreement and consistency in study selection, each reviewer evaluated the same set of 200 citations for inclusion and kappa values were calculated to estimate inter-reviewer reliability. After discussing and reconciling disagreements between reviewers, the same four team members reviewed an additional 100 citations. This process was continued until a kappa value of greater than 0.50 for each pair of reviewers was reached. For the remaining references, each reviewer evaluated each title and abstract for inclusion and exclusion, using the pre-established inclusion/exclusion criteria to determine eligibility for inclusion in the evidence synthesis. To ensure accuracy, a senior investigator/clinician conducted secondary reviews of all excluded abstracts. All citations deemed appropriate for inclusion by one or both of the reviewers were retrieved for full-text review.

Full-text articles were independently reviewed by two team members. When the two team members did not agree on inclusion or exclusion of an article, they met to discuss and reach consensus, and then the article was either included or excluded accordingly.

If consensus was not reached by the two initial reviewers, a senior investigator reviewed the article and adjudicated the decision on inclusion or exclusion.

Appendix E contains a record of excluded studies with reasons for exclusion.

## Data Extraction

Data from included studies were extracted into evidence tables and entered into electronic databases using Microsoft Excel^®^ and DistillerSR systematic review software. The data extracted into evidence tables included: study design; year, setting, duration, and study inclusion and exclusion criteria; population and clinical characteristics, including sex, age, ethnicity, comorbidities, functional ability, and ulcer stage; intervention characteristics; results for each outcome of interest; and withdrawals due to adverse events. Outcomes of interest for effectiveness were wound improvement – as determined by complete wound healing, healing rate or time, or reduction in wound size (surface area, volume, depth) – reduction in pain, prevention of serious complications of infection such as sepsis or osteomyelitis, and ulcer recurrence rates. Outcomes of interest for harms were pain, dermatologic reactions, bleeding, and complications including, but not limited to, infection and need for surgical intervention. Data on settings included patient care settings such as long-term care or nursing facility, hospital, and community. If available, we also extracted the number of patients randomized relative to the number of patients enrolled, how similar those patients were to the target population, and the funding source. Noncomparative observational studies were included if they evaluated harms of treatments for which comparative effectiveness evidence was available in other studies. These noncomparative observational studies were used for Key Question 2 (evaluation of harms) and were rated for study quality but were not formally extracted into evidence tables, due to the paucity of data they contained. We recorded intention-to-treat results when available. All summary measure data were collected as available and presented in the individual studies, including, but not limited to, percentage of complete wound healing, relative risk and risk ratios, confidence intervals, and significance values. A second team member verified all study data extraction for accuracy and completeness.

One of the challenges in extracting data from pressure ulcer studies is that various systems have been used to assess the severity of pressure ulcers. Most use a four-stage categorization with higher numbers indicating higher severity.10 In 2007 NPUAP redefined their four-stage classification system that defines the pressure ulcer based on depth and tissue involvement (Figure 2). Stage I is defined as superficial erythema, stage II as partial thickness ulceration, stage III as full thickness ulceration, and stage IV as full thickness with involvement of muscle and bone. A corresponding four-stage classification system was similarly adopted by EPUAP. Given that the stages are based on depth and tissue involvement, when an ulcer has overlying purulent material or eschar prohibiting the ability to determine the depth or extent of tissue involvement, the ulcer is classified as unstageable, or stage X. Discolored localized areas of intact skin that may indicate pressure-related injury to subcutaneous tissue are categorized as suspected deep tissue injuries. A description of the most commonly used systems to classify pressure ulcers prior to adapting the NPUAP system is reviewed in Appendix C and aligned with the current corresponding NPUAP stage.

In order to allow comparability across studies, we extracted the stage or grade reported, but used the corresponding NPUAP stage in summary tables and text when possible.

## Quality Assessment of Individual Studies

In this report, risk of bias is denoted as quality, with the following summary categories:

- Good quality is defined as a low risk of bias.
- Fair quality is defined as a moderate risk of bias.
- Poor quality is defined as a high risk of bias.

We used predefined criteria to assess the quality of controlled trials and observational studies at the individual study level (Appendix F). We also adapted criteria from methods proposed by Downs and Black11,12 (observational studies) and methods developed by the U.S. Preventive Services Task Force.12,13

We rated the quality of each controlled trial based on the methods described in published reports about randomization and allocation concealment; the similarity of compared groups at baseline; maintenance of comparable groups; adequate reporting of dropouts, attrition, crossover, adherence, and contamination; loss to followup; the use of intention-to-treat analysis; and ascertainment of outcomes.12 Individual studies were rated as “good,” “fair,” or “poor” (see Appendix F). Studies rated “good” have the least risk of bias and results are considered valid. Good-quality studies include clear descriptions of the population, setting, interventions, and comparison groups; a valid method for allocation of patients to treatment; low dropout rates and clear reporting of dropouts; appropriate means for preventing bias; and appropriate measurement of outcomes.

Studies rated “fair” do not meet all the criteria for a rating of good quality, but no flaw is likely to cause major bias. The study may be missing information, making it difficult to assess limitations and potential problems. The “fair” quality category is broad, and studies with this rating vary in their strengths and weaknesses: the results of some fair-quality studies are likely to be valid, while others are only probably valid.

Studies rated “poor” have significant flaws that imply biases of various types that may invalidate the results. They have a serious or “fatal” flaw in design, analysis, or reporting; large amounts of missing information; discrepancies in reporting; or serious problems in the delivery of the intervention. The results of these studies are at least as likely to reflect flaws in the study design as they are to reflect the true differences between the interventions that were compared. We did not exclude studies rated poor quality a priori, but poor-quality studies were considered to be less valid than higher-quality studies when synthesizing the evidence, particularly when discrepancies between studies were present.

## Data Synthesis

Due to the heterogeneity of outcomes reported, variation in the comparators to which interventions were compared, and the limited number and quality of studies for specific treatment comparisons, quantitative analysis was not appropriate for most bodies of literature included in this review. For most comparisons, we synthesized data qualitatively.

We evaluated the appropriateness of meta-analysis based on clinical and methodological diversity of studies and statistical heterogeneity. We conducted meta-analysis in selected instances (when the number, quality, and homogeneity of studies permitted) for comparisons examining the outcome of complete wound healing. We chose to limit meta-analysis to the outcome of complete wound healing because of (a) wide variability in the measurement of other outcomes including wound size reduction and (b) indication from the TEP that complete wound healing was the principal health outcome of interest. When meta-analysis was conducted, we used relative risk as the effect measure. We assessed the presence of statistical heterogeneity among the studies using standard χ^2^ tests and the magnitude of heterogeneity using the I^2^ statistic.14 We used random effects models to account for variation among studies15 and fixed effects Mantel-Haenszel models when variation among studies was estimated to be zero. Sensitivity analysis was conducted to assess the impact of quality on combined estimates and meta-regression was conducted to assess the association of effect measure with study duration. However, exploration of heterogeneity was typically limited by the small number of studies for each treatment category. All quantitative analyses were performed using Stata 11.0^®^ (StataCorp, College Station, Texas, 2009)

## Strength of the Body of Evidence

Within each key question, we graded the strength of evidence for effectiveness and for harms by intervention/comparator pair, and for harms by intervention, using an approach adapted from the AHRQ “Methods Guide for Effectiveness and Comparative Effectiveness Reviews.”8 Our approach considers four major categories to rate the strength of evidence:

- Quality of studies (good, fair, or poor)
- Consistency (low, moderate, or high)
- Directness (direct or indirect)
- Precision (low, moderate, or high).

As with our ratings of individual study quality, we used the terms “quality” in lieu of “risk of bias” in rating the overall strength of evidence of a given finding. Good quality is defined as low risk of bias, fair quality is defined as moderate risk of bias, and poor quality is defined as high risk of bias. Our ratings for consistency and precision were trichotomous (low, moderate, high) rather than dichotomous (consistent vs. inconsistent, precise vs. imprecise), to allow for a more graded assessment of those domains. For the domain of “directness,” we rated evidence from head-to-head comparisons as direct. We did not incorporate the distinction between ultimate outcomes (e.g., complete wound healing) and intermediate/surrogate outcomes (e.g., wound size reduction) into our ratings for directness. We did, however, give greater weight to studies demonstrating an effect on complete wound healing, as opposed to wound size reduction, based on input from the TEP that complete wound healing represents the most clinically important outcome of interest in pressure ulcer treatment.

We did not incorporate the domain of “dose-response association” into our strength of evidence ratings because few, if any, studies in our review included varying levels of exposure. We also did not include the domain of “plausible confounding that would decrease observed effect” because this domain is relevant primarily for observational studies and nearly all of our findings were based on the results of clinical trials. We did consider “strength of association” in rating strength of evidence, but did not assign explicit scores for strength of association in our strength of evidence ratings, due to variability in strength of association for the different measures of wound improvement used across studies.

We were not able to assess publication bias using a quantitative approach for most treatments because, in many instances, we were not able to perform a formal pooled analysis due to the heterogeneity of interventions, comparators, or outcomes, or due to the poor quality of studies. We did attempt to evaluate the possibility of publication bias by qualitatively examining the directionality of study findings by sample size for a given intervention and by looking for unpublished studies through our gray literature search.

The strength of evidence was assigned an overall grade of high, moderate, low, or insufficient according to a four-level scale:

- High—High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
- Moderate—Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
- Low—Low confidence that the evidence reflects the true effect. Further research is likely to change the confidence in the estimate of effect and is likely to change the estimate.
- Insufficient— Evidence either is unavailable or does not permit a conclusion.

## Applicability

Applicability is “the extent to which the effects observed in published studies are likely to reflect the expected results when a specific intervention is applied to the population of interest under ‘real-world’ conditions.”16 Applicability depends on the particular question and the needs of the user of the review. We developed our review to provide evidence that might be useful to clinicians, policymakers, patients, and other decisionmakers interested in pressure ulcer treatment. Because it depends on context, there is no generally accepted universal rating system for applicability. We described features of the included studies that are relevant to applicability in terms of the PICOTS elements. These elements are the features embedded in the key questions that inform clinical decisionmaking and the degree to which the evidence is likely to pertain to subpopulations. For example, it is important to determine whether techniques described in studies are representative of current practice. We extracted from studies included in our review key information that might affect applicability of findings, including characteristics of ulcers (e.g., stage), populations (e.g., spinal cord injured patients), study duration, cointerventions, comparators, and care setting. We based our approach to applicability on the guidance described by Atkins and colleagues.12,16

## Peer Review

Experts in prevention and management of pressure ulcers, geriatric medicine, wound care research, and epidemiology, as well as individuals representing important stakeholder groups, were invited to provide external peer review of this CER.

The AHRQ Task Order Officer and a designated EPC associate editor also provided comments and editorial review. To obtain public comment, the draft report was posted on the AHRQ Web site for 4 weeks. A disposition-of-comments report detailing the changes made to address the public and peer review comments will be made available 3 months after the Agency posts the final CER on the AHRQ Web site.