# Peer Reviewers

- Charles Cefalu, M.D., M.S.
  Chief, Section of Geriatric Medicine
  Professor of Internal Medicine
  Director, Geriatric Medicine Program
  Medical Center of Louisiana at New Orleans
  Co-Director, Center on Aging
  New Orleans, LA
- Linda Cowan, Ph.D., A.R.N.P., FNP-BC, C.W.S.
  President, CEO
  Wound Healing Services
  Assistant Professor
  Department of Adult and Elderly Nursing
  University of Florida
  Gainesville, FL
- Mary Ann Forceia, M.D., M.P.H.
  American College of Physicians
  Clinical Associate Professor of Medicine
  Medical Director, In-Home Program
  University of Pennsylvania
  Philadelphia, PA
- Lisa Gould, M.D.
  Vice President/Secretary
  Wound Healing Society
  Staff Surgeon
  James A. Haley Veterans’ Hospital
  Department of Surgery
  Tampa, FL
- Zena Moore, Ph.D., M.Sc., FFNMRCSI, P.G. Dip., Dip. Management, R.G.N.
  Council Member
  European Wound Management Association
  Deputy to the Head of the Department
  Department of Nursing & Midwifery
  Royal College of Surgeons in Ireland
  Dublin, Ireland
- Barbara Resnick, Ph.D., C.R.N.P., FAAN, FAANP
  Professor of Nursing
  University of Maryland School of Nursing
  Adjunct Professor
  Department of Epidemiology and Preventive Medicine
  University of Maryland School of Medicine
  Baltimore, MD
- Karen M. Schoelles, M.D., S.M., FACP
  Director, ECRI Evidence-based Practice Center
  ECRI Institute
  Plymouth Meeting, PA
- Paul Takahashi, M.D.
  Associate Professor of Medicine
  Mayo Clinic College of Medicine
  Rochester, MN
- Scott Ward, P.T., Ph.D.
  Past President
  American Physical Therapy Association
  Professor and Chair
  Department of Physical Therapy
  University of Utah, College of Health
  Salt Lake City, UT
- Joie Whitney, Ph.D., R.N., C.W.C.N., FAAN
  Professor
  Associate Dean for Research
  Nurse Scientist
  Harborview Medical Center
  University of Washington
  Seattle, WA