# Technical Expert Panel

- Mary Ann Forceia, M.D., M.P.H.
  American College of Physicians
  Clinical Associate Professor of Medicine
  Medical Director, In-Home Program
  University of Pennsylvania
  Philadelphia, PA
- Linda Humphrey, M.D., M.P.H.
  American College of Physicians
  Section of General Internal Medicine
  Veterans Affairs Medical Center
  Portland, OR
- Courtney Lyder, N.D., R.N., FAAN
  Dean and Professor
  School of Nursing
  Assistant Director, UCLA Health System
  University of California, Los Angeles
  Los Angeles, CA
- Laurie McNichol, M.S.N., R.N., G.N.P., C.W.O.C.N.
  Past President
  Director
  National Pressure Ulcer Advisory Panel
  Greensboro, NC
- Jennifer Murphy, M.D.
  Assistant Professor of Surgery
  Plastic and Reconstructive Surgery
  Oregon Health & Science University
  Portland, OR
- Karen Schoelles, M.D., S.M., FACP
  Director, ECRI Evidence-based Practice Center
  ECRI Institute
  Plymouth Meeting, PA
- Scott Ward, P.T., Ph.D.
  Past President
  American Physical Therapy Association
  Professor and Chair
  Department of Physical Therapy
  University of Utah, College of Health
  Salt Lake City, UT