# Key Informants

- Mary Ann Forceia, M.D., M.P.H.
  American College of Physicians
  Clinical Associate Professor of Medicine
  Medical Director, In-Home Program
  University of Pennsylvania
  Philadelphia, PA
- Bonnie Hilburn
  Senior National Service Officer
  Paralyzed Veterans of America
  Kansas City VA Medical Center
  Kansas City, MO
- Linda Humphrey, M.D., M.P.H.
  American College of Physicians
  Section of General Internal Medicine
  Veterans Affairs Medical Center
  Portland, OR
- Diane Krasner, Ph.D., R.N., C.W.C.N., C.W.S., M.A.P.W.C.A., FAAN
  Wound & Skin Care Consultant
  Adult Nursing Coordinator
  York County School of Technology
  York, PA
- Courtney Lyder, N.D., R.N., FAAN
  Dean and Professor
  School of Nursing
  Assistant Director, UCLA Health System
  University of California, Los Angeles
  Los Angeles, CA
- Floss Mambourg, M.S., M.P.A., R.N., N.E.A.-B.C.
  Assistant Director
  Patient Centered Care
  Portland VA Medical Center
  Portland, OR
- Lana McKenzie, R.N., B.S.N., M.B.A.
  Associate Executive Director
  Medical Services & Health Policy
  Paralyzed Veterans of America
  Washington, DC
- Susan Miller, M.D.
  Lead Medical Officer
  Centers for Medicare & Medicaid Services
  Baltimore, MD
- Zena Moore, Ph.D., M.Sc., FFNMRCSI, P.G. Dip., Dip. Management, R.G.N.
  Council Member
  European Wound Management Association
  Deputy to the Head of the Department
  Department of Nursing & Midwifery
  Royal College of Surgeons in Ireland
  Dublin, Ireland
- Jennifer Murphy, M.D.
  Assistant Professor of Surgery
  Plastic and Reconstructive Surgery
  Oregon Health & Science University
  Portland, OR
- Jyme Schafer, M.D., M.P.H.
  Director
  Division of Medical & Surgical Services
  Centers for Medicare & Medicaid Services
  Baltimore, MD
- Joie Whitney, Ph.D., R.N., C.W.C.N., FAAN
  Professor
  Associate Dean for Research
  Nurse Scientist
  Harborview Medical Center
  University of Washington
  Seattle, WA