# Acknowledgments

The authors thank our colleagues at the Oregon Evidence-based Practice Center (EPC): Robin Paynter, M.L.I.S., for conducting the literature searches, and Leah Williams, B.S., Alexander Ginsburg, M.A., M.C.R.P., and Elaine Graham, M.L.S., for editorial support. We also acknowledge Maya Rowland, M.P.H., Sujata Thakurta, M.A., Bernadette Zakher, M.B.B.S., and Susan Carson, M.P.H., for assistance with data extraction and evidence table editing. We appreciate and acknowledge the contributions of the Agency for Healthcare Research and Quality Task Order Officer, Christine Chang, M.D., M.P.H., for her support and guidance in developing this report, and the EPC Program Associate Editor, Jonathan Treadwell, Ph.D., for his review of the report, advice, and meaningful comments. We also thank the Key Informants, members of the Technical Expert Panel, and Peer Reviewers. Finally, we thank our EPC directors, Jeanne-Marie Guise, M.D., M.P.H, and Mark Helfand, M.D., M.P.H., M.S., for their leadership and review of our project.