# Discussion

Treatment for pressure ulcers involves a variety of different modalities intended to: alleviate the conditions contributing to ulcer development (support surfaces, repositioning, nutritional support); protect the wound from contamination, create a clean wound environment, promote tissue healing (local wound applications, debridement, wound cleansing, and a variety of adjunctive therapies); and surgically repair the wound. We evaluated evidence addressing the comparative effectiveness and harms in treatment categories where significant uncertainty exists about the best therapeutic options: support surfaces, nutritional supplements, local wound applications (dressings, topical therapies, and biological agents), surgical interventions, and adjunctive therapies. We also attempted to discern whether the balance of benefits and harms for different treatment options varied according to characteristics of the pressure ulcer, the patient, or the setting in which care was being delivered.

## Key Findings and Strength of Evidence

We identified evidence addressing a variety of different support surfaces, including air-fluidized (AF) beds, alternating pressure (AP) beds and chair cushions, and low-air-loss (LAL) beds. Other types of support surfaces were evaluated only in small, single studies. We found evidence of moderate strength that wound improvement was better on AF beds from studies that compared AF beds to other support surfaces, including standard hospital beds. Studies found no difference in wound improvement when different types of AP mattresses were compared. (moderate strength of evidence. Evidence about the effectiveness of AP seat cushions was insufficient as only two studies with very different population were identified.) There was low-strength evidence that AP beds or LAL beds led to similar wound improvement when compared to other surfaces, usually standard mattresses. The reported harms of different support surface options were minimal, though harms were infrequently and inconsistently reported in support surface studies.

Studies of nutritional support evaluated protein-containing nutritional supplementation and specific nutrient supplementation with vitamins or minerals, such as ascorbic acid (vitamin C) or zinc. Studies provided moderate strength of evidence that protein supplementation results in wound improvement. There was low strength of evidence indicating similar results with vitamin C compared to placebo. Evidence about zinc supplementation was insufficient to draw conclusions. There was insufficient evidence to adequately describe the harms of nutritional supplementation in this patient population.

A wide variety of modern wound dressings have been compared with each other or to standard care, usually with gauze dressings. We found low-strength evidence that hydrocolloid dressings are superior to gauze and moderate-strength evidence that hydrocolloid and foam (hydrocellular or polyurethane) dressings produced similar wound improvement. Evidence about the comparative effectiveness of other dressings – hydrogels, transparent films, silicone, and alginates – was insufficient to draw conclusions. We found moderate-strength evidence from four studies that radiant heat dressings accelerated the rate of healing compared with other dressings, of stage III and IV ulcers but we did not find evidence of a benefit of radiant heat dressings in terms of complete wound healing.

The most commonly evaluated topical therapies were debriding enzymes (primarily collagenase), phenytoin solution, dextranomer paste, and collagen applications. There was low-strength evidence that dextranomer is less effective than wound dressings. Evidence about enzymes and phenytoin was inconsistent, and insufficient to draw conclusions. Collagen applications did not appear to produce wound improvement compared with standard care, based on low-strength evidence.

The most commonly evaluated biological agent was platelet-derived growth factor (PDGF), for which there was low-strength evidence of benefit compared with placebo in promoting wound improvement in severe (stage III or IV) ulcers. There was insufficient evidence about the effectiveness of other biological agents.

There was moderate-strength evidence that the most common harms of wound dressings and topical agents were dermatologic complications, including irritation, inflammation, and maceration. However, variability across studies precluded an estimate of adverse events for specific dressings or topical therapies, and evidence was insufficient to determine whether certain types of dressings or topical therapies were more likely to cause these complications than others. Few harms were reported with biological agents, but the evidence about the harms of these agents was insufficient to reach conclusions about adverse event rates. Evidence was insufficient to make conclusions about the effectiveness or harms of local wound applications across different ulcer or patient characteristics, or settings.

Surgical interventions for pressure ulcers identified in studies meeting our inclusion criteria were primarily surgical flaps, most commonly myocutaneous and fasciocutaneous flaps. Studies of surgical interventions were nearly all observational, and most were conducted in single centers. There was insufficient evidence that one approach to closure of stage III to IV pressure ulcers is superior to others due to heterogeneity in patient populations and surgical procedures. There was low strength of evidence that sacral ulcers had a lower rate of ulcer recurrence when compared with ischial ulcers; that a higher rate of recurrent ulcers was found among patients with spinal cord injury compared with others; that a greater wound dehiscence rates occurs with surgeries in which bone is removed as part of the operation; and that more adverse events occur with surgery for ischial compared with sacral or trochanteric ulcers. Surgical flap failures requiring reoperation ranged from 12 to 24 percent.

Adjunctive therapies identified in our review included electrical stimulation, electromagnetic therapy, ultrasound, negative pressure wound therapy, hydrotherapy, light therapy, and laser therapy. Evidence about other adjunctive therapies—including vibration, shock wave, and hyperbaric oxygen—was limited to small, single studies. There was moderate-strength evidence that electrical stimulation improved healing rates, but insufficient evidence about the effect of electrical stimulation on complete wound healing due to heterogeneous findings across studies. Low-strength evidence indicated that the most common adverse effect of electrical stimulation was local skin irritation; and that harms were more common in frail elderly compared with younger populations. There was also low-strength evidence indicating that electromagnetic therapy, therapeutic ultrasound, and negative pressure wound therapy were similar to sham treatment or standard care in wound improvement; there was insufficient evidence to evaluate the harms of those adjunctive therapies due to a lack of reporting of harms. Light therapy provided benefit in terms of wound area reduction but not in terms of complete wound healing, and was not associated with significant adverse events, based on low-strength evidence. There was low-strength evidence that laser therapy was not associated with significant adverse events, but also that it did not provide wound improvement over sham or standard treatment. There was insufficient evidence to draw conclusions about hydrotherapy due to the paucity of studies.

## Findings in Relationship to What Is Already Known

Treatments for Pressure Ulcers have been described and evaluated with varying degrees of rigor in the past (e.g., Lyder, 2003^4^) A recent systematic review by Reddy, and colleagues, published in December 2008, evaluated 103 randomized trials published during or prior to August 2008.^10^ The review included studies evaluating support surfaces, nutritional supplements, wound dressings, biological agents, and adjunctive therapies. Our review included evaluations of those treatment categories and additionally evaluated surgical interventions. We included observational studies of pressure ulcer treatments, included assessments of treatment harms, and expanded the search to include studies published through June 2012. and assessed treatment harms, in studies published through June 2012. Our review also included observational studies in addition to clinical trials, in an effort to more comprehensively review the relevant literature.

The findings of this prior systematic review were qualitatively similar to ours, with a few exceptions. In the support surface category, Reddy and colleagues reported that AP surfaces and low-air-loss beds were not superior to standard, nonpowered surfaces, which is similar to our findings.10 They did not, however, report specifically on AF beds, as only one of the five studies of AF beds we included in our review were retrieved in their literature search. Our finding that there was moderate-strength evidence that AF beds were more effective than other surfaces in achieving wound area reduction is based on the finding from these additional studies. Additional systematic reviews on the use of support surfaces have been published by the Cochrane Collaboration. A recent report48 updated earlier versions226–228 and separated out treatment from prevention. This review summarized 18 trials (observational studies were not included). This review, like ours, found some limited evidence that AF beds lead to reductions in pressure ulcer size, and no significant effect of LAL beds on healing. Unlike our review, this review reported some benefit from the use of sheepskins, but this is based on a study that was excluded from our review because it was published in 1964.

Finally, the authors of this review found, as we did, that the evidence base was weak, with studies that were small, had serious methodological limitations, and often did not report key elements such as variance data, p-values, and the characteristics of the surfaces used as the comparators.

Reddy and colleagues reported that overall, nutritional supplements did not provide benefit in terms of ulcer healing, but that protein supplementation may provide wound healing benefit.10 Our findings were similar; we found moderate-strength evidence that protein supplementation accelerates wound healing, but studies did not provide evidence of an effect on complete wound healing. The Cochrane Collaboration published a 2008 systematic review on nutritional interventions to treat and prevent pressure ulcers but the authors were unable to draw conclusions about the effectiveness of nutritional interventions in the treatment of pressure ulcers due to the small number and poor quality of the available studies.229

We found to wound dressings and topical therapies, indicating that there was limited evidence to support the use of certain dressings and topical therapies over others, in terms of wound improvement, were similar to the conclusions drawn by Reddy, et al.10 Our finding that hydrocolloid dressings are likely to be superior to gauze in promoting wound improvement was similar to the conclusion in two other systematic reviews. A review by Chaby, et al. also found equivalence between hydrocolloid and foam dressings in promoting wound improvement, a finding supported by our meta-analysis of 8 studies comparing those dressing types. Both Reddy, et al. and Chaby, et al. highlighted a study demonstrating the superiority of alginate dressings to dextranomer paste; we also found dextranomer paste to be inferior to dressing but considered the evidence for this to be low-strength.10 We did find moderate-strength evidence that radiant heat dressings accelerated the rate of wound area reduction, but we did not find evidence of a benefit of radiant heat dressings in terms of complete wound healing. Similar to Reddy, et al., we found a potential benefit, based on low-strength evidence, for platelet-derived growth factor in promoting wound improvement with stage III and IV ulcers.10

We found evidence to evaluate the comparative effectiveness of eight adjunctive therapies used in the treatment of pressure ulcers. Of these, none demonstrated consistent effectiveness in complete wound healing. Electrical stimulation, electromagnetic therapy, and light therapy did show a tendency for wound improvement while the other adjunctive therapies showed no evidence of effectiveness. Our findings are consistent with the findings of two prior systematic reviews of electrical stimulation for pressure ulcers,10,187 two systematic reviews of therapeutic ultrasound,10,201 one prior systematic review of negative pressure wound therapy,10 and two systematic reviews of laser therapy.10,217 Our findings of no significant difference in wound improvement with electromagnetic therapy (EMT) are consistent with those of a prior Cochrane review.161 Although a trend toward improvement in rate of healing with EMT has been observed, consistent with prior systematic reviews,10,189 we found that the clinical significance of this trend remains unknown.

## Applicability

The applicability of our findings to real-world clinical settings is supported by several features of the body of literature we reviewed. First, the populations studied included a broad representation of patients with pressure ulcers—elderly patients, general populations of patients with limited mobility, patients with spinal cord injury—cared for in a wide variety of settings, including hospitals, nursing homes, wound care clinics, and at home. Second, the interventions represented most of the therapeutic modalities commonly used in clinical settings. Comparators were also commonly used therapies and often included standard care as defined by local practice patterns. In some studies this included use of comparators that may not be considered best practices, such as standard hospital beds and plain gauze dressings. However, as these treatment strategies remain in use in many settings, both in the United States and other countries, we retained these studies in our review.

Other features of the studies we identified, however, limit the applicability of our findings. First, the outcome in many studies was wound size (area, volume, or depth) reduction, as opposed to complete wound healing. Although wound size reduction is a reasonable measure of therapeutic effect, in clinical practice the goal of therapy is almost always complete wound healing, making wound size reduction a surrogate outcome with less clinical significance than complete wound healing. A principal reason for findings of wound size reduction without complete wound healing was the short duration of most trials. Complete healing takes time. Interventions lasting only a few weeks (as was the case for most of the trials included in our review) are less likely to achieve complete wound healing than interventions carried out for periods long enough for complete healing to occur, as they would be in clinical practice. A second reason that applicability is limited is that the treatment of pressure ulcers in clinical practice often involves multiple concurrent therapies, such as support surfaces, nutritional supplementation, biological or topical therapies, and adjunctive interventions. No studies compared one combination of concurrent or sequential therapies with another, and no conclusions can be drawn regarding the effectiveness of one compared with another.

A second issue affecting applicability is that treatment of pressure ulcers is typically multimodal and often involves the sequential use of different therapies. In practice, the relevant question is often not “which therapy works best” but rather “which combination of therapies works best” and “when is a specific treatment indicated.” Most comparative studies of pressure ulcer treatments examined head-to-head comparisons of single treatment modalities. Although contextual data and cointerventions were sometimes reported, integrating those data to answer questions about treatment combinations and timing was difficult.

Studies of surgery are additionally limited by the fact that most were observational and conducted in one or, at most, a few centers. Because surgical technique and quality is often operator- and/or site-dependent, and because outcomes are influenced by local practices, staffing, and other features of the environment, it is difficult to generalize the findings of studies of surgery included in this review.

## Implications for Clinical and Policy Decisionmaking

The limitations in applicability discussed above, as well as the limitations of the evidence base discussed below, make it difficult to draw firm conclusions with implications for clinical and policy decisionmaking. Notably, we generated no findings that were supported by high strength of evidence, and only a few findings supported by moderate-strength evidence. Most findings were based on low-strength evidence, and for many issues there was insufficient evidence to draw any conclusions.

Findings supported by moderate strength of evidence deserve consideration but must be examined critically. For example, the finding that AF beds promote wound improvement compared with other surfaces might warrant consideration of this technology. However, it is important to point out that although the five studies of these beds had consistent findings, they are somewhat dated and most compared AF beds to standard beds, rather than to other specialized options. Decisions about investments in support surfaces would benefit from head-to-head trials of current technologies that measured effectiveness in terms of complete wound healing, not only reduction in wound size. Nutritional supplementation may provide benefit in terms of wound improvement, though the effects of nutritional supplementation were not dramatic, and it was not clear from the studies in our review whether nutritional supplementation was beneficial to all patients or to those with evidence of nutritional deficiencies. Nutritional support is commonly prescribed for ill or debilitated patients with evidence of malnutrition; whether this affects ulcer healing, and whether patients without evidence of malnutrition might benefit from nutritional supplementation, is not clear.

Decisions about dressings and topical applications are often guided by matching the primary functions of different dressings (e.g., absorbent, hydrating) with the primary considerations for treatment of individual ulcers (e.g., dryness, contamination risk, exudate). Given the wide array of options, comparative effectiveness and harms data have great potential to guide individualized decisionmaking. We found limited evidence, however, to provide such guidance. Overall, we did not find substantial evidence to support certain local wound applications over others. There was evidence to suggest that radiant heat improved the pace of wound healing, but not complete wound healing per se. Some biological agents showed promise for the treatment of severe ulcers, but the evidence was not substantial, and in light of the cost of these agents, more and better evidence is likely needed before they are widely adopted.

Surgery is typically reserved for refractory ulcers unlikely to heal with conservative management. Evidence about surgery is limited to mainly single-center observational studies. While we found some evidence to inform decisions and expectations about which ulcers will fare best with surgical intervention, and which surgeries are likely to produce the lowest complication rates, the influence of those findings on clinical decisionmaking should be tempered by the low quality of the studies that produced the findings, and the potentially limited generalizability of the findings across sites and surgeons.

Adjunctive therapies include therapies that are variably used in the treatment of pressure ulcers. Our review revealed moderate-strength evidence that electrical stimulation may accelerate healing but did not otherwise produce findings that would support greater use of adjunctive therapies for the goal of wound healing.

## Limitations of the Comparative Effectiveness Review Process

The most important potential limitation of our review is that important studies whose findings might influence clinical and policy decisionmaking may not have been identified. We conducted a comprehensive, broadly inclusive search that produced 7,274 study titles and abstracts. Although we excluded studies published before 1985, we do not believe that important studies of therapies used in current practice were missed; the general consistency of our findings with those of other systematic reviews, which included studies published prior to 1985, provides some assurance that our review was not biased by our time frame selection. Although we did not include foreign-language studies, we identified these studies and, based on review of their abstracts, found that none would have altered our conclusions. Our review focused on clinical outcomes of pressure ulcer treatments, particularly wound improvement. Other outcomes, such as ease of use and nursing/staff time, might also influence treatment decisions but were beyond the scope of our review. Finally, we excluded studies of the treatment of nonpressure ulcers. To the extent that evidence for interventions studied in other types of wounds, including venous ulcers, is applicable to the treatment of pressure ulcers, our review may have underestimated the quantity and quality of the body of evidence for these interventions.

There may have been biased reporting of results in the literature such that only selected studies were published and retrievable, and that published studies may have been affected by conflicts of interest. Reporting bias and conflicts of interest are concerns with any systematic review. We were not able to conduct quantitative analyses to evaluate the possibility of reporting bias for most of our findings, because the heterogeneity across studies in our review, and in many cases the lack of key information needed to perform quantitative syntheses, generally precluded meaningful comparison of effect sizes. Mitigating against the likelihood of reporting bias in our review, however, is the fact that the majority of studies in our review were small (most fewer than 100 patients, many fewer than 50), and most reported no significant effect of the intervention. Reporting bias typically results in selective publication of larger studies and/or those with positive findings, and studies biased by conflict of interests would also be more likely to report positive findings. We also conducted gray literature searches to look for unpublished data and did not find evidence of unreported studies.

We took several measures to guard against the influence of bias in our identification and evaluation of studies. Abstracts were reviewed by at least two team members, including a clinician/senior investigator. Studies were extracted based on prespecified data elements, extraction done by one team member was checked by another, and quality rating of studies performed by two team members and disagreements adjudicated by consensus. Rating of elements of strength of evidence was discussed and calibrated among team members.

## Limitations of the Evidence Base

The main limitation of the evidence base in our review was poor study quality. Most trials did not specify randomization method, did not conceal allocation, even when this might be possible, and did not mask outcomes assessment. Most studies did use intention-to-treat analyses. Most studies were small, and many were underpowered to detect significant differences. Studies were also highly variable in terms of patient populations, ulcer characteristics (e.g., anatomic site, duration, stage), interventions (even within a given intervention category, e.g., different types of foam dressings), and comparators (especially variability in implementation of standard, or usual, care), limiting our ability to combine or compare results across studies.

Another major limitation of the evidence base relates to the most common outcome measure, wound size reduction. Comparing changes in the size of pressure ulcers poses several measurement issues. For example, reduction in the size of larger and smaller pressure ulcers is hard to compare. Healing could involve “bridges” that split a large ulcer into two. Measurement in person or from tracings or photographs can be difficult, especially when measurement and photographic techniques are not standardized across studies.

Studies rarely described whether interventions were carried out as planned and in a manner conducive to maximizing potential effectiveness. Lack of documentation of treatment fidelity limited our ability to determine whether findings indicated lack of treatment effectiveness or problems with treatment implementation.

Finally, a major limitation of studies in our review was the duration of interventions and followup periods, typically a few weeks. Many pressure ulcers, especially more severe ulcers, may take months, or even years to heal. Many of the studies in our review were implemented over a period that did not necessarily allow for complete ulcer healing and therefore detection of significant differences in ulcer healing across groups. One strength in this body of literature was that most studies did use intention-to-treat analyses.

## Research Gaps

The major gaps in research identified by our review relate to the limitations of the evidence base as described above. Future studies with larger sample sizes, more rigorous adherence to methodological standards for clinical trials or observational studies, longer followup periods, standardization of comparators, and more standardized and clinically meaningful outcome measures (including more patient-centered outcomes such as quality of life and pain) are needed to inform clinical practice and policy. Inclusion of information about cointerventions, and the timing of studied interventions in relation to other interventions, would improve the applicability of study findings. Similarly, stratification of findings by patient characteristics (e.g., comorbidities, ulcer stage) would help determine the applicability of different interventions for specific patients and situations. It is particularly important for future studies to report findings according to ulcer stage, as the rate of healing, conditions necessary to promote healing, and therefore treatment choices may differ for partial and full thickness ulcers. Decisions about defining other aspects of patient populations, interventions, comparators, outcomes, study timing and duration, and study settings should be guided by clinical practice, expertise, and factors most relevant to decision makers, including patients, clinicians, and policymakers.

For several interventions, there was insufficient evidence to reach conclusions due to small sample sizes or mixed results across studies. These interventions included AP beds compared with other surfaces, topical debriding enzymes, phenytoin, and growth factors. Future studies could clarify the comparative effectiveness of these interventions and identify possible reasons for disparate results. For other interventions, findings indicated a possible benefit, but the strength of evidence was low due to study quality, duration, sample size, and measured outcomes (wound size reduction rather than complete wound healing). These interventions include platelet-derived growth factor and light therapy. Future studies are needed to confirm or refute the effectiveness of these interventions.

As mentioned, further study is warranted comparing AF beds with more modern support surfaces and evaluating comparative effectiveness in terms of complete wound healing. Similarly, in light of findings suggesting a benefit for radiant heat dressings and electrical stimulation in terms of wound healing rate, further study should compare these technologies with other treatments, with sufficient followup to evaluate complete wound healing. There was limited evidence to support the use of nutritional supplements as a component of pressure ulcer care, but few studies examined whether supplementation might have a differential effect for patients with and without baseline nutritional deficiencies. Future studies could address this issue.

Hyperbaric oxygen therapy is one clinical area that our TEP identified as high priority but for which we found limited evidence. Although studies and systematic reviews have evaluated this treatment in chronic wounds generally, its utility among patients with pressure ulcers specifically has undergone limited evaluation.

## Conclusions

Choices of treatments for pressure ulcer are often guided by product availability, local practice patterns, and individualized decisionmaking based on specific patients and the features of a given pressure ulcer. Our review did not generate many findings to guide those choices based on evidence.

We found limited evidence to draw firm conclusions about the best approaches for treating pressure ulcers. This finding is consistent with that of a prior systematic review addressing most of the same treatment categories included in our review.10 We found evidence from five studies indicating greater wound improvement with AF beds over other support surfaces, from four studies indicating a benefit of radiant heat dressings over other dressings, and from nine studies indicating a benefit of electrical stimulation. However, the benefit observed in all cases was wound size reduction or better healing rates, rather than completely healed wounds, and evidence for the benefit of support surfaces in promoting wound improvement was based primarily on comparisons of AF beds with hospital beds that may not be considered the standard of care in the field. The balance of costs and potential harms of those technologies against the benefits observed is unclear.

Studies generally did not provide evidence to support the use of one type of commonly used wound dressing over another. There was evidence that hydrocolloid and foam dressings performed similarly, but evidence for other dressing types – hydrogels, alginates, transparent films, and silicone dressings – compared with each other or with standard gauze dressings was limited. Similarly, there was low-strength or insufficient evidence to judge the balance of effectiveness and harms for nutritional supplementation, topical therapies, biological agents, surgical interventions, and adjunctive therapies other than electrical stimulation.

Advancing pressure ulcer care will require more rigorous study to solidify the evidence base for this widely used set of treatments.

Results are summarized below in Table 31.

Table 31 Summary of evidence: Pressure ulcer treatment strategies – Iimpact of pressure ulcer treatment strategies on wound improvement and harms

Key Question and Treatment Strategy | Strength of Evidence | Conclusion
Key Question 1. In adults with pressure ulcers, what is the comparative effectiveness of treatment strategies for improved health outcomes, including but not limited to: complete wound healing, healing time, reduced wound surface area, pain, and prevention of serious complications of infection?
Support
Air-fluidized beds | Moderate | Air-fluidized beds produced better healing in terms of reduction in ulcer size compared with other surfaces (5 studies conducted in the late 1980s and 1990s).
Alternating pressure beds | Moderate | Complete wound healing and reduction in ulcer size were similar across different brands and types of alternating pressure beds (4 studies).
Alternating pressure beds compared with other surfaces | Low | Wound improvement was similar for alternating pressure beds when compared with air, fluid, or standard beds (4 studies).
Alternating pressure chair cushions | Insufficient | Evidence about alternating pressure chair cushions did not permit conclusions due to differences in the patient populations studied (2 studies).
Low-air-loss beds | Low | Wound improvement was similar for low-air-loss beds compared with foam surfaces (4 studies) and for low-air-loss beds compared with low-air-loss bed overlays (1 study).
Nutrition
Protein-containing nutritional supplements | Moderate | When used in addition to other measures for treating pressure ulcers, protein-containing nutritional supplementation resulted in wound improvement (12 studies).
Vitamin C | Low | Vitamin C used as a single nutritional supplement did not result in wound improvement (1 study).
Zinc | Insufficient | The evidence did not allow conclusions as to whether zinc supplementation improves pressure ulcer healing (1 study).
Local Wound Applications
Hydrocolloid dressings compared with conventional care | Low | Wound improvement was superior with hydrocolloid compared with gauze dressings (10 studies).
Hydrocolloid compared with foam | Moderate | Wound improvement was equivalent with hydrocolloid and foam dressings (8 studies).
Comparisons of different wound dressings | Insufficient | Evidence regarding the comparative effectiveness of hydrogel (compared with standard care or other dressing types; 7 studies), transparent film (4 studies), silicone (2 studies), and alginate dressings (1 study) was inconclusive due to limitations in the number, size, and quality of studies.
Radiant heat compared with other dressings (healing rate) | Moderate | Radiant heat dressings produced more rapid wound healing rates than other dressings for stage III and IV ulcers (4 studies).
Radiant heat compared with other dressings (complete wound healing) | Moderate | Radiant heat dressings were similar to other dressings in terms of complete wound healing of stage III and IV ulcers (4 studies).
Debriding enzymes compared with dressings or other topical therapies | Insufficient | Evidence about the effectiveness of collagenase and other debriding enzymes was inconclusive due to differences in the enzymes studied and outcomes measured (5 studies).
Dextranomer paste compared with wound dressings | Low | Dextranomer paste was inferior to wound dressings (alginate, hydrogel) in promoting wound area reduction (2 studies).
Topical collagen compared with hydrocolloid dressings or standard care | Low | Wound improvement was similar with topical collagen applications compared with hydrocolloid dressings or standard care (3 studies).
Topical phenytoin | Insufficient | Three studies of the effectiveness of topical phenytoin used different comparators and produced inconsistent results.
Maggot therapy | Insufficient | Evidence about the effectiveness of maggot therapy was inconclusive due to poor study quality (3 studies).
Platelet-derived growth factor | Low | Platelet-derived growth factor was superior to placebo in producing wound improvement in stage III and IV pressure ulcers (4 studies).
Biological agents other than platelet-derived growth factor (fibroblast, nerve, and macrophage suspension) | Insufficient | Evidence about the effectiveness of other biological agents used for the treatment of pressure ulcers was inconclusive due to limitations in the number, size, and quality of studies (7 studies of various biological agents).
Surgery
Surgical techniques | Insufficient | Evidence was inconclusive as to whether one approach to closure of stage III to IV pressure ulcers was superior to others due to poor-quality studies and heterogeneity in patient populations and surgical procedures (4 studies).
Adjunctive
Electrical stimulation | Moderate | Electrical stimulation was beneficial in accelerating the rate of healing of stage II, III, and IV pressure ulcers (9 studies).
Electromagnetic therapy | Low | Wound improvement of stage II, III, or IV pressure ulcers was similar with electromagnetic therapy compared with sham treatment (4 studies).
Therapeutic ultrasound | Low | Wound improvement was similar with ultrasound compared with standard care or sham treatment (3 studies).
Negative pressure wound therapy | Low | Wound improvement was similar with negative pressure wound therapy compared with standard care (3 studies).
Hydrotherapy | Insufficient | Evidence on the effectiveness of hydrotherapy was insufficient based on 2 randomized trials evaluating different treatment modalities (1 of whirlpool therapy and 1 of pulsatile lavage).
Light therapy (complete wound healing) | Low | Light therapy was similar to sham light therapy in producing complete wound healing based on 2 randomized trials.
Light therapy (wound surface area reduction) | Low | Light therapy reduced wound surface area over time compared with standard care or sham light therapy (5 studies).
Laser therapy | Low | Wound improvement was similar with laser therapy compared with sham treatment or standard care (4 studies).
Key Question 1a. Does the comparative effectiveness of treatment strategies differ according to features of the pressure ulcers, such as anatomic site or severity at baseline?
Support
Support, all strategies | Insufficient | Only 4 studies reported results by ulcer stage or location, and the interventions, characteristics, and results varied and did not permit conclusions.
Nutrition
Nutrition, all strategies | Insufficient | Only 3 of the 16 studies analyzed results by ulcer characteristics, and the impact on the conclusion was inconsistent.
Local Wound Applications
Local wound Applications, all strategies | Insufficient | Few studies conducted subgroup analyses by ulcer characteristics (7 studies). Indirect comparisons of results across studies were limited due to heterogeneity of studies.
Surgery
Sacral compared with ischial pressure ulcers | Low | Sacral pressure ulcers had lower recurrence rates after surgery than ischial pressure ulcers (4 studies).
Adjunctive
Adjunctive, all strategies | Insufficient | Evidence did not permit determination as to whether the effectiveness of adjunctive therapies varied based on pressure ulcer characteristics due to heterogeneity of studies (6 studies).
Key Question 1b. Does the comparative effectiveness of treatment strategies differ according to patient characteristics, including but not limited to: age, race/ethnicity, body weight, specific medical comorbidities, and known risk factors for pressure ulcers, such as functional ability, nutritional status, or incontinence?
Support
Support, all strategies | Insufficient | No studies were identified that allowed conclusions about the impact of patient characteristics on the effectiveness of different support surfaces in pressure ulcer wound improvement. Indirect comparisons of results across studies were limited due to heterogeneity of studies.
Nutrition
Nutrition, all strategies | Insufficient | Evidence did not permit determination as to whether patient characteristics, including baseline nutritional status, modified the effect of nutritional support on pressure ulcer healing due to a limited number of studies reporting outcomes by baseline nutritional status (2 studies).
Local Wound Applications
Local wound applications, all strategies | Insufficient | Studies generally did not report outcomes by patient characteristics, including incontinence and mobility (1 study). Indirect comparisons of results across studies were limited due to heterogeneity of studies.
Surgery
Surgical flap closure | Low | Spinal cord–injured patients had higher rates of recurrent pressure ulcer after surgical flap closure than other patients with pressure ulcers (1 study).
Adjunctive
Electrical stimulation | Low | The effectiveness of electrical stimulation was similar in spinal-cord–injured patients compared with others (4 studies).
Electromagnetic therapy Therapeutic ultrasound Negative pressure wound therapy Light therapy Laser therapy | Insufficient | Evidence did not permit determination as to whether the effectiveness of electromagnetic therapy compared with sham electromagnetic therapy (2 studies), ultrasound therapy compared with sham ultrasound therapy, negative pressure wound therapy, light therapy, or laser therapy varied based on patient characteristics due to heterogeneity of studies and lack of reporting of specific patient characteristics.
Key Question 1c. Does the comparative effectiveness of treatment strategies differ according to patient care settings, such as home, nursing facility, or hospital, or according to features of patient care settings, including but not limited to nurse/patient staffing ratio, staff education and training in wound care, the use of wound care teams, and home caregiver support and training?
Support
Support, all strategies | Insufficient | Only 1 study provided data on results by setting and none provided information on setting characteristics. Indirect comparisons of results across studies were limited due to heterogeneity of studies.
Nutrition
Nutrition, all strategies | Insufficient | No studies reported results by patient care settings. Indirect comparisons of results across studies were limited due to heterogeneity of studies.
Local Wound Applications
Local wound applications, all strategies | Insufficient | No studies reported results by patient care settings. Indirect comparisons of results across studies were limited due to heterogeneity of studies.
Surgery
Surgery, all strategies | Insufficient | No studies reported results by patient care settings. Indirect comparisons of results across studies were limited due to heterogeneity of studies.
Adjunctive
Electrical stimulation | Low | Electrical stimulation produced similar results in a hospital compared with a rehabilitation center (9 studies).
Electromagnetic therapy Therapeutic ultrasound Negative pressure wound therapy Light therapy Laser therapy | Insufficient | Due to a lack of studies comparing different settings, evidence did not permit determination as to whether the effectiveness of electromagnetic therapy compared with sham electromagnetic therapy (2 studies), ultrasound therapy compared with sham ultrasound therapy, negative pressure wound therapy, light therapy, or laser therapy varied based on features of the patient care settings.
Key Question 2. What are the harms of treatments for pressure ulcers?
Harms: Support
Support, all strategies | Insufficient | Few of the identified studies (7 out of 24) explicitly addressed harms attributable to support surfaces. In those where harms were mentioned, most reported no significant differences in harms across the different support surfaces. However, as the harms studied were different and were associated with different support surfaces, we were unable to summarize across studies.
Harms: Nutrition
Nutrition, all strategies | Insufficient | Harms or adverse events were reported in about half of the studies (8 of 16), but the studies reported different harms, did not describe the harm, or did not specify if it was related to treatment.
Harms: Local Wound Applications
Dressings and topical therapies | Moderate | Harms reported with dressings and topical therapies for pressure ulcers most commonly included skin irritation and inflammation and tissue damage and maceration. Variability in study populations, interventions, adverse event measurement, and reporting precluded an estimate of adverse event rates for dressings and topical therapies (30 studies).
Dressings and topical therapies | Insufficient | Evidence was inconclusive as to whether specific dressing types or topical therapies were associated with fewer harms than others due to poor study quality and differential reporting of harms across studies (7 studies).
Biological agents | Insufficient | Few harms were reported with biological agents, but evidence did not permit determination of the incidence of harms due to lack of precision across studies (5 studies).
Harms: Surgery
Recurrence or flap failure | Low | Reoperation due to recurrence or flap failure ranged from 12 to 24 percent (2 studies).
Harms: Adjunctive
Electrical stimulation | Low | The most common adverse effect of electrical stimulation was local skin irritation (3 studies).
Electromagnetic therapy Therapeutic ultrasound Negative pressure wound therapy | Insufficient | Due to a lack of reporting, evidence did not permit conclusions about the harms of electromagnetic therapy (1 study), ultrasound (3 studies), or negative pressure wound therapy (2 studies).
Light therapy | Low | Light therapy caused no significant adverse events based on 4 randomized studies (4 studies).
Laser therapy | Low | Short-term use of laser therapy caused no significant adverse events based on 3 randomized studies (4 studies in all).
Key Question 2a. Do the harms of treatment strategies differ according to features of the pressure ulcers, such as anatomic site or severity at baseline?
Harms: Support
Support, all strategies | Insufficient | None of the identified studies reported if differences in harms of support surfaces varied based on features of the pressure ulcers. Indirect comparisons of harms across studies were limited due to heterogeneity of studies.
Harms: Nutrition
Nutrition, all strategies | Insufficient | No studies reported harms by ulcer characteristics. Indirect comparisons of harms across studies were limited due to heterogeneity of studies.
Harms: Local Wound Applications
Local wound applications, all strategies | Insufficient | No studies reported harms by ulcer characteristics. Indirect comparisons of harms across studies were limited due to heterogeneity of studies.
Harms: Surgery
Surgery, all strategies | Low | Wound dehiscence was more common if bone was removed at time of surgical procedure (1 study).
Ischial ulcer surgery | Low | Complication rates after surgery were higher for ischial ulcers than for sacral or trochanteric ulcers (2 studies).
Harms: Adjunctive
Adjunctive, all strategies | Insufficient | Due to a lack of reporting, there was inconclusive evidence to determine if differences in harms of any adjunctive therapies varied based on features of the pressure ulcers (3 studies of electrical stimulation).
Key Question 2b. Do the harms of treatment strategies differ according to patient characteristics, including age, race/ethnicity, body weight, specific medical comorbidities, and known risk factors for pressure ulcers, such as functional ability, nutritional status, or incontinence?
Harms: Support
Support, all strategies | Insufficient | None of the identified studies reported if differences in harms of support surfaces varied based on patient characteristics. Indirect comparisons of harms across studies were limited due to heterogeneity of studies.
Harms: Nutrition
Nutrition, all strategies | Insufficient | No studies reported harms by patient characteristics. Indirect comparisons of harms across studies were limited due to heterogeneity of studies.
Harms: Local Wound Applications
Local wound applications, all strategies | Insufficient | No studies reported harms by patient characteristics. Indirect comparisons of harms across studies were limited due to heterogeneity of studies.
Harms: Surgery
Surgery, all strategies | Insufficient | No studies reported harms by patient characteristics. Indirect comparisons of harms across studies were limited due to a lack of studies and reporting.
Harms: Adjunctive
Electrical stimulation | Low | Frail elderly patients experienced more adverse events with electrical stimulation compared with a younger population (3 studies).
Key Question 2c. Do the harms of treatment strategies differ according to patient care settings, such as home, nursing facility, or hospital, or according to features of patient care settings, including but not limited to nurse/patient staffing ratio, staff education and training in wound care, the use of wound care teams, and home caregiver support and training?
Harms: Support
Support, all strategies | Insufficient | None of the identified studies reported if differences in harms of support surfaces varied by patient care setting. Indirect comparisons of harms across studies were limited due to heterogeneity of studies.
Harms: Nutrition
Nutrition, all strategies | Insufficient | No studies reported harms by patient care setting. Indirect comparisons of harms across studies were limited due to heterogeneity of studies.
Harms: Local Wound Applications
Local wound applications, all strategies | Insufficient | No studies reported harms by patient care setting. Indirect comparisons of harms across studies were limited due to heterogeneity of studies.
Harms: Surgery
Surgery, all strategies | Insufficient | No studies reported harms by patient care setting. Indirect comparisons of harms across studies were limited due to heterogeneity of studies and surgical procedures.
Harms: Adjunctive
Adjunctive, all strategies | Insufficient | No studies reported harms by patient care setting. Indirect comparisons of harms across studies were limited due to heterogeneity of studies and a lack of studies comparing different settings.