# Evidence Tables and Overall Quality Ratings

## Evidence Table H-1 Support

Evidence Table H-1a Support trials

Evidence Table H-1b Support observational studies

## Evidence Table H-2 Support Quality Rating

Evidence Table H-2a Support trials quality rating

Evidence Table H-2b Support observational studies quality rating

## Evidence Table H-3 Nutrition

Evidence Table H-3a Nutrition trials

Evidence Table H-3b Nutrition observational studies

## Evidence Table H-4 Nutrition Quality Rating

Evidence Table H-4a Nutrition trial quality rating

Evidence Table H-4b Nutrition cohort study quality rating

## Evidence Table H-5 Local Wound Applications (Dressings, Topical Applications, and Biological Therapies)

Evidence Table H-5a Dressings trials

Evidence Table H-5b Dressings observational studies

Evidence Table H-5c Topical application trials

Evidence Table H-5d Topical application observational studies

Evidence Table H-5e Biological therapies trials and observational studies

## Evidence Table H-6 Local Wound Applications (Dressings, Topical Applications, and Biological Therapies) Quality Rating

Evidence Table H-6a Local wound applications trial quality rating

Evidence Table H-6b Local wound applications observational studies quality rating

## Evidence Table H-7 Surgery

Evidence Table H-7a Surgery Trials

## Evidence Table H-8 Surgery Quality Rating

Evidence Table H-8a Surgery trials quality rating

Evidence Table H-8b Surgery observational studies quality rating

## Evidence Table H-9 Adjunctive

Evidence Table H-9a Adjunctive trial and observational studies

## Evidence Table H-10 Adjunctive Quality Rating

Evidence Table H-10a Adjunctive trial quality rating

Evidence Table H-10b Adjunctive observational studies quality rating

## References

1 Allman RM, Walker JM, Hart MK, et al. Air-fluidized beds or conventional therapy for pressure sores. A randomized trial. Annals of Internal Medicine. Nov. 1987;107(5):641-8. [pmid: 3310792].
2 Branom R, Rappl LM. “Constant force technology” versus low-air-loss therapy in the treatment of pressure ulcers. [Erratum appears in Ostomy Wound Manage 2001 Nov;47(11):6]. Ostomy Wound Management. Sep. 2001;47(9):38-46. [pmid: 11889743].
3 Caley L, Jones S, Freer J, et al. Randomized Prospective Trial: Treatment Outcomes and Cost-Effectiveness of Two Types of Low-Air-Loss Therapy. 9th Annual Clinical Symposium on Pressure Ulcer and Wound Management. Nashville, TN. 1994. 1-2.
4 Clark M DIP. A randomised controlled trial comparing the healing of pressure sores upon two pressure-redistributing seat cushions. Proceedings of the 7th European European Conference on Advances in Wound Management. 1997.
5 Day A, Leonard F. Seeking quality care for patients with pressure ulcers. Decubitus. Jan. 1993;6(1):32-43. [pmid: 8427642].
6 Devine B. Alternating pressure air mattresses in the management of established pressure sores. Journal of Tissue Viability. 1995;5(3):94-8.
7 Evans D, Land L, Geary A. A clinical evaluation of the Nimbus 3 alternating pressure mattress replacement system. Journal of Wound Care. Apr. 2000;9(4):181-6. [pmid: 11933303].
8 Land L, Evans D, Geary A, et al. A clinical evaluation of an alternating-pressure mattress replacement system in hospital and residential care settings. Journal of Tissue Viability. Jan. 2000;10(1):6-11. [pmid: 10839090].
9 Ferrell BA, Osterweil D, Christenson P. A randomized trial of low-air-loss beds for treatment of pressure ulcers. Journal of the American Medical Association. 1993;269(4):494-7. [pmid: 8338511].
10 Groen HW, Groenier KH, Schuling J. Comparative study of a foam mattress and a water mattress. Journal of Wound Care. Jul. 1999;8(7):333-5. [pmid: 10776222].
11 Izutsu T, Matsui T, Satoh T, et al. Effect of rolling bed on decubitus in bedridden nursing home patients. Tohoku Journal of Experimental Medicine. Feb. 1998;184(2):153-7. [pmid: 9605022].
12 Jackson BS, Chagares R, Nee N, et al. The effects of a therapeutic bed on pressure ulcers: an experimental study. Journal of Enterostomal Therapy. Nov–Dec. 1988;15(6):220-6. [pmid: 3204209].
13 Keogh A, Dealey C. Profiling beds versus standard hospital beds: effects on pressure ulcer incidence outcomes. Journal of Wound Care. Feb. 2001;10(2):15-9. [pmid: 12964222].
14 Makhsous M, Lin F, Knaus E, et al. Promote pressure ulcer healing in individuals with spinal cord injury using an individualized cyclic pressure-relief protocol. Advances in Skin & Wound Care. Nov. 2009;22(11):514-21. [pmid: 20026933].
15 Malbrain M, Hendriks B, Wijnands P, et al. A pilot randomised controlled trial comparing reactive air and active alternating pressure mattresses in the prevention and treatment of pressure ulcers among medical ICU patients. Journal of Tissue Viability. Feb. 2010;19(1):7-15. [pmid: 20079647].
16 Mulder G, Taro N, Seeley J, et al. A study of pressure ulcer response to low air loss beds vs. conventional treatment. Journal of Geriatric Dermatology. 1994;2(3):87-91.
17 Munro BH, Brown L, Heitman BB. Pressure ulcers: one bed or another?. Geriatric nursing (New York, N.Y.). 1989;10(4):190-2. [pmid: 2777121].
18 Nixon J, Nelson EA, Cranny G, et al. Pressure relieving support surfaces: a randomised evaluation. Health Technology Assessment (Winchester, England). Jul. 2006;10(22):iii-iv. ix. x. 1. 163. [pmid: 16750060].
19 Rosenthal MJ, Felton RM, Nastasi AE, et al. Healing of advanced pressure ulcers by a generic total contact seat: 2 randomized comparisons with low air loss bed treatments. Archives of Physical Medicine & Rehabilitation. Dec. 2003;84(12):1733-42. [pmid: 14669176].
20 Russell L, Reynolds TM, Carr J, et al. Randomised controlled trial of two pressure-relieving systems. Journal of Wound Care. Feb. 2000;9(2):52-5. [pmid: 11933280].
21 Russell L, Reynolds T, Carr J, et al. A comparison of healing rates on two pressure-relieving systems. British Journal of Nursing. Dec 8–2001 Jan 10. 2000;9(22):2270-80. [pmid: 12271193].
22 Russell L, Reynolds TM, Towns A, et al. Randomized comparison trial of the RIK and the Nimbus 3 mattresses. British Journal of Nursing. Feb 27–Mar 12. 6. 2003;12(4):254-9. [pmid: 12671572].
23 Strauss MJ, Gong J, Gary BD, et al. The cost of home air-fluidized therapy for pressure sores. A randomized controlled trial. Journal of Family Practice. Jul. 1991;33(1):52-9. [pmid: 2056290].
24 Ochs RF, Horn SD, van Rijswijk L, et al. Comparison of air-fluidized therapy with other support surfaces used to treat pressure ulcers in nursing home residents. Ostomy Wound Management. Feb. 2005;51(2):38-68. [pmid: 15699554].
25 Valente SA, Greenough WB III, DeMarco SL, et al. More expensive surfaces are not always better. Kuwait Medical Journal. 2012;44(1):40-5.
26 Warner DJ. A clinical comparison of two pressure-reducing surfaces in the management of pressure ulcers. Decubitus. May. 1992;5(3):52-5. 8. 60. 2. 4. [pmid: 1596352].
27 Benati G, Delvecchio S, Cilla D, et al. Impact on pressure ulcer healing of an arginine-enriched nutritional solution in patients with severe cognitive impairment. Archives of Gerontology & Geriatrics - Supplement. 2001;7:43-7. [pmid: 11431045].
28 Cereda E, Gini A, Pedrolli C, et al. Disease-specific, versus standard, nutritional support for the treatment of pressure ulcers in institutionalized older adults: a randomized controlled trial. Journal of the American Geriatrics Society. Aug. 2009;57(8):1395-402. [pmid: 19563522].
29 Chernoff R. The effect of a high protein fomula (Replete) on decubitus ulcer healing in long term tube fed institutionalized patients. Journal of the American Dietetic Association. 1990;90(130).
30 Desneves KJ, Todorovic BE, Cassar A, et al. Treatment with supplementary arginine, vitamin C and zinc in patients with pressure ulcers: a randomised controlled trial. Clinical Nutrition. Dec. 2005;24(6):979-87. [pmid: 16297506].
31 Lee SK, Posthauer ME, Dorner B, et al. Pressure ulcer healing with a concentrated, fortified, collagen protein hydrolysate supplement: a randomized controlled trial. Advances in Skin & Wound Care. Mar. 2006;19(2):92-6. [pmid: 16557055].
32 Leigh B, Desneves K, Rafferty J, et al. The effect of different doses of an arginine-containing supplement on the healing of pressure ulcers. Journal of Wound Care. 2012;21(3):150-6. [pmid: 22399084].
33 Meaume S, Kerihuel JC, Constans T, et al. Efficacy and safety of ornithine alpha-ketoglutarate in heel pressure ulcers in elderly patients: results of a randomized controlled trial. Journal of Nutrition, Health & Aging. Aug. 2009;13(7):623-30. [pmid: 19621198].
34 Myers SA, Takiguchi S, Slavish S, et al. Consistent wound care and nutritional support in treatment. Decubitus. Aug. 1990;3(3):16-28. [pmid: 2119183].
35 Ohura T, Nakajo T, Okada S, et al. Evaluation of effects of nutrition intervention on healing of pressure ulcers and nutritional states (randomized controlled trial). Wound Repair & Regeneration. May–Jun. 2011;19(3):330-6. [pmid: 21539650].
36 Ter Riet G, Kessels AGH, Knipschild PG. Randomized clinical trial of ascorbic acid in the treatment of pressure ulcers. Journal of Clinical Epidemiology. 1995;48(12):1453-60. [pmid: 8543959].
37 Van Anholt RD, Sobotka L, Meijer EP, et al. An arginine- and micronutrient-enriched nutritional supplement accelerates pressure ulcer healing and reduces wound care in non-malnourished patients. EWMA Journal. 2010 49. 2010;10(2):45.
38 Barnes P Jr, Sauter TE, Zaheri S. Subnormal prealbumin levels and wound healing. Texas Medicine. Aug. 2007;103(8):65-8. [pmid: 19113064].
39 Breslow RA, Hallfrisch J, Guy DG, et al. The importance of dietary protein in healing pressure ulcers. Journal of the American Geriatrics Society. 1993;41(4):357-62. [pmid: 8463519].
40 Brewer S, Desneves K, Pearce L, et al. Effect of an arginine-containing nutritional supplement on pressure ulcer healing in community spinal patients. Journal of Wound Care. Jul. 2010;19(7):311-6. [pmid: 20616774].
41 Houston S, Haggard J, Williford J Jr, et al. Adverse effects of large-dose zinc supplementation in an institutionalized older population with pressure ulcers [4]. Journal of the American Geriatrics Society. 2001;49(8):1130-2. [pmid: 11555083].
42 Yamamoto T, Fujioka M, Kitamura R, et al. Evaluation of nutrition in the healing of pressure ulcers: are the EPUAP nutritional guidelines sufficient to heal wounds. European Pressure Ulcer Advisory Panel. Wounds: A Compendium of Clinical Research & Practice. 2009;21(6):153-7.
43 Alm A, Hornmark AM, Fall PA, et al. Care of pressure sores: a controlled study of the use of a hydrocolloid dressing compared with wet saline gauze compresses. Acta Dermato-Venereologica Supplementum. 1989;149:1-10. [pmid: 2694713].
44 Bale S, Squires D, Varnon T, et al. A comparison of two dressings in pressure sore management. Journal of Wound Care. Nov. 1997;6(10):463-6. [pmid: 9455271].
45 Bale S, Hagelstein S, Banks V, et al. Costs of dressings in the community. Journal of Wound Care. Jul. 1998;7(7):327-30. [pmid: 9791356].
46 Bale S, Banks V, Haglestein S, et al. A comparison of two amorphous hydrogels in the debridement of pressure sores. Journal of Wound Care. Feb. 1998;7(2):65-8. [pmid: 9543975].
47 Banks V, Bale SE, Harding KG. Comparing two dressings for exuding pressure sores in community patients. Journal of Wound Care. 1994;3(4):175-8.
48 Banks V, Bale S, Harding K. The use of two dressings for moderately exuding pressure sores. Journal of Wound Care. 1994;3(3):132-4.
49 Belmin J, Meaume S, Rabus M-T, et al. Sequential treatment with calcium alginate dressings and hydrocolloid dressings accelerates pressure ulcer healing in older subjects: a multicenter randomized trial of sequential versus nonsequential treatment with hydrocolloid dressings alone. Journal of the American Geriatrics Society. Feb. 2002;50(2):269-74. [pmid: 12028208].
50 Bito S, Mizuhara A, Oonishi S, et al. Randomised controlled trial evaluating the efficacy of wrap therapy for wound healing acceleration in patients with NPUAP stage II and III pressure ulcer. BMJ Open. 2012;2:e000371. [pmid: 22223842].
51 Brod M, McHenry E, Plasse TF, et al. A randomized comparison of poly-hema and hydrocolloid dressings for treatment of pressure sores. Archives of Dermatology. Jul. 1990;126(7):969-70. [pmid: 2193631].
52 Brown-Etris M, Milne C, Orsted H, et al. A prospective, randomized, multisite clinical evaluation of a transparent absorbent acrylic dressing and a hydrocolloid dressing in the management of Stage II and shallow Stage III pressure ulcers. Advances in Skin & Wound Care. Apr. 2008;21(4):169-74. [pmid: 18385577].
53 Chang KW, Alsagoff S, Ong KT, et al. Pressure ulcers--randomised controlled trial comparing hydrocolloid and saline gauze dressings. Medical Journal of Malaysia. Dec. 1998;53(4):428-31. [pmid: 10971989].
54 Chuangsuwanich A, Charnsanti O, Lohsiriwat V, et al. The efficacy of silver mesh dressing compared with silver sulfadiazine cream for the treatment of pressure ulcers. Journal of the Medical Association of Thailand. May. 2011;94(5):559-65. [pmid: 21675444].
55 Colin D, Kurring PA, Yvon C. Managing sloughy pressure sores. Journal of Wound Care. Nov. 1996;5(10):444-6. [pmid: 9117814].
56 Colwell JC, Foreman MD, Trotter JP. A comparison of the efficacy and cost-effectiveness of two methods of managing pressure ulcers. Decubitus. Jul. 1993;6(4):28-36. [pmid: 8297488].
57 Darkovich SL, Brown-Etris M, Spencer M. Biofilm hydrogel dressing: a clinical evaluation in the treatment of pressure sores. Ostomy Wound Management. Jul–Aug. 1990;29:47-60. [pmid: 2202317].
58 Day A, Dombranski S, Farkas C, et al. Managing sacral pressure ulcers with hydrocolloid dressings: results of a controlled, clinical study. Ostomy Wound Management. Mar. 1995;41(2):52-4. 6. 8 passim. [pmid: 7598778].
59 Gorse GJ, Messner RL. Improved pressure sore healing with hydrocolloid dressings. Archives of Dermatology. Jun. 1987;123(6):766-71. [pmid: 3555355].
60 Honde C, Derks C, Tudor D. Local treatment of pressure sores in the elderly: amino acid copolymer membrane versus hydrocolloid dressing. Journal of the American Geriatrics Society. Nov. 1994;42(11):1180-3. [pmid: 7525682].
61 Kaya AZ, Turani N, Akyuz M. The effectiveness of a hydrogel dressing compared with standard management of pressure ulcers. Journal of Wound Care. Jan. 2005;14(1):42-4. [pmid: 15656468].
62 Kerihuel JC. Effect of activated charcoal dressings on healing outcomes of chronic wounds. Journal of Wound Care. May. 10. 2010;19(5):208-2. 14. 5. [pmid: 20505594].
63 Kim YC, Shin JC, Park CI, et al. Efficacy of hydrocolloid occlusive dressing technique in decubitus ulcer treatment: a comparative study. Yonsei Medical Journal. Jun. 1996;37(3):181-5. [pmid: 8826783].
64 Kloth LC, Berman JE, Nett M, et al. A randomized controlled clinical trial to evaluate the effects of noncontact normothermic wound therapy on chronic full-thickness pressure ulcers. Advances in Skin & Wound Care. Nov–Dec. 2002;15(6):270-6. [pmid: 12477979].
65 Kraft MR, Lawson L, Pohlmann B, et al. A comparison of Epi-Lock and saline dressings in the treatment of pressure ulcers. Decubitus. Nov. 1993;6(6):42-4. 6. 8. [pmid: 8286026].
66 Kurzuk-Howard G, Simpson L, Palmieri A. Decubitus ulcer care: a comparative study. Western Journal of Nursing Research. Feb. 1985;7(1):58-79. [pmid: 3850687].
67 Matzen S, Peschardt A, Alsbjorn B. A new amorphous hydrocolloid for the treatment of pressure sores: a randomised controlled study. Scandinavian Journal of Plastic & Reconstructive Surgery & Hand Surgery. Mar. 1999;33(1):13-5. [pmid: 10207960].
68 Meaume S, Vallet D, Morere MN, et al. Evaluation of a silver-releasing hydroalginate dressing in chronic wounds with signs of local infection. [Erratum appears in J Wound Care. 2005 Nov;14(10):479]. Journal of Wound Care. Oct. 2005;14(9):411-9. [pmid: 16240620].
69 Meaume S, Van De Looverbosch D, Heyman H, et al. A study to compare a new self-adherent soft silicone dressing with a self-adherent polymer dressing in stage II pressure ulcers. Ostomy Wound Management. Sep. 2003;49(9):44-51. [pmid: 14581709].
70 Motta G, Dunham L, Dye T, et al. Clinical efficacy and cost-effectiveness of a new synthetic polymer sheet wound dressing. Ostomy Wound Management. Oct. 4. 1999;45(10):41-6. 8. 9. [pmid: 10687651].
71 Mulder GD, Altman M, Seeley JE, et al. Prospective randomized study of the efficacy of hydrogel, hydrocolloid, and saline solution -- moistened dressings on the management of pressure ulcers. Wound Repair & Regeneration. 1993;1(4):213-8. [pmid: 17166097].
72 Neill K, Conforti C, Kedas A, et al. Pressure sore response to a new hydrocolloid dressing. Wounds: A Compendium of Clinical Research & Practice. 1989;1:173-85.
73 Oleske DM, Smith XP, White P, et al. A randomized clinical trial of two dressing methods for the treatment of low-grade pressure ulcers. Journal of Enterostomal Therapy. May–Jun. 1986;13(3):90-8. [pmid: 3519718].
74 Payne WG, Posnett J, Alvarez O, et al. A prospective, randomized clinical trial to assess the cost-effectiveness of a modern foam dressing versus a traditional saline gauze dressing in the treatment of stage II pressure ulcers. Ostomy Wound Management. Feb. 2009;55(2):50-5. [pmid: 19246785].
75 Price P, Bale S, Crook H, et al. The effect of a radiant heat dressing on pressure ulcers. Journal of Wound Care. Apr. 2000;9(4):201-5. [pmid: 11933306].
76 Sebern MD. Pressure ulcer management in home health care: efficacy and cost effectiveness of moisture vapor permeable dressing. Archives of Physical Medicine & Rehabilitation. Oct. 1986;67(10):726-9. [pmid: 3533007].
77 Sebern MD. Cost and efficacy of pressure ulcer management in a metropolitan visiting nurse association. Decubitus. Aug. 1989;2(3):58-9. [pmid: 2775474].
78 Seeley J, Jensen JL, Hutcherson J. A randomized clinical study comparing a hydrocellular dressing to a hydrocolloid dressing in the management of pressure ulcers. Ostomy Wound Management. Jun. 1999;45(6):39-44. 6. 7. [pmid: 10655861].
79 Small N, Mulder M, Mackenzie MJ, et al. A comparative analysis of pressure sore treatment modalities in community settings. Curationis. Feb. 2002;25(1):74-82. [pmid: 12096575].
80 Thomas S, Banks V, Bale S, et al. A comparison of two dressings in the management of chronic wounds. Journal of Wound Care. Sep. 1997;6(8):383-6. [pmid: 9341430].
81 Thomas DR, Goode PS, LaMaster K, et al. Acemannan hydrogel dressing versus saline dressing for pressure ulcers. A randomized, controlled trial. Advances in Wound Care. Oct. 1998;11(6):273-6. [pmid: 10326343].
82 Thomas DR, Diebold MR, Eggemeyer LM. A controlled, randomized, comparative study of a radiant heat bandage on the healing of stage 3–4 pressure ulcers: a pilot study. Journal of the American Medical Directors Association. Jan–Feb. 2005;6(1):46-9. [pmid: 15871870].
83 Whitney JD, Salvadalena G, Higa L, et al. Treatment of pressure ulcers with noncontact normothermic wound therapy: healing and warming effects. Journal of Wound, Ostomy, & Continence Nursing. Sep. 2001;28(5):244-52. [pmid: 11557928].
84 Winter A, Hewitt H. Testing a hydrocolloid. Nursing Times. Dec. 12–8. 1990;86(50):59-62. [pmid: 2255648].
85 Xakellis. Hydrocolloid versus saline-gauze dressings in treating pressure ulcers: a cost-effectiveness analysis. Arch Phys Med Rehabil. 1992;73:463-9. [pmid: 1580775].
86 Yapucu Gunes U, Eser I. Effectiveness of a honey dressing for healing pressure ulcers. Journal of Wound, Ostomy, & Continence Nursing. Mar–Apr. 2007;34(2):184-90. [pmid: 17413836].
87 Yastrub DJ. Relationship between type of treatment and degree of wound healing among institutionalized geriatric patients with stage II pressure ulcers... reprinted with permission from the author and Nurse Practitioner Associates for Continuing Education. Care Management Journals. 2004;5(4):213-8. [pmid: 16294574].
88 Meaume S, Ourabah Z, Charru P, et al. Optimizing wound care with a new lipido-colloid dressing (Urgotul Duo). British Journal of Nursing. Mar 22–Apr 11. 2007;16(6):S4. S6. S8 passim. [pmid: 17505400].
89 Moody M. Calcium alginate: a dressing trial. Nursing Standard. 1991;5(50):3-6. [pmid: 1911033].
90 Parnell LKS, Ciufi B, Gokoo CF. Preliminary use of a hydrogel containing enzymes in the treatment of stage II and stage III pressure ulcers. Ostomy Wound Management. Aug. 2005;51(8):50-60. [pmid: 16234576].
91 Stoker FM. A major contributor. Evaluation of Comfeel Pressure Relieving Dressing. Professional Nurse. Sep. 1990;5(12):644-53. [pmid: 2217219].
92 Viamontes L, Temple D, Wytall D, et al. An evaluation of an adhesive hydrocellular foam dressing and a self-adherent soft silicone foam dressing in a nursing home setting. Ostomy Wound Management. Aug. 2003;49(8):48-52. 4. 6. 8. [pmid: 14631663].
93 Agren MS, Stromberg HE. Topical treatment of pressure ulcers. A randomized comparative trial of Varidase and zinc oxide. Scandinavian Journal of Plastic & Reconstructive Surgery. 1985;19(1):97-100. [pmid: 3895409].
94 Alvarez OM, Fernandez-Obregon A, Rogers RS, et al. Chemical debridement of pressure ulcers: a prospective, randomized, comparative trial of collagenase and papain/urea formulations. Wounds: A Compendium of Clinical Research & Practice. 2000;12(2):15-25.
95 Burgos A, Gimenez J, Moreno E, et al. Collagenase ointment application at 24- versus 48-hour intervals in the treatment of pressure ulcers. A randomised multicentre study. Clinical Drug Investigation. 2000;19(6):399-407.
96 Burgos A, Gimenez J, Moreno E, et al. Cost, efficacy, efficiency and tolerability of collagenase ointment versus hydrocolloid occlusive dressing in the treatment of pressure ulcers. A comparative, randomised, multicentre study. Clinical Drug Investigation. 2000;19(5):357-65.
97 Felzani G, Spoletini I, Convento A, et al. Effect of lysine hyaluronate on the healing of decubitus ulcers in rehabilitation patients. Advances in Therapy. May. 2011;28(5):439-45. [pmid: 21499725].
98 Gerding GA, Browning JS. Oxyquinoline-containing ointment vs. standard therapy for stage I and stage II skin lesions. Dermatology Nursing. Oct. 1992;4(5):389-98. [pmid: 1482629].
99 Graumlich JF, Blough LS, McLaughlin RG, et al. Healing pressure ulcers with collagen or hydrocolloid: A randomized, controlled trial. Journal of the American Geriatrics Society. 2003;51(2):147-54. [pmid: 12558709].
100 Guthrie M, Diakiw J, Zaydon AC, et al. A randomized double-blind clinical study of dermagran dual therapeutic system in the treatment of decubitus ulcers. Wounds: A Compendium of Clinical Research and Practice. 1989;1(3):142-54.
101 Hollisaz MT, Khedmat H, Yari F. A randomized clinical trial comparing hydrocolloid, phenytoin and simple dressings for the treatment of pressure ulcers [ISRCTN33429693]. BMC Dermatology. 2004;4(1):18. [pmid: 15601464].
102 Hsu YC, Chang HH, Chen MF, et al. Therapeutic effect of sheng-ji-san on pressure ulcers. American Journal of Chinese Medicine. 2000;28(3–4):391-9. [pmid: 11154053].
103 Kuflik A, Stillo JV, Sanders D, et al. Petrolatum versus Resurfix ointment in the treatment of pressure ulcers. Ostomy Wound Management. Feb. 2001;47(2):52-6. [pmid: 11235499].
104 LeVasseur SA, Helme RD. A double-blind clinical trial to compare the efficacy of an active based cream F14001 against a placebo non-active based cream for the treatment of pressure ulcers in a population of elderly subjects. Journal of Advanced Nursing. Aug. 1991;16(8):952-6. [pmid: 1779084].
105 Muller E, van Leen MW, Bergemann R. Economic evaluation of collagenase-containing ointment and hydrocolloid dressing in the treatment of pressure ulcers. Pharmacoeconomics. 2001;19(12):1209-16. [pmid: 11772156].
106 Nisi G, Brandi C, Grimaldi L, et al. Use of a protease-modulating matrix in the treatment of pressure sores. Chirurgia Italiana. Jul–Aug. 2005;57(4):465-8. [pmid: 16060184].
107 Pullen R, Popp R, Volkers P, et al. Prospective randomized double-blind study of the wound-debriding effects of collagenase and fibrinolysin/deoxyribonuclease in pressure ulcers. Age & Ageing. Mar. 2002;31(2):126-30. [pmid: 11937475].
108 Rhodes RS, Heyneman CA, Culbertson VL, et al. Topical phenytoin treatment of stage II decubitus ulcers in the elderly. Annals of Pharmacotherapy. Jun. 2001;35(6):675-81. [pmid: 11408983].
109 Sayag J, Meaume S, Bohbot S. Healing properties of calcium alginate dressings. Journal of Wound Care. Sep. 1996;5(8):357-62. [pmid: 8954425].
110 Shamimi Nouri K, Karimian R, Nasli E, et al. Topical application of Semelil (ANGIPARS(trademark)) in treatment of pressure ulcers: A randomized clinical trial. Daru. 2008;16(SUPPL 1):54-7.
111 Sipponen A, Jokinen JJ, Sipponen P, et al. Beneficial effect of resin salve in treatment of severe pressure ulcers: a prospective, randomized and controlled multicentre trial. British Journal of Dermatology. May. 2008;158(5):1055-62. [pmid: 18284391].
112 Subbanna PK, Margaret Shanti FX, George J, et al. Topical phenytoin solution for treating pressure ulcers: a prospective, randomized, double-blind clinical trial. Spinal Cord. Nov. 2007;45(11):739-43. [pmid: 17279096].
113 Tytgat H, Van Asch H. Topical ketanserin in the treatment of decubitus ulcers: A double-blind study with 2% ketanserin ointment against placebo. Advances in Therapy. 1988;5(4):143-52.
114 Zeron HM, Krotzsch Gomez FE, Munoz REH. Pressure ulcers: a pilot study for treatment with collagen polyvinylpyrrolidone. International Journal of Dermatology. Mar. 2007;46(3):314-7. [pmid: 17343594].
115 Harding KG, Bale S, Stock J, et al. A multi-center comparison of a hydrocellular adhesive dressing and a hydrocolloid dressing in the management of stage II and III pressure ulcers. 9th Annual Symposium on Advanced Wound Care and 6th Annual Medical Research Forum on Wound Repair. 1996.
116 Hindryckx P, De Cuyper C, Hendrickx B, et al. The treatment of infected decubitus ulcers with 1% silver sulfadiazine cream. Current Therapeutic Research - Clinical and Experimental. 1990;48(3):535-9.
117 Narayanan S, Van Vleet J, Strunk B, et al. Comparison of pressure ulcer treatments in long-term care facilities: clinical outcomes and impact on cost. Journal of Wound, Ostomy, & Continence Nursing. May–Jun. 2005;32(3):163-70. [pmid: 15931146].
118 Sherman RA, Wyle F, Vulpe M. Maggot therapy for treating pressure ulcers in spinal cord injury patients. Journal of Spinal Cord Medicine. Apr. 1995;18(2):71-4. [pmid: 7640976].
119 Sherman RA. Maggot versus conservative debridement therapy for the treatment of pressure ulcers. Wound Repair & Regeneration. Jul–Aug. 2002;10(4):208-14. [pmid: 12191002].
120 Wang S-y, Wang J-n, Lv D-c, et al. Clinical research on the bio-debridement effect of maggot therapy for treatment of chronically infected lesions. Orthopaedic Audio-Synopsis Continuing Medical Education [Sound Recording]. 2010;2(3):201-6. [pmid: 22009949].
121 Danon D, Madjar J, Edinov E, et al. Treatment of human ulcers by application of macrophages prepared from a blood unit. Experimental Gerontology. Nov–Dec. 1997;32(6):633-41. [pmid: 9785089].
122 Hirshberg J, Coleman J, Marchant B, et al. TGF-beta3 in the treatment of pressure ulcers: a preliminary report. Advances in Skin & Wound Care. Mar–Apr. 2001;14(2):91-5. [pmid: 11899912].
123 Landi F, Aloe L, Russo A, et al. Topical treatment of pressure ulcers with nerve growth factor: a randomized clinical trial. Annals of Internal Medicine. Oct. 21. 2003;139(8):635-41. [pmid: 14568851].
124 Mustoe TA, Cutler NR, Allman RM, et al. A phase II study to evaluate recombinant platelet-derived growth factor-BB in the treatment of stage 3 and 4 pressure ulcers. Archives of Surgery. Feb. 1994;129(2):213-9. [pmid: 8304833].
125 Payne WG, Ochs DE, Meltzer DD, et al. Long-term outcome study of growth factor-treated pressure ulcers. American Journal of Surgery. Jan. 2001;181(1):81-6. [pmid: 11248182].
126 Payne WG, Wright TE, Ochs D, et al. An exploratory study of dermal replacement therapy in the treatment of stage III pressure ulcers. Journal of Applied Research. 2004;4(1):12-23.
127 Rees RS, Robson MC, Smiell JM, et al. Becaplermin gel in the treatment of pressure ulcers: a phase II randomized, double-blind, placebo-controlled study. Wound Repair & Regeneration. May–Jun. 1999;7(3):141-7. [pmid: 10417749].
128 Robson MC, Phillips LG, Thomason A, et al. Platelet-derived growth factor BB for the treatment of chronic pressure ulcers. Lancet. Jan. 4. 1992;339(8784):23-5. [pmid: 1345953].
129 Robson MC, Phillips LG, Thomason A, et al. Recombinant human platelet-derived growth factor-BB for the treatment of chronic pressure ulcers. Annals of Plastic Surgery. 1992;29(3):193-201. [pmid: 1524367].
130 Robson LE. Safety and effect of topical recombinant human interleukin-1beta in the management of pressure sores. Wound Repair & Regeneration. Jul. 1994;2(3):177-81. [pmid: 17156109].
131 Robson MC, Hill DP, Smith PD, et al. Sequential cytokine therapy for pressure ulcers: clinical and mechanistic response. Annals of Surgery. Apr. 2000;231(4):600-11. [pmid: 10749622].
132 Robson MC, Phillips LG, Lawrence WT, et al. The safety and effect of topically applied recombinant basic fibroblast growth factor on the healing of chronic pressure sores. Annals of Surgery. Oct. 1992;216(4):401-6. discussion 6–8. [pmid: 1417189].
133 Scevola S, Nicoletti G, Brenta F, et al. Allogenic platelet gel in the treatment of pressure sores: a pilot study. International Wound Journal. Jun. 2010;7(3):184-90. [pmid: 20455960].
134 Zuloff-Shani A, Adunsky A, Even-Zahav A, et al. Hard to heal pressure ulcers (stage III–IV): efficacy of injected activated macrophage suspension (AMS) as compared with standard of care (SOC) treatment controlled trial. Archives of Gerontology & Geriatrics. Nov–Dec. 2010;51(3):268-72. [pmid: 20034682].
135 Juri H, Palma JA. CO2 laser in decubitus ulcers: a comparative study. Lasers in Surgery & Medicine. 1987;7(4):296-9. [pmid: 3683061].
136 Foster RD, Anthony JP, Mathes SJ, et al. Flap selection as a determinant of success in pressure sore coverage. Archives of Surgery. Aug. 1997;132(8):868-73. [pmid: 9267271].
137 Foster RD, Anthony JP, Mathes SJ, et al. Ischial pressure sore coverage: A rationale for flap selection. British Journal of Plastic Surgery. 1997;50(5):374-9. [pmid: 9245873].
138 Kierney PC, Engrav LH, Isik FF, et al. Results of 268 pressure sores in 158 patients managed jointly by plastic surgery and rehabilitation medicine. Plastic & Reconstructive Surgery. Sep. 1998;102(3):765-72. [pmid: 9727442].
139 Schryvers OI, Stranc MF, Nance PW. Surgical treatment of pressure ulcers: 20-year experience. Archives of Physical Medicine & Rehabilitation. Dec. 2000;81(12):1556-62. [pmid: 11128889].
140 Yamamoto Y, Tsutsumida A, Murazumi M, et al. Long-term outcome of pressure sores treated with flap coverage. Plastic & Reconstructive Surgery. Oct. 1997;100(5):1212-7. [pmid: 9326782].
141 Adegoke BO, Badmos KA. Acceleration of pressure ulcer healing in spinal cord injured patients using interrupted direct current. African Journal of Medicine & Medical Sciences. Sep. 2001;30(3):195-7. [pmid: 14510128].
142 Adunsky A, Ohry A, Group D. Decubitus direct current treatment (DDCT) of pressure ulcers: results of a randomized double-blinded placebo controlled study. Archives of Gerontology & Geriatrics. Nov–Dec. 2005;41(3):261-9. [pmid: 15998547].
143 Ahmad ET. High voltage pulsed galvanic stimulation: effect of treatment durations on healing of chronic pressure ulcers. Indian Journal of Physiotherapy & Occupational Therapy. 2008;2(3):1-5. [pmid: 21991123].
144 Ahmad ET. High-voltage pulsed galvanic stimulation: effect of treatment duration on healing of chronic pressure ulcers. Annals of Burns & Fire Disasters. 2008;21(3):124-8. [pmid: 21991123].
145 Baker LL, Rubayi S, Villar F, et al. Effect of electrical stimulation waveform on healing of ulcers in human beings with spinal cord injury. Wound Repair & Regeneration. Jan–Mar. 1996;4(1):21-8. [pmid: 17129344].
146 Burke DT, Ho CHK, Saucier MA, et al. Effects of hydrotherapy on pressure ulcer healing. American Journal of Physical Medicine and Rehabilitation. 1998;77(5):394-8. [pmid: 9798830].
147 Comorosan S, Vasilco R, Arghiropol M, et al. The effect of diapulse therapy on the healing of decubitus ulcer. Romanian Journal of Physiology (Bucuresti). Jan–Jun. 1993;30(1–2):41-5. [pmid: 7982015].
148 Dehlin O, Elmstahl S, Gottrup F. Monochromatic phototherapy in elderly patients: a new way of treating chronic pressure ulcers?. [Erratum appears in Aging Clin Exp Res. 2003 Dec;15(6):519]. Aging-Clinical & Experimental Research. Jun. 2003;15(3):259-63. [pmid: 14582689].
149 Dehlin O, Elmstahl S, Gottrup F. Monochromatic phototherapy: effective treatment for grade II chronic pressure ulcers in elderly patients. Aging-Clinical & Experimental Research. Dec. 2007;19(6):478-83. [pmid: 18172370].
150 Durovic A, Maric D, Brdareski Z, et al. The effects of polarized light therapy in pressure ulcer healing. Vojnosanitetski Pregled. Dec. 2008;65(12):906-12. [pmid: 19160985].
151 Ford CN, Reinhard ER, Yeh D, et al. Interim analysis of a prospective, randomized trial of vacuum-assisted closure versus the healthpoint system in the management of pressure ulcers. Annals of Plastic Surgery. Jul. 2002;49(1):55-61. discussion. [pmid: 12142596].
152 Gentzkow GD, Pollack VP, Kloth LC, et al. Improved healing of pressure ulcers using Dermapulse, a new electrical stimulation device. Wounds: A Compendium of Clinical Research and Practice. 1991;3(5):158-70.
153 Griffin JW, Tooms RE, Mendius RA, et al. Efficacy of high voltage pulsed current for healing of pressure ulcers in patients with spinal cord injury. Physical Therapy. Jun. 1991;71(6):433-42. discussion 42–4. [pmid: 2034707].
154 Gupta A, Taly AB, Srivastava A, et al. Efficacy of pulsed electromagnetic field therapy in healing of pressure ulcers: A randomized control trial. Neurology India. Sep–Oct. 2009;57(5):622-6. [pmid: 19934563].
155 Ho CH, Powell HL, Collins JF, et al. Poor nutrition is a relative contraindication to negative pressure wound therapy for pressure ulcers: preliminary observations in patients with spinal cord injury. Advances in Skin & Wound Care. Nov. 2010;23(11):508-16. [pmid: 20975334].
156 Ho CH, Bensitel T, Wang X, et al. Pulsatile lavage for the enhancement of pressure ulcer healing: a randomized controlled trial. Physical Therapy. 2012;92(1):38-48. [pmid: 21949432].
157 Houghton PE, Campbell KE, Fraser CH, et al. Electrical stimulation therapy increases rate of healing of pressure ulcers in community-dwelling people with spinal cord injury. Archives of Physical Medicine & Rehabilitation. May. 2010;91(5):669-78. [pmid: 20434602].
158 Iordanou P, Baltopoulos G, Giannakopoulou M, et al. Effect of polarized light in the healing process of pressure ulcers. [Erratum appears in Int J Nurs Pract 2002 Apr;8(2):116]. International Journal of Nursing Practice. Feb. 2002;8(1):49-55. [pmid: 11831427].
159 Kloth LC, Feedar JA. Acceleration of wound healing with high voltage, monophasic, pulsed current. [Erratum appears in Phys Ther 1989 Aug;69(8):702]. Physical Therapy. Apr. 1988;68(4):503-8. [pmid: 3258429].
160 Lucas C, van Gemert MJC, de Haan RJ. Efficacy of low-level laser therapy in the management of stage III decubitus ulcers: a prospective, observer-blinded multicentre randomised clinical trial. Lasers in Medical Science. 2003;18(2):72-7. [pmid: 12928815].
161 Lucas C, Coenen CHM, De Haan RJ. The effect of low level laser therapy (LLLT) on stage III decubitus ulcers (pressure sores); A prospective randomised single blind, multicentre pilot study. Lasers in Medical Science. 2000;15(2):94-100. [pmid: 12928815].
162 Maeshige N, Fujiwara H, Honda H, et al. Evaluation of the combined use of ultrasound irradiation and wound dressing on pressure ulcers. Journal of Wound Care. Feb. 2010;19(2):63-8. [pmid: 20216490].
163 McDiarmid T, Burns PN, Lewith GT, et al. Ultrasound and the treatment of pressure sores. Physiotherapy. 1985;71(2):66-70.
164 Nussbaum EL, Biemann I, Mustard B. Comparison of ultrasound/ultraviolet-C and laser for treatment of pressure ulcers in patients with spinal cord injury. Physical Therapy. Sep. 1994;74(9):812-23. discussion 24–5. [pmid: 8066108].
165 Onigbinde AT, Olafimihan KF, Ojoawo A, et al. The effect of ultraviolet radiation (type B) on decubitus ulcers. Internet Journal of Allied Health Sciences & Practice. 2010;8(1):1-6.
166 Ozdemir F, Kasapoglu M, Oymak F, et al. Efficiency of magnetic field treatment on pressure sores in bedridden patients. Balkan Medical Journal. 2011;28(3):274-8.
167 Salzberg CA, Cooper-Vastola SA, Perez FJ, et al. The effects of non-thermal pulsed electromagnetic energy (DIAPULSE) on wound healing of pressure ulcers in spinal cord-injured patients: a randomized, double-blind study. Wounds: A Compendium of Clinical Research & Practice. Jan–Feb. 1995;7(1):11-6.
168 Schubert V. Effects of phototherapy on pressure ulcer healing in elderly patients after a falling trauma. A prospective, randomized, controlled study. Photodermatology, Photoimmunology & Photomedicine. Feb. 2001;17(1):32-8. [pmid: 11169174].
169 Schwien T, Gilbert J, Lang C. Pressure ulcer prevalence and the role of negative pressure wound therapy in home health quality outcomes. Ostomy Wound Management. Sep. 2005;51(9):47-60. [pmid: 16230764].
170 Srivastava RN. An innovative, cost-effective, negative pressure device for management of bedsores in traumatic paraplegia. Spine Journal. 2010;10(9):86S-7S.
171 Taly AB, Sivaraman Nair KP, Murali T, et al. Efficacy of multiwavelength light therapy in the treatment of pressure ulcers in subjects with disorders of the spinal cord: A randomized double-blind controlled trial. Archives of Physical Medicine & Rehabilitation. Oct. 2004;85(10):1657-61. [pmid: 15468027].
172 Ter Riet G. Correction: Randomised clinical trial of ultrasound treatment for pressure ulcers (British Medical Journal (22nd April) (1040–1041)). British Medical Journal. 1995;310(6990):1300.
173 Ter Riet G, Kessels AGH, Knipschild P. A randomized clinical trial of ultrasound in the treatment of pressure ulcers. Physical Therapy. 1996;76(12):1301-12. [pmid: 8959999].
174 Wanner MB, Schwarzl F, Strub B, et al. Vacuum-assisted wound closure for cheaper and more comfortable healing of pressure sores: a prospective study. Scandinavian Journal of Plastic & Reconstructive Surgery & Hand Surgery. 2003;37(1):28-33. [pmid: 12625392].
175 Wood JM, Evans PE 3rd, Schallreuter KU, et al. A multicenter study on the use of pulsed low-intensity direct current for healing chronic stage II and stage III decubitus ulcers. Archives of Dermatology. Aug. 1993;129(8):999-1009. [pmid: 8352625].
176 Arashi M, Sugama J, Sanada H, et al. Vibration therapy accelerates healing of Stage I pressure ulcers in older adult patients. Advances in Skin & Wound Care. Jul. 2010;23(7):321-7. [pmid: 20562541].
177 Arashi M, Sugama J, Sanada H. Vibration Therapy Accelerates Healing of Stage I Pressure Ulcers in Older Adult Patients. Journal of Wound, Ostomy & Continence Nursing. 2011:S8-S.
178 Edsberg LE, Brogan MS, Jaynes CD, et al. Topical hyperbaric oxygen and electrical stimulation: exploring potential synergy. Ostomy Wound Management. Nov. 2002;48(11):42-50. [pmid: 12426451].
179 Feedar JAK, LC. Acceleration of wound healing with high voltage pulsating direct current (abstract). Phys Ther. 1985;(65):741.
180 Larking AM, Duport S, Clinton M, et al. Randomized control of extracorporeal shock wave therapy versus placebo for chronic decubitus ulceration. Clinical Rehabilitation. Mar. 2010;24(3):222-9. [pmid: 20156981].
181 Stefanovska A. Treatment of chronic wounds by means of electric and electromagnetic fields. Part 2. Value of FES parameters for pressure sore treatment. Medical & Biological Engineering & Computing. May. 1993;31(3):213-20. [pmid: 8412373].
182 Ullah MO. A study to detect the efficacy of Micro-current Electrical Therapy on decubitus wound. Journal of Medical Sciences. 2007;7(8):1320-4.