# Overall Strength of Evidence

Table G-1 Overall strength of evidence