# Excluded Studies List

1 various innovations in the management of decubitus ulcer. Kango Gijutsu - Japanese Journal of Nursing Art. 1986:594-600. exclusion reason - not relevant. [pmid: 3636507].
2 prevention and treatment of decubitus ulcers. Soins; La Revue de Reference Infirmiere. 1989:32-6. exclusion reason - not relevant. [pmid: 2602966].
3 About pressure ulcers. Nursing. 1989:76. exclusion reason - background. [pmid: 2771256].
4 Electromagnetic energy hastens healing of pressure ulcers. Geriatrics. 1991:16. exclusion reason - unable to find.
5 For your information: Pressure ulcers. Missouri Medicine. 1991:633-4. exclusion reason - background. [pmid: 1836047].
6 Pressure ulcers in adults. Pennsylvania Nurse. 1992:7. 10. exclusion reason - background. [pmid: 1508557].
7 Platelet derived growth factors: New impulses in wound healing. Therapiewoche. 1993:1380-1381. exclusion reason - not relevant.
8 Cutinova(registered trademark) cavity - innovative hydroactive wounddressing, specifically for treatment of deep and complicated wounds. H+G Zeitschrift fur Hautkrankheiten. 1994:678. exclusion reason - not relevant.
9 Care of chronic wounds: Leg ulcer and decubitus. Physical wound cleansing. Krankenhaus Arzt. 1995:409-410. exclusion reason - not relevant.
10 Decubitus ulcers in geriatrics: The significance of hydrocolloid dressings. Revue du Praticien - Medecine Generale. 1996:38-39. exclusion reason - not relevant.
11 Pressure ulcer treatment: Quick reference guide for clinicians. Journal of Pharmaceutical Care in Pain & Symptom Control. 1996:93-124. exclusion reason - background.
12 Pressure sores -- part ii: Management of pressure related tissue damage. International Journal of Nursing Practice. 1997:1. exclusion reason - no original data. [pmid: 9274208].
13 Special report: Pressure-reducing support surfaces in the prevention and treatment of pressure ulcers: Group 3 technologies and continuous rotational devices. Part iii. Tecnologica MAP Supplement. 1998:20-1. exclusion reason - unable to find. [pmid: 10183371].
14 Special report: Prevention and treatment of pressure ulcers: Group 2 technologies. Part ii. Tecnologica MAP Supplement. 1998:17-9. exclusion reason - unable to find. [pmid: 10183370].
15 Special report: Pressure-reducing support surfaces in the prevention and treatment of pressure ulcers: Group 1 technologies. Part i. Tecnologica MAP Supplement. 1998:43-5. exclusion reason - unable to find. [pmid: 10183362].
16 Making the right dressing choice: What the survey said. Community Nurse. 1999:41. exclusion reason - no original data. [pmid: 10732576].
17 Improve pressure ulcer outcomes with protocols. Homecare Quality Management. 1999:11. exclusion reason - no original data.
18 Vacuum-assisted closure for chronic wound healing. Tecnologica MAP Supplement. 2000:19-20. exclusion reason - unable to find. [pmid: 11503769].
19 Sequential moist wound healing in decubitus and leg ulcers. Vasomed. 2000:35. exclusion reason - not relevant.
20 decubitus ulcer. Biological wound treatment stimulates the healing process. MMW Fortschritte der Medizin. 2001:59. exclusion reason - not relevant. [pmid: 11420836].
21 Aggressive nutrition intervention. Staff training is key to ensuring positive outcomes. Health Care Food & Nutrition Focus. 2001:12. exclusion reason - no original data. [pmid: 11213747].
22 Uf tests potential remedy for pressure ulcers in elderly. Florida Nurse. 2001:32-32. exclusion reason - no original data.
23 mepentol, the first product for the prevention and treatment of grade i pressure ulcers. Revista de Enfermeria. 2002:41. exclusion reason - not relevant. [pmid: 13677759].
24 chronic decubitus, ulcus cruris. Maggots feed for wound healing. MMW Fortschritte der Medizin. 2002:69. exclusion reason - not relevant. [pmid: 11847894].
25 The pressure sore alleviation project. Journal of Tissue Viability. 2002:77. exclusion reason - wrong intervention. [pmid: 12001329].
26 new product for support of wound healing in decubitus ulcer. Decusin. Krankenpflege Journal. 2003:40. exclusion reason - not relevant. [pmid: 12718268].
27 Summaries for patients. Nerve growth factor improves healing of pressure ulcers of the foot. Annals of Internal Medicine. 2003:10. exclusion reason - no original data. [pmid: 12513039].
28 new collagen powder for wound healing + cost control. Krankenpflege Journal. 2004:260. exclusion reason - not relevant. [pmid: 15675418].
29 bedridden patients at high risk for decubitus ulcer. Skin oil prevents decubitus wounds. MMW Fortschritte der Medizin. 2004:62. exclusion reason - not relevant. [pmid: 15357488].
30 knowing how to choose the best support surface for the prevention and treatment of decubitus ulcers?. Revue de L’Infirmiere. 2004:22-4. exclusion reason - background. [pmid: 15984746].
31 Item no. 50: Complications of immobility on decubitus. Prevention and management: Bedsore. Annales de Dermatologie et de Venereologie. 2005:7S11-7S15. exclusion reason - not relevant. [pmid: 16419514].
32 Radiant heat bandages for stage 3–4 pressure ulcers. Caring for the Ages. 2005:27-27. exclusion reason - unable to find.
33 New equip pressure ulcer standard. Primary Intention: The Australian Journal of Wound Management. 2005:117-117. exclusion reason - not relevant.
34 efficacy of mepentol supported by scientific evidence. Revista de Enfermeria. 2007:6-7. exclusion reason - not relevant. [pmid: 17957968].
35 Patient information. Preventing and treating pressure sores. Advance for Nurse Practitioners. 2007:29. exclusion reason - background. [pmid: 19998955].
36 Facility lowers rate of pressure ulcers, specifically on heel: Use of boot proves to be a step in right direction. Briefings on Patient Safety. 2009:3-5. exclusion reason - no original data.
37 Selected excerpt from best practice statement: Optimizing the use of versivarg xcrg gelling foam dressing. Ostomy Wound Management. 2009:3-18. exclusion reason - unable to find.
38 Therapeutic mattresses for pressure ulcer management. Critical Care Nurse. 2009:91-91. exclusion reason - no original data.
39 Fall: Court sees deviations from nursing standards. Legal Eagle Eye Newsletter for the Nursing Profession. 2009:2-2. exclusion reason - background.
40 The effect of stochastic electrical noise on hard-to-heal wounds. Journal of Wound Care. 2011:96-103. exclusion reason - not relevant.
41 Tratamiento de las ãlceras con acupuntura acupuncture treatment in ulcers. Agora de Enfermeria. 2011:27-30. exclusion reason - not relevant.
42 Methods guide for effectiveness and comparative effectiveness reviews. Ahrq publication no. 10(12)-ehc063-ef. Rockville, MD. Agency for Healthcare Research and Quality. April. 2012. [pmid: 21433403]. exclusion reason - background.
43 Abe N, Noguchi M, Hayashi M, Watanabe T, Kushima H. The use of bilobed and trilobed gluteal perforator-based island flaps for the repair of sacral pressure ulcers. Japanese Journal of Plastic and Reconstructive Surgery. 1994:1111-1116. exclusion reason - not relevant.
44 Acarturk TO. Treatment of large ischial ulcers communicating with the hip joint with proximal femoral resection and reconstruction with a combined vastus lateralis, vastus intermedius and rectus femoris musculocutaneous flap. Journal of Plastic, Reconstructive & Aesthetic Surgery: JPRAS. 2009:1497-502. exclusion reason - not relevant. [pmid: 18718837].
45 Adams J, Teague L, Mahoney J. The impact of pressure ulcers on patient quality of life: Validation of the cardiff wound impact questionnaire. Symposium on advanced wound care and wound healing society meeting. april 28-may 1, 2007. tampa convention center, tampa, florida. Wounds: A Compendium of Clinical Research & Practice. 2007:A26-A26. exclusion reason - background.
46 Adelson R, Hepburn K, Reed R, Dawson A. Effective dissemination of the ahcpr guideline: Prevention and early management of pressure ulcers. [abstract]. Abstract Book/Association for Health Services Research. 1997:167-168. exclusion reason - background.
47 Aggarwal A, Sangwan SS, Siwach RC, Batra KM. Gluteus maximus island flap for the repair of sacral pressure sores. Spinal Cord. 1996:346-50. exclusion reason - not relevant. [pmid: 8963988].
48 Agreda JJS, Bou JT, Posnett J, Soriano JV, San Miguel L, Santos JMM. An approach to the economic impact of the treatment of pressure ulcers in spain. [spanish]. Gerokomos. 2007:43-52. exclusion reason - background.
49 Aguilo Sanchez S, Figueiras Mareque L, Quintilla Gatnau A, Veiga Bogo L. Traditional dressings or cures in a moist environment?. [spanish]. Revista Rol de Enfermería. 2001:50-54. exclusion reason - not relevant. [pmid: 12149995].
50 Ahluwalia R, Martin D, Mahoney JL. The operative treatment of pressure wounds: A 10-year experience in flap selection. International Wound Journal. 2009:355-8. exclusion reason - not relevant. [pmid: 19912392].
51 Ahluwalia R, Martin D, Mahoney JL. The operative treatment of pressure wounds: A 10-year experience in flap selection. International Wound Journal. 2010:103-6. exclusion reason - not relevant. [pmid: 20529150].
52 Akan IM, Ulusoy MG, Bilen BT, Kapucu MR. Modified bilateral advancement flap: The slide-in flap. Annals of Plastic Surgery. 1999:545-8. exclusion reason - not relevant. [pmid: 10340865].
53 Akbari Sari A, Flemming K, Cullum NA, Wollina U. Therapeutic ultrasound for pressure ulcers. Cochrane Database of Systematic Reviews. 2009. exclusion reason - Systematic Review, not directly used. [pmid: 16855964].
54 Akguner M, Karaca C, Atabey A, Menderes A, Top H. Surgical treatment for ischial pressure sores with gracilis myocutaneous flap. Journal of Wound Care. 1998:276-8. exclusion reason - not relevant. [pmid: 9697459].
55 Akiyama M, Ohnishi Y, Henta T, Tajima S, Ishibashi A, Kawada A. An evaluation of actosin ointment against superficial cutaneous blood flow: A laser doppler flowmetric study. Acta Dermatologica - Kyoto. 1998:171-176. exclusion reason - wrong outcome.
56 Allman RM The impact of pressure ulcers on health care costs and mortality Advances in Wound Care 19982exclusion reason - no original data. 9729946
57 Allman RM, Damiano AM, Strauss MJ. Pressure ulcer status and post-discharge health care resource utilization among older adults with activity limitations. Advances in Wound Care. 1996:38-44. exclusion reason - wrong outcome. [pmid: 8845997].
58 Allman RM, Laprade CA, Noel LB, Walker JM, Moorer CA, Dear MR, Smith CR. Pressure sores among hospitalized patients. Annals of Internal Medicine. 1986:337-42. exclusion reason - background. [pmid: 3740674].
59 Alterescu V. The financial costs of inpatient pressure ulcers to an acute care facility. Decubitus. 1989:14-23. exclusion reason - background. [pmid: 2775470].
60 Alvarez ML. Delivering positive outcomes fromnegative pressure wound therapy (npwt). Wound Repair and Regeneration. 2011:A10. exclusion reason - not relevant.
61 Alvarez OM, Fernandez-Obregon A, Rogers RS, Bergamo L, Masso J, Black M. A prospective, randomized, comparative study of collagenase and papain-urea for pressure ulcer debridement. Wounds: A Compendium of Clinical Research & Practice. 2002:293-301. exclusion reason - no original data.
62 Amione P, Ricci E, Topo F, Izzo L, Pirovano R, Rega V, Cocci C, Masina M. Comparison of allevyn adhesive and biatain adhesive in the management of pressure ulcers. Journal of Wound Care. 2005:365-70. exclusion reason - wrong outcome. [pmid: 16178291].
63 Anderson C, Rappl L. Lateral rotation mattresses for wound healing. Ostomy Wound Management. 2004:50-4. 56. 58 passim. exclusion reason - wrong outcome. [pmid: 15259801].
64 Ao M, Mae O, Namba Y, Asagoe K. Perforator-based flap for coverage of lumbosacral defects. Plastic & Reconstructive Surgery. 1998:987-91. exclusion reason - not relevant. [pmid: 9514331].
65 Apelqvist J, Ragnarson Tennvall G. Cavity foot ulcers in diabetic patients: A comparative study of cadexomer iodine ointment and standard treatment. An economic analysis alongside a clinical trial. Acta Dermato-Venereologica. 1996:231-5. exclusion reason - wrong population. [pmid: 8800307].
66 Arboledas Bellon J, Melero Lopez A. Calcium alginate and hydrocellular dressings in the prevention and treatment of pressure ulcers. [spanish]. Metas de Enfermería. 2004:28-32. exclusion reason - not relevant.
67 Arnold-Long M, Johnson R, Reed L. Negative pressure wound therapy overlay technique with collagen dressings for nonhealing wounds. Journal of Wound, Ostomy, & Continence Nursing. 2010:549-53. exclusion reason - not relevant. [pmid: 20838320].
68 Aronovitch S. A comparative, randomized, controlled study to determine safety and efficacy of preventive pressure ulcer systems: Preliminary analysis. The Journal for Prevention and Healing. 1998:15-16. exclusion reason - not relevant.
69 Asbjornsen G, Hernaes B, Molvaer G. The effect of transcutaneous electrical nerve stimulation on pressure sores in geriatric patients. Journal of Clinical and Experimental Gerontology. 1990:209-214. exclusion reason - not relevant.
70 Aslan G, Tuncali D, Bingul F, Ates L, Yavuz N. The duck modification of the tensor fascia lata flap. Annals of Plastic Surgery. 2005:637-9. exclusion reason - not relevant. [pmid: 15900151].
71 Atkins D, Chang S, Gartlehner G, Buckley DI, Whitlock EP, Berliner E, Matchar D. Assessing applicability when comparing medical interventions: Agency for healthcare research and quality and the effective health care program. Journal of clinical epidemiology. 2011:1198-207. exclusion reason - background. [pmid: 21463926].
72 Atri SC, Misra J, Bisht D, Misra K. Use of homologous platelet factors in achieving total healing of recalcitrant skin ulcers. Surgery. 1990:508-12. exclusion reason - wrong population. [pmid: 2396195].
73 Augeraud C, Guillain P. comparative study of 4 kinds of dressings. Soins; La Revue de Reference Infirmiere. 2000:21-4. exclusion reason - not relevant. [pmid: 11040822].
74 Aziz Z, Flemming K, Cullum NA, Olyaee Manesh A. Electromagnetic therapy for treating pressure ulcers. Cochrane Database of Systematic Reviews. 2010:CD002930. exclusion reason - Systematic Review, not directly used. [pmid: 21069672].
75 Baba-Akbari SariA, Flemming K, Cullum NA, Wollina U. Therapeutic ultrasound for pressure ulcers. Cochrane Database of Systematic Reviews. 2006:CD001275. exclusion reason - Systematic Review, not directly used. [pmid: 16855964].
76 Baharestani M. Early initiation of negative pressure wound therapy* in the treatment of stage iii and iv pressure ulcers: Analyzing the impact of length of home care services. World Union of Wound Healing Societies. Toronto, Canada. 2008. exclusion reason - wrong outcome.
77 Baharestani MM, Houliston-Otto DB, Barnes S. Early versus late initiation of negative pressure wound therapy: Examining the impact on home care length of stay. Ostomy Wound Management. 2008:48-53. exclusion reason - wrong outcome. [pmid: 19037137].
78 Baker RP, Brown EM, Coakham HB. Overwhelming cranial and spinal subdural empyema secondary infected sacral decubitus ulcers. British Journal of Neurosurgery. 2003:572-3. exclusion reason - not relevant. [pmid: 14756492].
79 Balakrishnan C, Vanjari SB, Esposito G. Tissue expansion in the treatment of pressure ulcers. [5]. Plastic and Reconstructive Surgery. 1991:1108. exclusion reason - no original data. [pmid: 1946766].
80 Bale S. The management of extensive pressure sores. Journal of Wound Care. 1996:470. exclusion reason - not relevant. [pmid: 9117820].
81 Bale S, Dealey C, Defloor T, Hopkins A, Worboys F. The experience of living with a pressure ulcer. Nursing Times. 2007:42-3. exclusion reason - background. [pmid: 17476848].
82 Bale S, Hahn TW, Gad P. Time to healing and health related quality of life in the treatment of pressure ulcers with foam dressings. 12th Conference of the European Wound Management Association. 2002. exclusion reason - no original data.
83 Bale S, Tebble N, Jones V, Price P. The benefits of implementing a new skin care protocol in nursing homes. Journal of Tissue Viability. 2004:44-50. exclusion reason - wrong outcome. [pmid: 15114926].
84 Ballard K, Baxter H. Vacuum-assisted closure. Nursing Times. 2001:51-2. exclusion reason - no original data. [pmid: 11957602].
85 Ballard K, Baxter H. Promoting healing in static wounds. Nursing Times. 2001:52. exclusion reason - no original data. [pmid: 11954459].
86 Ballek A. Rotational therapy beds: Are they worth the cost?. Hospital Materials Management. 1997:18-9. exclusion reason - no original data. [pmid: 10168221].
87 Banks. Evaluation of a new polyurethane foam dressing. Journal of Wound Care. 1997:266-269. exclusion reason - wrong outcome. [pmid: 9274262].
88 Banks K, Jones ES, Law MS, MacAvoy S. An effective skin integrity program. Journal of Nursing Staff Development. 1993:93-6. exclusion reason - background. [pmid: 8492186].
89 Banks V. Management issues in pressure area care. Journal of Wound Care. 1998:369-70. exclusion reason - no original data. [pmid: 9791370].
90 Banks V. Nutrition and pressure area management. Journal of Wound Care. 1998:318-9. exclusion reason - background. [pmid: 9697469].
91 Banks V. Pressure sores: Topical treatment and the healing process. Journal of Wound Care. 1998:265-6. exclusion reason - no original data. [pmid: 9677999].
92 Banks V, Bale S, Harding K. A comparative study to evaluate the effectiveness of lyofoam a in the treatment of superficial pressure sores. 3rd European Conference on Advances in Wound Management. 1993. exclusion reason - no original data.
93 Banks V, Bale S, Harding KG. Superficial pressure sores: Comparing two regimes. Journal of Wound Care. 1994:8-10. exclusion reason - duplicate.
94 Baranoski S. Collaborative roles lead to success in wound healing. Decubitus. 1992:66-8. exclusion reason - background. [pmid: 1596354].
95 Barnes E, Malone-Lee J. Pressure sores: Tegaderm pouch dressings. Nursing Times. 1985:45-6. exclusion reason - no original data. [pmid: 3853162].
96 Barnes J, BK. Management of pressure sores: A comparison of granuflex hydrocolloid dressing and granuflex e hydrocolloid dressing. The Pharmacist and Wound Care. 1992. exclusion reason - no original data.
97 Barnes S, Rutland BS. Air-fluidized therapy as a cost-effective treatment for a “worst case” pressure necrosis. Journal of Enterostomal Therapy. 1986:27-9. exclusion reason - not relevant. [pmid: 3633272].
98 Barnhart EV, Jarvis V. Skin integrity, impaired: Pressure ulcer, stage 1b. A standardized nursing care plan. CAET Journal. 1993:15-16. exclusion reason - no original data.
99 Barr JE. Multi-center evaluation of a new wound dressing. Ostomy Wound Management. 1993:60-4. 66. 7. exclusion reason - not relevant. [pmid: 8136005].
100 Barr JE. Managing deep, full-thickness pressure ulcers with a new hydrocolloid/alginate wound filler: Dermasorbtm spiral. Ostomy Wound Management. 1994:4p. exclusion reason - not relevant.
101 Barr JE, Day AL, Weaver VA, Taler GM. Assessing clinical efficacy of a hydrocolloid/alginate dressing on full-thickness pressure ulcers. Ostomy Wound Management. 1995:28-30. 32. 34. 6. passim. exclusion reason - not relevant. [pmid: 7546113].
102 Barrett R, Tuttle V, Whalen E, Gatchell C, Dawe A. Pressure ulcers and nutritional support: A partnership to improve patient outcomes. Journal of Nursing Care Quality. 2010:145-50. exclusion reason - background. [pmid: 19707154].
103 Barrois B, Carles M, Rumeau M, Tell L, Toussaint JF, Bonnefoy M, De Vathaire F. Efficacy and tolerability of hyaluronan (ialuset(registered trademark)) in the treatment of pressure ulcers: A multicentre, non-randomised, pilot study. Drugs in R and D. 2007:267-273. exclusion reason - wrong intervention. [pmid: 17767392].
104 Baskov AV. the surgical treatment of decubitus ulcers in patients with spinal cord trauma. Zhurnal Voprosy Neirokhirurgii Imeni N - N - Burdenko. 2000:7-10. exclusion reason - not relevant. [pmid: 10738756].
105 Bates-Jensen BM. Wound care nurses’ judgements on healing time in chronic wounds. Ostomy Wound Management. 1996:36-8. 40. 42 passim. exclusion reason - background. [pmid: 8826137].
106 Bates-Jensen BM. A quantitative analysis of wound characteristics as early predictors of healing in pressure sores. University of California. Los Angeles. 1998:236. exclusion reason - not relevant.
107 Bates-Jensen BM. Wound characteristics as early predictors of healing in pressure sores. 33rd annual communicating nursing research conference/14th annual win assembly, building on a legacy of excellence in nursing research. held april 13–15 2000. adam’s mark hotel, denver, colorado. Communicating Nursing Research. 2000:191-191. exclusion reason - background.
108 Bates-Jensen BM, Guihan M, Garber SL, Chin AS, Burns SP. Characteristics of recurrent pressure ulcers in veterans with spinal cord injury. Journal of Spinal Cord Medicine. 2009:34-42. exclusion reason - wrong outcome. [pmid: 19264047].
109 Bauer M. Follow-up and critical review of various surgical techniques for the treatment of decubitus. Wiener Medizinische Wochenschrift. 1989:586. exclusion reason - not relevant.
110 Bauer N, Bushey F, Amaros D. Diffusion of responsibility and pressure ulcers. World Council of Enterostomal Therapists Journal. 2002:9-18. exclusion reason - background.
111 Bauerle J, Neander KD. use of pulsed electrical stimulation in the therapy of decubitus ulcers. Krankenpflege Journal. 1996:270-5. exclusion reason - not relevant. [pmid: 8717869].
112 Bauernfeind G, Strupeit S. quality assurance by professional wound documentation: Often professional terminology is lacking. Pflege Zeitschrift. 2009:333-6. exclusion reason - background. [pmid: 19555001].
113 Bauman WA, Spungen AM, Collins JF. Lack of efficacy of oxandrolone to increase the percent of healed pressure ulcers in persons with sci: Va cooperative study. Journal of Spinal Cord Medicine. 2009:458. exclusion reason - wrong intervention.
114 Baxter C, Mertz PM. Local factors that affect wound healing. Nursing RSA Verpleging. 18. 1992:16-9. 22. 3. exclusion reason - background. [pmid: 1584283].
115 Baxter H. A comparison of two hydrocolloid sheet dressings. British Journal of Community Nursing. 574. 576. 2000:572-7. exclusion reason - wrong outcome. [pmid: 12066057].
116 Baxter H. How a discipline came of age: A history of wound care. Journal of Wound Care. 2002:383-6. 388. 390 passim. exclusion reason - background. [pmid: 12494830].
117 Beaulieu MB. the stages of healing of decubitus ulcers. Soins; La Revue de Reference Infirmiere. 1995:18-20. exclusion reason - background. [pmid: 7716577].
118 Bechert K. Journal of the american college of certified wound specialists: Editorial. Journal of the American College of Certified Wound Specialists. 2010:2. exclusion reason - background.
119 Beckel J. Implementation of a standardized protocol for treating pressure ulcers in a nursing home. Geriatric Nursing. 1992:84-9. exclusion reason - not relevant. [pmid: 1321086].
120 Beele H, Meuleneire F, Nahuys M, Percival SL. A prospective randomised open label study to evaluate the potential of a new silver alginate/carboxymethylcellulose antimicrobial wound dressing to promote wound healing. International Wound Journal. 2010:262-70. exclusion reason - wrong intervention. [pmid: 20529142].
121 Beitz JM. Overcoming barriers to quality wound care: A systems perspective. Ostomy Wound Management. 2001:56-64. exclusion reason - background. [pmid: 11889750].
122 Beitz JM, van Rijswijk L. Using wound care algorithms: A content validation study. Journal of Wound, Ostomy, & Continence Nursing. 1999:238-9. exclusion reason - wrong intervention. [pmid: 10795206].
123 Bejany DE, Chao R, Perito PE, Politano VA. Continent urinary diversion and diverting colostomy in the therapy of non-healing pressure sores in paraplegic patients. Paraplegia. 1993:242-8. exclusion reason - not relevant. [pmid: 8493039].
124 Beldon P. Problems encountered managing pressure ulceration of the sacrum. British Journal of Community Nursing. 2008:S6. S8. 10 passim. exclusion reason - background. [pmid: 19060829].
125 Bell J. The role of pressure-redistributing equipment in the prevention and management of pressure ulcers. Journal of Wound Care. 2005:185-8. exclusion reason - no original data. [pmid: 15835233].
126 Bell JC, Matthews SD. Results of a clinical investigation of four pressure-reduction replacement mattresses. Journal of ET Nursing. 1993:204-10. exclusion reason - wrong outcome. [pmid: 8110886].
127 Benbow M. Guidelines for the prevention and treatment of pressure ulcers. Nursing Standard. 2006:42-4. exclusion reason - background. [pmid: 16989340].
128 Bennett C, Thomason SS, Boyle P, Dammers A, Lacko H, Nichols J, Resulta A, Watkins C. Intensive development of an exportable pressure ulcer prevention and treatment program. Journal of Spinal Cord Medicine. 2009:483. exclusion reason - background.
129 Bennett RG, Baran PJ, DeVone L, Bacetti H, Kristo B, Tayback M, Greenough WB III. Low airloss hydrotherapy versus standard care for incontinent hospitalized patients. Journal of the American Geriatrics Society. 1998:569-576. 654. 655. exclusion reason - wrong outcome. [pmid: 9588369].
130 Bennett RG, Bellantoni MF, Ouslander JG. Air-fluidized bed treatment of nursing home patients with pressure sores. Journal of the American Geriatrics Society. 1989:235-42. exclusion reason - wrong outcome. [pmid: 2918193].
131 Bennis S, Davis S. An effective approach to treating decubitus ulcers in home healthcare patients. Home Healthcare Nurse. 1994:47-52. exclusion reason - wrong population. [pmid: 8113091].
132 Benraad HB. Treatment of different stages of decubitus ulcers. Pharmaceutisch Weekblad. 1999:1482-1485. exclusion reason - background.
133 Benskin L. Pressure ulcer of one year’s duration healed in three weeks through the use of polymeric membrane dressing. 39th annual wound, ostomy and continence nurses annual conference. Journal of Wound, Ostomy & Continence Nursing. 2007:S26-S26. exclusion reason - not relevant.
134 Berard P, Montandon S, Jedynak D, Saubier EC. trial of a hydrocolloid in occlusive dressings in the treatment of skin wounds, duoderm. Revista de Enfermeria. 1986:17-20. exclusion reason - not relevant. [pmid: 3633609].
135 Berg W, Lossing C, Traneroth C, Gunnarsson A. an effective method for treatment of pressure sores. Total reduction of pressure supersedes the turning schedule. Lakartidningen. 1993:585-8. exclusion reason - not relevant. [pmid: 8437470].
136 Bergemann R, Lauterbach KW, Vanscheidt W, Neander KD, Engst R. Economic evaluation of the treatment of chronic wounds: Hydroactive wound dressings in combination with enzymatic ointment versus gauze dressings in patients with pressure ulcer and venous leg ulcer in germany. Pharmacoeconomics. 1999:367-77. exclusion reason - wrong outcome. [pmid: 10623365].
137 Bergstrom N. Review: Specially designed products to prevent or heal pressure sores are more effective than standard mattresses... Commentary on cullum n, deeks j, sheldon ta et al. Beds, mattresses and cushions for pressure sore prevention and treatment. (cochrane review, latest version 2000). Cochrane library. Oxford. Update software. Evidence Based Nursing. 2000:54-54. exclusion reason - Systematic Review, not directly used.
138 Bergstrom N, Bennett MA, Carlson CE, et al. Pressure ulcer treatment. Clinical Practice Guideline - Quick Reference Guide for Clinicians. 1994. exclusion reason - background.
139 Bergstrom N, Horn SD, Smout RJ, Bender SA, Ferguson ML, Taler G, Sauer AC, Sharkey SS, Voss AC. The national pressure ulcer long-term care study: Outcomes of pressure ulcer treatments in long-term care. Journal of the American Geriatrics Society. 2005:1721-9. exclusion reason - background. [pmid: 16181171].
140 Bergstrom N, Smout R, Horn S, Spector W, Hartz A, Limcangco MR. Stage 2 pressure ulcer healing in nursing homes. Journal of the American Geriatrics Society. 2008:1252-8. exclusion reason - background. [pmid: 18482291].
141 Bergstrom N, Theodore J, Trumble ME. Pressure ulcers among home care patients: Whose responsibility are they?. Journal of the American Geriatrics Society. 2000:1165-1166. exclusion reason - background. [pmid: 10983921].
142 Berlemont M. extensive resection of the hip for suppurative arthritis in the paraplegic. Evaluation of 170 cases. Revue de Chirurgie Orthopedique et Reparatrice de l Appareil Moteur. 1985:377-87. exclusion reason - not relevant. [pmid: 4081138].
143 Berlemont M, Keromest R. dangers of ischiectomy in ulcers in the paraplegic patient. Review of 236 records. Revue de Chirurgie Orthopedique et Reparatrice de l Appareil Moteur. 1987:656-64. exclusion reason - not relevant. [pmid: 3444945].
144 Berlowitz DR. Striving for six sigma in pressure ulcer care. Journal of the American Geriatrics Society. 2003:1320-1321. exclusion reason - background. [pmid: 12919247].
145 Berlowitz DR, Brandeis GH, Anderson J, Brand HK. Predictors of pressure ulcer healing among long-term care residents. Journal of the American Geriatrics Society. 1997:30-4. exclusion reason - wrong intervention. [pmid: 8994484].
146 Berlowitz DR, Brienza DM. Are all pressure ulcers the result of deep tissue injury? A review of the literature. Ostomy Wound Management. 2007:34-8. exclusion reason - background. [pmid: 17978413].
147 Berlowitz DR, Frantz RA. Implementing best practices in pressure ulcer care: The role of continuous quality improvement. Journal of the American Medical Directors Association. 2007:S37-41. exclusion reason - background. [pmid: 17336874].
148 Berlowitz DR, Wilking SV. The short-term outcome of pressure sores. Journal of the American Geriatrics Society. 1990:748-52. exclusion reason - background. [pmid: 2370394].
149 Berman JE, Sandford PR, Sandford BS, Collins JF, Bauman WA, Spungen AM. Inclusion of undermined wound area improves accuracy of serial assessments based on measured wound surface area. Journal of Spinal Cord Medicine. 2009:458-459. exclusion reason - background.
150 Bernabei R, Landi F, Bonini S, Onder G, Lambiase A, Pola R, Aloe L. Effect of topical application of nerve-growth factor on pressure ulcers. Lancet. 1999:307. exclusion reason - no original data. [pmid: 10440316].
151 Bernardo M, Wenter C, March A, Dona G. Pressure sores: Experience and new perspectives of intervention. Geriatria. 1993:325-329. exclusion reason - background.
152 Bhanganada K, Kiettiphongthavorn V, Wilde H. The use of super-saturated sucrose solution for chronic skin ulcers (resurrection of an old remedy). Journal of the Medical Association of Thailand. 1986:358-66. exclusion reason - wrong intervention. [pmid: 3760735].
153 Bialoszewski D, Kowalewski M. Superficially, longer, intermittent ozone theraphy in the treatment of the chronic, infected wounds. Ortopedia Traumatologia Rehabilitacja. 2003:652-8. exclusion reason - not relevant. [pmid: 17679848].
154 Bielecki M, Skowronski R, Skowronski J. sacral pressure sores and their treatment. Chirurgia Narzadow Ruchu i Ortopedia Polska. 2006:51-6. exclusion reason - not relevant. [pmid: 17128774].
155 Biglari B, vd Linden PH, Simon A, Aytac S, Gerner HJ, Moghaddam A. Use of medihoney as a non-surgical therapy for chronic pressure ulcers in patients with spinal cord injury. Spinal Cord. 2012:165-9. exclusion reason - not relevant. [pmid: 21931331].
156 Bih LI, Lu SY. The rehabilitation of pressure sores after myocutaneous flap surgery. Taiwan i Hsueh Hui Tsa Chih - Journal of the Formosan Medical Association. 1989:387-93. exclusion reason - not relevant. [pmid: 2794940].
157 Bilkay U, Helvaci E, Tokat C, Ozek C, Akin Y. surgical coverage technics of pressure sores and their outcomes. Ulusal Travma ve Acil Cerrahi Dergisi = Turkish Journal of Trauma & Emergency Surgery:TJTES. 2006:143-9. exclusion reason - not relevant. [pmid: 16676254].
158 Bill B, Pedersen J, Call E, Oberg C. Wound dressing shear test method (bench) providing results equivalent to humans. exclusion reason - Scientific Information Packets, not directly used.
159 Bingham P. Noncontact, low-frequency ultrasound therapy for infected pressure ulcers in a patient with multiple comorbidities... Scientific and clinical abstracts from the 40th annual wound, ostomy and continence nurses annual conference. Journal of Wound, Ostomy & Continence Nursing. 2008:S7-S7. exclusion reason - no original data.
160 Bizot E, Longrais E. hygiene of fluidized beds. Soins; La Revue de Reference Infirmiere. 1985:29-32. exclusion reason - background. [pmid: 3854510].
161 Blaylock B. Air support therapy: Ethical considerations. Journal of ET Nursing. 1992:171-3. exclusion reason - background. [pmid: 1420530].
162 Bliss M. An update on horizontal support surfaces. Journal of Tissue Viability. 2000:35-6. exclusion reason - background. [pmid: 10839096].
163 Bliss M. Pressure sores--demographic perspectives. Journal of Tissue Viability. 109. 2000:106-15. exclusion reason - background. [pmid: 11299569].
164 Bliss M. Selection criteria for systematic literature reviews. Journal of Tissue Viability. 2001:173-4. author reply 174–5. exclusion reason - background. [pmid: 11949611].
165 Bliss M. The importance of accurate terminology in wound care. Journal of Tissue Viability. 2003:180. exclusion reason - background. [pmid: 14606120].
166 Bliss M. Justifying placebo use in clinical trials. Journal of Tissue Viability. 2004:33. exclusion reason - background. [pmid: 14768133].
167 Bliss M, Thomas JM. An investigative approach. An overview of randomised controlled trials of alternating pressure supports. Professional Nurse. 1993:437-44. exclusion reason - no original data. [pmid: 8475148].
168 Bliss MR. Managing pressure ulcers. Advances in Wound Care. 1995:6. 8. exclusion reason - no original data. [pmid: 7582343].
169 Bliss MR. Preventing pressure sores in elderly patients: A comparison of seven mattress overlays. [erratum appears in age ageing 1995 nov;24(6):543]. Age & Ageing. 1995:297-302. exclusion reason - wrong outcome. [pmid: 7484486].
170 Bliss MR. Pressure sore protocol. Journal of Wound Care. 1997:248. author reply 249. exclusion reason - no original data. [pmid: 9256734].
171 Bliss MR. Pressure sores and severe sepsis. Hospital Medicine (London). 1999:146. exclusion reason - background. [pmid: 10320850].
172 Bliss MR. Clinical research in patient support systems. 1981. Journal of Tissue Viability. 2003:154-6. 158. 160 passim. exclusion reason - not relevant. [pmid: 14606118].
173 Bliss MR. Pressure ulcer care needs medical input. Journal of Wound Care. 2005:354-5. exclusion reason - background. [pmid: 16178288].
174 Bliss MR, Schofield M. A pilot leg ulcer clinic in a geriatric day hospital. Age & Ageing. 1993:279-84. exclusion reason - not relevant. [pmid: 8213334].
175 Blom MF. Dramatic decrease in decubitus ulcers. Geriatric Nursing. 1985:84-7. exclusion reason - background. [pmid: 3844361].
176 Bluestein D, Javaheri A. Pressure ulcers: Prevention, evaluation, and management. American Family Physician. 2008:1186-94. exclusion reason - background. [pmid: 19035067].
177 Blumen N, Bar-On Z, Azaria M, Ohry A. pressure sores: Pathophysiology, prevention, treatment and rehabilitation. Harefuah. 1992:321-6. exclusion reason - not relevant. [pmid: 1572582].
178 Bobel LM. Nutritional implications in the patient with pressure sores. Nursing Clinics of North America. 1987:379-90. exclusion reason - background. [pmid: 3646666].
179 Bocchi A, Dominici MM, Taglia M, Caleffi E, Dominici C. clinical and nursing protocol in the treatment of the decubital ulcers. Annali Italiani di Chirurgia. 2007:119-24. exclusion reason - not relevant. [pmid: 17583121].
180 Bocchi A, Traspassi S, Bianco G, Castagnetti F, Papadia F. Treatment of decubitus ulcers in patients with spina bifida. Europa Medicophysica. 2002:139-146. exclusion reason - wrong population.
181 Bodnar B, Myron P. Portrait of practice: Reducing the prevalence of pressure ulcers. Decubitus. 1992:49-52. exclusion reason - background. [pmid: 1558692].
182 Bogie KM, Ho CH, Terris DD. Clinical interface. Clinical evidence for new pressure ulcer treatment modalities. Long-Term Care Interface. 2005:43-47. exclusion reason - wrong population.
183 Boiko VV, Krivoruchko IA, Pasychnyi DA. surgical treatment of integumentary tissues of foot and shin using adhesive dermal tension and cryotherapy. Klinicheskaia Khirurgiia. 2002:33-6. exclusion reason - not relevant. [pmid: 11944294].
184 Bollero D, Driver V, Glat P, Gupta S, Lazaro-Martinez JL, Lyder C, Ottonello M, Pelham F, Vig S, Woo K. The role of negative pressure wound therapy in the spectrum of wound healing. Ostomy Wound Management. 2010:2-18. exclusion reason - background.
185 Bolton L. Hydrocellular dressings versus hydrocolloid dressings... A randomized clinical study comparing a hydrocellular dressing to a hydrocolloid dressing in the management of pressure ulcers. Ostomy Wound Management. 2000:8-8. exclusion reason - no original data.
186 Bolton L. Are silver products safe and effective for chronic wound management?. Journal of Wound, Ostomy, & Continence Nursing. 2006:469-77. exclusion reason - Systematic Review, not directly used. [pmid: 17133133].
187 Bolton L. Do products affect wound outcomes when using standardized algorithms?... Scientific and clinical abstracts from the 40th annual wound, ostomy and continence nurses annual conference. Journal of Wound, Ostomy & Continence Nursing. 2008:S31-S31. exclusion reason - no original data.
188 Bolton LS, Girolami S, Slayton TM, Berger L, Foster KT, Merkle Whittington D, S. Association for the Advancement of Wound Care Guideline. Assessing the need for developing a comprehensive content-validated pressure ulcer guideline. Ostomy Wound Management. 2008:22-30. exclusion reason - background. [pmid: 19037134].
189 Bolton L, McNees P, van Rijswijk L, de Leon J, Lyder C, Kobza L, Edman K, Scheurich A, Shannon R, Toth M. G Wound Outcomes Study. Wound-healing outcomes using standardized assessment and care in clinical practice. Journal of Wound, Ostomy, & Continence Nursing. 2004:65-71. exclusion reason - wrong intervention. [pmid: 15209428].
190 Bolton LB, Donaldson NE, Rutledge DN, Bennett C, Brown DS. The impact of nursing interventions: Overview of effective interventions, outcomes, measures, and priorities for future research. Medical Care Research & Review. 2007:123S-43S. exclusion reason - background. [pmid: 17406015].
191 Bolton LL. Evidence corner. Wounds heal better with sequential strategies. Wounds: A Compendium of Clinical Research & Practice. 2002:A28. exclusion reason - not relevant.
192 Bolton LL. Evidence corner. Rht: A veterans affairs (va) medical center pilot study on stage iii–iv pressure ulcers. Wounds: A Compendium of Clinical Research & Practice. 2005:A22. exclusion reason - wrong outcome.
193 Bolton LL. Evidence corner. Debriding pressure ulcers with maggot versus conventional therapy. Wounds: A Compendium of Clinical Research & Practice. 2006:A19. exclusion reason - no original data.
194 Bond TK. Consistency in prevention and treatment of pressure ulcers through a wound care team. Nursing Case Management. 1997:203-18. exclusion reason - not relevant. [pmid: 9392263].
195 Bonnefoy M, Coulon L, Bienvenu J, Boisson RC, Rys L. Implication of cytokines in the aggravation of malnutrition and hypercatabolism in elderly patients with severe pressure sores. Age and Ageing. 1995:37-42. exclusion reason - not relevant. [pmid: 7539207].
196 Borgman H, Sellmer W. Prophylaxis and therapy of decubitus. Krankenhauspharmazie. 1994:687-691. exclusion reason - not relevant.
197 Borgognone A, Anniboletti T, De Vita F, Schirosi M, Palombo P. Ischiatic pressure sores: Our experience in coupling a split-muscle flap and a fasciocutaneous flap in a ‘criss-cross’ way. Spinal Cord. 2010:770-3. exclusion reason - not relevant. [pmid: 20309001].
198 Borgstrom PS, Ekberg O, Lasson A. Radiography of pressure ulcers. Acta Radiologica. 1988:581-4. exclusion reason - background. [pmid: 3166880].
199 Borman H, Maral T. The gluteal fasciocutaneous rotation-advancement flap with v-y closure in the management of sacral pressure sores. Plastic & Reconstructive Surgery. 2002:2325-9. exclusion reason - not relevant. [pmid: 12045558].
200 Bortolani A, Sanna A, Barisoni D, Rigotti G, Furlan S. Review of 150 pressure sores in paraplegics. Rivista Italiana di Chirurgia Plastica. 1990:377-383. exclusion reason - not relevant.
201 Bosch M, Halfens RJG, van der Weijden T, Wensing M, Akkermans R, Grol R. Organizational culture, team climate, and quality management in an important patient safety issue: Nosocomial pressure ulcers. Worldviews on Evidence-Based Nursing. 2011:4-14. exclusion reason - background. [pmid: 20367807].
202 Boschnakov K, Tschervenkov J, Videlov D. the use of skin-muscle flaps in decubitus ulcer treatment. Zentralblatt fur Chirurgie. 1990:275-8. exclusion reason - not relevant. [pmid: 2346063].
203 Boshnakov K. skin-muscle flaps formed in the gluteal and femoral regions. Khirurgiia. 1986:29-35. exclusion reason - not relevant. [pmid: 3821007].
204 Boshnakov K, Chervenkov I. surgical treatment of decubital wounds in the trochanteric area. Khirurgiia. 1989:33-8. exclusion reason - not relevant. [pmid: 2761176].
205 Bou Torra J-E, Soldevilla Agreda JJ, Martinez Cuervo F, Rueda Lopez J. collagen powder dressing in the treatment of pressure ulcer. Multicenter comparative study assessing effectiveness and cost. Revista de Enfermeria. 2002:50-7. exclusion reason - not relevant. [pmid: 13677749].
206 Bourdel_Marchasson I, Barateau M, et al. A multi-center trial of the effects of oral nutritional supplementation in critically ill older inpatients. Nutrition. 2000:1-5. exclusion reason - wrong population. [pmid: 10674226].
207 Bourdel-Marchasson I, Rondeau V. Nutritional intervention trials for preventing and treating pressure ulcer. Nutrition. 2001:155-6. exclusion reason - no original data. [pmid: 11240343].
208 Bouza AlvarezC, Sanz de Leon O, Amate Blanco J. Effectiveness of special dressings in the treatment of pressure and leg ulcers. Ipe-01/28 (public report) (structured abstract). Health Technology Assessment Database. 2011. exclusion reason - no original data.
209 Bouza C, Saz Z, Munoz A, Amate JM. Efficacy of advanced dressings in the treatment of pressure ulcers: A systematic review. Journal of Wound Care. 2005:193-9. exclusion reason - Systematic Review, not directly used. [pmid: 15909431].
210 Bovy A. surgical treatment of pressure sores of the heel. Revue Medicale de Bruxelles. 1986:329-32. exclusion reason - not relevant. [pmid: 3526501].
211 Boykin A, Winland-Brown J. Pressure sores: Nursing management Compare hydrocolloid occlusive dressing with povidone-iodine therapy. Tanner CA, editor. Using nursing research: National League for Nursing. 1989:252-256. exclusion reason - unable to find.
212 Boykin J. 5 questions--and answers--about hyperbaric oxygen therapy. Advances in Skin & Wound Care. 2001:232. 234. exclusion reason - no original data. [pmid: 11905969].
213 Bozzuto TM, Fife CE. Adjunctive therapies for wound healing. JAMA. 2000:40. author reply 41. exclusion reason - no original data. [pmid: 10872005].
214 Braden BJ, Bryant R. Innovations to prevent and treat pressure ulcers. Geriatric Nursing. 1990:182-6. exclusion reason - no original data. [pmid: 2163958].
215 Bradley M, Cullum N, Nelson EA, Petticrew M, Sheldon T, Torgerson D. Systematic reviews of wound care management: (2). Dressings and topical agents used in the healing of chronic wounds. Health Technology Assessment (Winchester, England). 1999:1-35. exclusion reason - Systematic Review, not directly used. [pmid: 10683589].
216 Bradley M, Cullum N, Sheldon T. The debridement of chronic wounds: A systematic review. Health Technology Assessment. 1999:iii-73. exclusion reason - Systematic Review, not directly used.
217 Bradley MD, Nelson EA, Petticrew M, Cullum NA, Sheldon T. Dressings for pressure sores. Cochrane Database of Systematic Reviews. 2009. exclusion reason - background.
218 Brady SM. Management of pressure sores with occlusive dressings in a select population. Nursing Management. 1987:47-50. exclusion reason - no original data. [pmid: 3649654].
219 Brancati A. debridement of decubitus ulcers. Soins; La Revue de Reference Infirmiere. 2011:51. exclusion reason - not relevant. [pmid: 21449191].
220 Brandeis GH, Morris JN, Nash DJ, Lipsitz LA. Incidence and healing rates of pressure ulcers in the nursing home. Decubitus. 1989:60-2. exclusion reason - not relevant. [pmid: 2787661].
221 Brandeis GH, Morris JN, Nash DJ, Lipsitz LA. The epidemiology and natural history of pressure ulcers in elderly nursing home residents. JAMA. 1990:2905-9. exclusion reason - background. [pmid: 2232085].
222 Braumann C, Guenther N, Menenakos C, Muenzberg H, Pirlich M, Lochs H, Mueller JM. Clinical experiences derived from implementation of an easy to use concept for treatment of wound healing by secondary intention and guidance in selection of appropriate dressings. International Wound Journal. 2011:253-260. exclusion reason - wrong population. [pmid: 21401884].
223 Braun JL, Silvetti AN, Xakellis GC. Decubitus ulcers: What really works?. Patient Care. 1988:22. exclusion reason - background.
224 Braun JL, Silvetti AN, Xakellis GC. What really works for pressure sores. Patient Care. 1992:63. exclusion reason - background.
225 Bravo FG, Schwarze HP. Free-style local perforator flaps: Concept and classification system. Journal of Plastic, Reconstructive & Aesthetic Surgery:JPRAS. 2009:602-8. discussion 609. exclusion reason - not relevant. [pmid: 19181580].
226 Breite MJ. Pressure ulcers: The benefits and costs of new therapies. JAMA. 1993:2735. author reply 2735–6. exclusion reason - no original data. [pmid: 8492393].
227 Brem H, Balledux J, Bloom T, Kerstein MD, Hollier L. Healing of diabetic foot ulcers and pressure ulcers with human skin equivalent: A new paradigm in wound healing. Archives of Surgery. 2000:627-634. exclusion reason - wrong population. [pmid: 10843357].
228 Brem H, Jacobs T, Vileikyte L, Weinberger S, Gibber M, Gill K, Tarnovskaya A, Entero H, Boulton AJM. Wound-healing protocols for diabetic foot and pressure ulcers. Surgical Technology International. 2003:85-92. exclusion reason - wrong population. [pmid: 12931288].
229 Brem H, Kirsner RS. Use of graftskin (apligraf) in the treatment of pressure ulcers and acute wounds. Wounds: A Compendium of Clinical Research & Practice. 2000:72A-77. exclusion reason - not relevant.
230 Brem H, Lyder C. Protocol for the successful treatment of pressure ulcers. American Journal of Surgery. 2004:9-17. exclusion reason - background. [pmid: 15223496].
231 Brem H, Tomic-Canic M, Tarnovskaya A, Ehrlich HP, Baskin-Bey E, Gill K, Carasa M, Weinberger S, Entero H, Vladeck B. Healing of elderly patients with diabetic foot ulcers, venous stasis ulcers, and pressure ulcers. Surgical Technology International. 2003:161-7. exclusion reason - wrong population. [pmid: 12931298].
232 Brennan MR, Faliks S. Honey -- debriding alternative. 41st annual wound, ostomy and continence nurses annual conference. st. Louis, missouri. june 6–10, 2009. Journal of Wound, Ostomy & Continence Nursing. 2009:S17-S17. exclusion reason - no original data.
233 Brenner P, Berger A. The long-term management of sacral, ischial and trochanteric pressure sores by myocutaneous island flaps and their postoperative course. European Journal of Plastic Surgery. 1987:24-28. exclusion reason - not relevant.
234 Breslow R, Hallfrisch J, Moser PB, Maney M, Muller D, Goldberg A. High calories and protein improve healing of pressure sores in malnourished nursing home patients. Federation of American Societies for Experimental Biology (FASEB) World Meeting. Washington, DC. 1987. Paper No. 4042. exclusion reason - unable to find.
235 Breslow RA. The effect of dietary protein intake on pressure sore healing and nutritional status in nursing home subjects. University of Maryland College Park. 1990:129. exclusion reason - no original data.
236 Brienza DM, Geyer MJ. Understanding support surface technologies. Advances in Skin & Wound Care. 2000:237-44. exclusion reason - background. [pmid: 11075023].
237 Brindle CT. Wound-product selection and innovations: 3308: Identifying high-risk icu patients: Use of an absorbent soft silicone self-adherent bordered foam dressing to decrease pressure ulcers in the surgical trauma icu patient. Journal of Wound Ostomy & Continence Nursing. 2009:Supplement S27. exclusion reason - Scientific Information Packets, not directly used.
238 Bristow JV, Goldfarb EH, Green M. Clinitron therapy: Is it effective?. Geriatric Nursing. 1987:120-4. exclusion reason - wrong intervention. [pmid: 3646981].
239 Brooks R, Semlyen A. Economic appraisal in pressure sore management. Journal of Wound Care. 1997:491-4. exclusion reason - background. [pmid: 9455275].
240 Brown Etris M. A strategy for the management of pressure ulcers in nursing homes. Ostomy Wound Management. 1989:28-32. exclusion reason - no original data. [pmid: 2719804].
241 Brown Etris M. A randomized comparative clinical evaluation of a transparent absorbent acrylic dressing and a hydrocolloid dressing on stage ii and iii pressure ulcers. Journal of Wound, Ostomy & Continence Nursing. 2006:S53-S53. exclusion reason - not relevant.
242 Brown EtrisM, Punchello M, Shields D, Barnes H, Galluzzi K, Whalen A, et al. Interim analysis of a randomized prospective multi-centred 20-week comparison of two wound management systems on pressure ulcers. 31st Annual Wound, Ostomy and Continence Conference. 1999. exclusion reason - no original data.
243 Brown G. Long-term outcomes of full-thickness pressure ulcers: Healing and mortality. Ostomy Wound Management. 2003:42-50. exclusion reason - no original data. [pmid: 14652420].
244 Brown GL. Re: Recombinant human platelet-derived growth factor-bb for the treatment of chronic pressure ulcers. Annals of Plastic Surgery. 1993:192. exclusion reason - no original data. [pmid: 8489189].
245 Brown-Etris M. Measuring healing in wounds. Advances in Wound Care. 1995:suppl 53-8. exclusion reason - background. [pmid: 7627405].
246 Brown-Etris M, Milne CT. Use of a foam dressing with a unique spoke-shaped delivery system on pressure ulcers of the heel and elbow. 39th annual wound, ostomy and continence nurses annual conference. Journal of Wound, Ostomy & Continence Nursing. 2007:S30-1. exclusion reason - no original data.
247 Brown-Etris M, Punchello M, O’Connor T. Use of a transparent absorbent acrylic dressing on stage ii and iii pressure ulcers. Journal of Wound, Ostomy & Continence Nursing. 2006:S53-4. exclusion reason - not relevant.
248 Brown-Maher T. Multidisciplinary approach to chronic wound care: Our 2-year newfoundland and labrador experience. Journal of Cutaneous Medicine & Surgery. 2009:S26-8. exclusion reason - no original data. [pmid: 19480748].
249 Bryant R. Commentary on abstracts from the literature. Wound. Effects of hydrotherapy on pressure ulcer healing. [original article by burke td, ho ch-k, saucier ma, stewart g appears in am j phys med rehabil 1998;77:394–3]. Whitney JD, editor. Journal of Wound, Ostomy & Continence Nursing. 2000:12A-13. exclusion reason - background.
250 Buck DW 2nd, Lewis VL Jr. The use of argon beam coagulation in pressure sore reconstruction. Journal of Plastic, Reconstructive & Aesthetic Surgery:JPRAS. 2009:1684-7. exclusion reason - not relevant. [pmid: 18977700].
251 Bufton T. Wound care. A home from home. Nursing Times. 1995:66-74. exclusion reason - not relevant. [pmid: 7716025].
252 Burke DT, Ho CH, Saucier MA. Hydrotherapy effects on pressure ulcer healing. [abstract]. Archives of Physical Medicine and Rehabilitation. 1997:1053. exclusion reason - no original data.
253 Burrows C, Miller R, Townsend D, Bellefontaine R, Mackean G, Orsted HL, Keast DH. Best practice recommendations for the prevention and treatment of venous leg ulcers: Update 2006. Advances in Skin & Wound Care. 2007:611-21. quiz 622–3. exclusion reason - background. [pmid: 17975369].
254 Burt S, McDonald L, Burke T. Unexpected outcomes from monochromatic infrared energy (mire). Journal of Wound, Ostomy & Continence Nursing. 2006:S26-S26. exclusion reason - no original data.
255 Burton P. Prevention is better than cure. Journal of Community Nursing. 1995:18. exclusion reason - background.
256 Cali TJ, Bruce M. Pressure ulcer treatment: Examining selected costs of therapeutic failure. Advances in Wound Care. 1999:8-11. exclusion reason - no original data. [pmid: 10326352].
257 Call E, Pederson J, Baker L, Oberg C. Characterization of wound dressings physical properties and their potential impact on prevention of ulceration. 2010. EPUAP Annual Conference. 2010. exclusion reason - Scientific Information Packets, not directly used.
258 Campbell C, Parish LC. The decubitus ulcer: Facts and controversies. Clinics in Dermatology. 2010:527-32. exclusion reason - background. [pmid: 20797513].
259 Campbell C, Parish LC. Treatment of decubitus ulcers. SKINmed. 2011:114-5. exclusion reason - not relevant. [pmid: 21548518].
260 Campbell KE, LeMesurier A. Hydrocolloid dressings: A case series in wear time and function. Link (17012473). 2004:13-15. exclusion reason - wrong population.
261 Candela-Zamora MD, Martin-Gomez MA, Solas-Gomez B, Fernandez-Perez C, Martin-Gonzalez M, Manzanedo-Basilio L, Navarro-Gorjon S, Gonzalez-Dugo R, Rodriguez-Sanchez S, Nunez-Marugan MS, Nosti del Valle C, Garcia-Acena T, Cano-Escudero S, del Prado-Gonzalez N. comparative study of the effectiveness two of hyperoxygenated fatty acids in the treatment of grade i ulcers in geriatric hospitalized patients. Enfermeria Clinica. 2010:10-6. exclusion reason - not relevant. [pmid: 20117031].
262 Cannon BC, Cannon JP. Management of pressure ulcers. American Journal of Health-System Pharmacy. 2004:1895-905. quiz 1906–7. exclusion reason - background. [pmid: 15487879].
263 Capillas PerezR, Cabre Aguilar V, Gil Colome AM, Gaitano Garcia A, Torra i Bou JE. comparison of the effectiveness and cost of treatment with humid environment as compared to traditional cure. Clinical trial on primary care patients with venous leg ulcers and pressure ulcers. Revista de Enfermeria. 2000:17-24. exclusion reason - not relevant. [pmid: 10788945].
264 Capra F, Biraghi M. Preliminary clinical-iconographic evolution of cadexomer iodine in the topical treatment of decubitus ulcers. Giornale Italiano di Ricerche Cliniche e Terapeutiche. 1990:65-70. exclusion reason - not relevant.
265 Carasa M, Polycarpe M. Caring for the chronically critically ill patient: Establishing a wound- healing program in a respiratory care unit. American Journal of Surgery. 2004:18-21. exclusion reason - no original data. [pmid: 15223497].
266 Carley PJ, Wainapel SF. Electrotherapy for acceleration of wound healing: Low intensity direct current. Archives of Physical Medicine and Rehabilitation. 1985:443-6. exclusion reason - wrong population. [pmid: 3893385].
267 Carlton T, Strasburg P. Implementing research: Improving care of patients with pressure ulcers. Communicating Nursing Research. 2009:469-469. exclusion reason - wrong outcome.
268 Carr RD, Lalagos DE. Clinical evaluation of a polymeric membrane dressing in the treatment of pressure ulcers. Decubitus. 1990:38-42. exclusion reason - not relevant. [pmid: 2205233].
269 Carroll P. Pressure ulcers and materiel management: Cost-effective prevention and care. Hospital Materiel Management Quarterly. 1993:38-49. exclusion reason - background. [pmid: 10129709].
270 Casali B, Bonati PA, DelGin G, Ascari C. The use of a blood platelet lysate in the treatment of pressure sores experimental observations. European Wound Management Association Conference. Milan, Italy. 1997. exclusion reason - not relevant.
271 Casey G. Three steps to effective wound care. Elderly Care. 1998:14-6. exclusion reason - background. [pmid: 10542489].
272 Cassell BL. Treating pressure sores stage by stage. RN. 1986:36-40. exclusion reason - no original data. [pmid: 3635207].
273 Cavadas PC. Turn-over deepithelialized edge flaps in pressure sore repair. Plastic & Reconstructive Surgery. 1997:921-2. exclusion reason - no original data. [pmid: 9047226].
274 Ceelen KK, Stekelenburg A, Loerakker S, Strijkers GJ, Bader DL, Nicolay K, Baaijens FP, Oomens CWJ. Compression-induced damage and internal tissue strains are related. J Biomech. 2008:3399-3404. exclusion reason - wrong population. [pmid: 19010470].
275 Centers for Medicare & Medicaid Services, U. S. D. o. H. a. H. Services. Decision memo for air-fluidized beds for pressure ulcers (cag-00017r). 2012. exclusion reason - background.
276 Ceolim MF, Araujo IEM, Diogo MJE, Bajay HM, Rosa KM. Comparing hydrocolloid to dry gauze dressings in the treatment of sacral pressure sores. Nursing: A new era for action, international council of nurses icn 22nd quadrennial congress. Geneva, Switzerland. International Council of Nurses. 2001:445. exclusion reason - no original data.
277 Cervelli V, De Angelis B, Lucarini L, Spallone D, Balzani A, Palla L, Gentile P, Cerulli P. Tissue regeneration in loss of substance on the lower limbs through use of platelet-rich plasma, stem cells from adipose tissue, and hyaluronic acid. Advances in Skin & Wound Care. 2010:262-72. exclusion reason - wrong population. [pmid: 20489388].
278 Cervo FA, Cruz AC, Posillico JA. Pressure ulcers. Analysis of guidelines for treatment and management. Geriatrics. 2000:55-60. quiz 62. exclusion reason - background. [pmid: 10732005].
279 Ceschino M, Enrichens F, Olivero G. the he/neon soft-laser in the treatment of decubitus ulcer. Minerva Chirurgica. 1988:49-56. exclusion reason - not relevant. [pmid: 3283603].
280 Chaby G, Senet P, Vaneau M, Martel P, Guillaume JC, Meaume S, Téot L, Debure C, Dompmartin A, Bachelet H, Carsin H, Matz V, Richard JL, Rochet JM, Sales-Aussias N, Zagnoli A, Denis C, Guillot B, Chosidow O. Dressings for acute and chronic wounds: A systematic review. Archives of Dermatology. 2007:1297-1304. exclusion reason - background. [pmid: 17938344].
281 Chadwick P, Harrison M, Morris C, Bamford A, Stansby G. Avance® negative pressure wound therapy system: A clinical focus. Wounds UK. 2010:114-122. exclusion reason - not relevant.
282 Chaiken N. Making progress with stalled wounds. Pressure ulceration and the use of active leptospermum honey for debridement and healing. Ostomy Wound Management. 2010:12. exclusion reason - not relevant.
283 Chambers J. Topical manuka honey for mrsa-contaminated skin ulcers. Palliative Medicine. 2006:557. exclusion reason - not relevant. [pmid: 16903411].
284 Chan DCW, Fong DHF, Leung JYY, Patil NG, Leung GKK. Maggot debridement therapy in chronic wound care. Hong Kong Medical Journal. 2007:382-6. exclusion reason - Systematic Review, not directly used. [pmid: 17914145].
285 Chan JWH, Virgo KS, Johnson FE. Hemipelvectomy for severe decubitus ulcers in patients with previous spinal cord injury. American Journal of Surgery. 2003:69-73. exclusion reason - not relevant. [pmid: 12531450].
286 Chang J, Cuellar NG. The use of honey for wound care management: A traditional remedy revisited. Home Healthcare Nurse. 2009:308-16. quiz 317–8. exclusion reason - no original data. [pmid: 19448499].
287 Chapman BR, Mills KJ, Pearce LM, Crowe TC. Use of an arginine-enriched oral nutrition supplement in the healing of pressure ulcers in patients with spinal chord injuries: An observational study. Nutrition & Dietetics. 2011:208-213. exclusion reason - Scientific Information Packets, not directly used.
288 Chapuis A, Dollfus P. The use of a calcium alginate dressing in the management of decubitus ulcers in patients with spinal cord lesions. Paraplegia. 1990:269-71. exclusion reason - wrong outcome. [pmid: 2235034].
289 Charles MA, Oldenbrook J, Catton C. Evaluation of a low-air-loss mattress system in the treatment of patients with pressure ulcers. Ostomy Wound Management. 1995:46-8. 50. 52. exclusion reason - wrong outcome. [pmid: 7612140].
290 Chavarria Leon G, Cruz Cerdas L. Pressure sores: Surgical management in a national rehabilitation centre. Cirugia Plastica Ibero-Latinoamericana. 2002:63-68. exclusion reason - not relevant.
291 Chen Q. Effect of egg albumen combined with infrared ray irradiation to treat patients with bedsore induced by fecal incontinence. [chinese]. Chinese Nursing Research. 2004:1550-1551. exclusion reason - not relevant.
292 Chen TH. Bilateral gluteus maximus v-y advancement musculocutaneous flaps for the coverage of large sacral pressure sores: Revisit and refinement. Annals of Plastic Surgery. 1995:492-7. exclusion reason - not relevant. [pmid: 8579267].
293 Chen X, Jiang Z, Chen Z, Wang D. Application of skin traction for surgical treatment of grade iv pressure sore: A clinical report of 160 cases. Spinal Cord. 2011:76-80. exclusion reason - not relevant. [pmid: 20644559].
294 Chen Y, Mai X, Wang Y. wound repair with the fasciocutaneous flap of double reverse z-plasty. Chung-Hua Cheng Hsing Shao Shang Wai Ko Tsa Chih - Chinese Journal of Plastic Surgery & Burns. 1995:126-8. exclusion reason - not relevant. [pmid: 7648500].
295 Cheneworth CC, Hagglund KH, Valmassoi B, Brannon C. Portrait of practice: Healing heel ulcers. Advances in Wound Care. 1994:44-8. exclusion reason - no original data. [pmid: 7812583].
296 Cheng TJ, Tang YB. Treatment of ischial pressure sores with an inferior gluteus maximus musculocutaneous island flap. British Journal of Plastic Surgery. 1995:521-2. exclusion reason - no original data. [pmid: 7551539].
297 Cheong EC, Lim J, Lim TC. An atrophic, fat-infiltrated gracilis muscle for ischial reconstruction?. British Journal of Plastic Surgery. 2005:749-51. exclusion reason - not relevant. [pmid: 15927165].
298 Cheong EC, Wong MTC, Ong WC, Lim J, Lim TC. Sensory innervated superior gluteal artery perforator flap for reconstruction of sacral wound defect. Plastic & Reconstructive Surgery. 2005:958-9. exclusion reason - not relevant. [pmid: 15731715].
299 Cherubino M, Rubin JP, Miljkovic N, Kelmendi-Doko A, Marra KG. Adipose-derived stem cells for wound healing applications. Annals of Plastic Surgery. 2011:210-5. exclusion reason - background. [pmid: 21200308].
300 Chin T, Hyakusoku H. A new device: A portable and effective irrigation system for pressure ulcers. Plastic & Reconstructive Surgery. 2003:1973-4. exclusion reason - not relevant. [pmid: 14663270].
301 Chou R, Helfand M. Challenges in systematic reviews that assess treatment harms. Ann Intern Med. 2005:1090-1099. exclusion reason - background. [pmid: 15968034].
302 Chuang W. Management of the fungally infected pressure ulcer. World Council of Enterostomal Therapists Journal. 2007:34-34. exclusion reason - no original data.
303 Cid GonzalezM, Garcia Viveros JA, Martinez Florindo J, Alcon Jimenez C. An alternative in the treatment of longstanding pressure ulcers. Use of sucrose in 6 patients. [spanish]. Enfermeria Clinica. 2003:177-179. exclusion reason - not relevant.
304 Citak M, Backhaus M, Meindl R, Muhr G, Fehmer T. Rare complication after vac-therapy in the treatment of deep sore ulcers in a paraplegic patient. Archives of Orthopaedic & Trauma Surgery. 2010:1511-4. exclusion reason - not relevant. [pmid: 20306199].
305 Clark M. Pressure sore treatment. 2. Evidence of effectiveness. Journal of Wound Care. 1997:400-2. exclusion reason - no original data. [pmid: 9341434].
306 Clark M. Models of pressure ulcer care: Costs and outcomes. British Journal of Healthcare Management. 2001:412-416. exclusion reason - wrong intervention.
307 Clark M. Guidelines for seating in pressure ulcer prevention and management. Nursing Times. 2009:40-1. exclusion reason - background. [pmid: 19480169].
308 Clark M. Evidence in wound prevention and treatment: Are the ‘rules’ too hard?. Journal of Tissue Viability. 2010:85. exclusion reason - background. [pmid: 20699188].
309 Clark M, Schols JMGA, Benati G, Jackson P, Engfer M, Langer G, Kerry B, Colin D. P European Pressure Ulcer Advisory. Pressure ulcers and nutrition: A new european guideline. Journal of Wound Care. 2004:267-72. exclusion reason - background. [pmid: 15977767].
310 Clark M, DIP. A randomised controlled trial comparing the healing of pressure sores upon two pressure-redistributing seat cushions. Proceedings of the 7th European European Conference on Advances in Wound Management. 1997. exclusion reason - duplicate.
311 Clark MD. A randomised controlled trial comparing the healing of pressure sores upon two pressure-redistributing seat cushions. Proceedings of the 7th European Conferences on Advances in Wound Management. Harrogate, UK. 1998:122-5. exclusion reason - no original data.
312 Clegg A, Richbourg L. Multi-site heel ulcer study conducted by nc woc nurses... Scientific and clinical abstracts from the 40th annual wound, ostomy and continence nurses annual conference. Journal of Wound, Ostomy & Continence Nursing. 2008:S61-2. exclusion reason - wrong outcome.
313 Clegg JP, Guest JF. Modelling the cost-utility of bio-electric stimulation therapy compared to standard care in the treatment of elderly patients with chronic non-healing wounds in the uk. Current Medical Research and Opinion. 2007:871-883. exclusion reason - wrong outcome. [pmid: 17407644].
314 Coerper S, Gottwald G, Beckert S, Becker HD. Wound healing and wound treatment 2004 -- the current state... First published in german in zeitung fur wundheilung in 2004 vol 9;1:20–3. EWMA Journal. 2005:4. exclusion reason - background.
315 Coggrave M, West H, Leonard B. Topical negative pressure for pressure ulcer management. British Journal of Nursing. 2002:S29-36. exclusion reason - not relevant. [pmid: 11979189].
316 Colin D. Trials with a new non-stick dressing. Revue de Geriatrie. 1988:199-201. exclusion reason - not relevant.
317 Colin D, Kurring PA, Quinlan D, Yvon C. The clinical investigation of an amorphous hydrogel compared with a dextranomer paste dressing in the management of sloughy pressure sores. Proceedings of the 5th European Conference on Advances in Wound Management. 1995. exclusion reason - no original data.
318 Collins N. Anabolic agents and wound healing. Advances in Skin & Wound Care. 2001:154-5. exclusion reason - no original data. [pmid: 11905983].
319 Collins N. Arginine and wound healing. Advances in Skin & Wound Care. 2001:16-7. exclusion reason - no original data. [pmid: 11905451].
320 Collins N. Tube feeding and pressure ulcers. Advances in Skin & Wound Care. 2001:72-3. exclusion reason - no original data. [pmid: 11899909].
321 Collins N. Vitamin c and pressure ulcers. Advances in Skin & Wound Care. 2002:186. 188. exclusion reason - no original data. [pmid: 12151986].
322 Collins N. Zinc supplementation: Yea or nay?. Advances in Skin & Wound Care. 2003:226-30. exclusion reason - no original data. [pmid: 14581813].
323 Collins N. Diarrhea and wound healing. Advances in Skin & Wound Care. 2003:175-6. exclusion reason - no original data. [pmid: 12897673].
324 Collins N. Vegetarian diets and wound healing. Advances in Skin & Wound Care. 2003:65-6. exclusion reason - no original data. [pmid: 12690229].
325 Collins N. Adding vitamin c to the wound management mix. Advances in Skin & Wound Care. 2004:109-12. exclusion reason - wrong intervention. [pmid: 15194971].
326 Collins N. The right mix: Using nutritional interventions and an anabolic agent to manage a stage iv ulcer. Advances in Skin & Wound Care. 38. 2004:36-9. exclusion reason - not relevant. [pmid: 14752325].
327 Compagno G, DTP. The use of a hyperproteinic integrator in pressure ulcers management. [abstract]. 13th Conference of the European Wound Management Association. 2003. exclusion reason - no original data.
328 Conforti C. Pressure sores: Dressed for successful healing. Nursing. 1989:58-61. exclusion reason - no original data. [pmid: 2927763].
329 Conner-Kerr T, Isenberg RA. Retrospective analysis of pulsed radiofrequency energy therapy use in the treatment of chronic pressure ulcers. Advances in skin & wound care. 2012:253-60. exclusion reason - wrong intervention. [pmid: 22610109].
330 Consortium for Spinal Cord Medicine Clinical Practice, G. Pressure ulcer prevention and treatment following spinal cord injury: A clinical practice guideline for health-care professionals. Journal of Spinal Cord Medicine. 2001:S40-101. exclusion reason - background. [pmid: 11958176].
331 Cooper PJ, Gray DG, Mollison J. A randomised controlled trial of two pressure-reducing surfaces. Journal of Wound Care. 1998:374-376. exclusion reason - wrong population. [pmid: 9832744].
332 Cooper SM, Young E. Topical negative pressure in the treatment of pressure ulcers. Journal of the American Academy of Dermatology. 1999:280. exclusion reason - no original data. [pmid: 10426905].
333 Cooper SM, Young E. Topical negative pressure. International Journal of Dermatology. 2000:896-8. exclusion reason - no original data. [pmid: 11168656].
334 Cope C, Barry P, Hassall M, Barnett R, Richards M, Vandervord J. V-y advancement hamstring myocutaneous island flap repair of ischial pressure ulcers. Australian & New Zealand Journal of Surgery. 1995:412-6. exclusion reason - not relevant. [pmid: 7786266].
335 Corbi Y. prevention and treatment of bedsores. At each stage a precise therapeutic intervention and an adjusted nursing process. Soins; La Revue de Reference Infirmiere. 1995:29-32. exclusion reason - not relevant. [pmid: 7725136].
336 Corbyn C, Rush A. Challenges of wound management in bariatric patients. Wounds UK. 2010:62-71. exclusion reason - no original data.
337 Correa GI, Calderon WO, Burnier LA, Danilla SE, Roa RG, Guzman LM. Proximal amputation of inferior extremity secondary to recurrent pressure ulcers in patients with spinal cord injuries. [erratum appears in spinal cord. 2008 jul;46(7):530]. Spinal Cord. 2008:135-9. exclusion reason - not relevant. [pmid: 17607312].
338 Coskunfirat OK, Ozgentas HE. Gluteal perforator flaps for coverage of pressure sores at various locations. Plastic & Reconstructive Surgery. 2004:2012-7. discussion 2018–9. exclusion reason - not relevant. [pmid: 15253191].
339 Court-Tillis D. Critical path network. Skin flap path incorporates 30-day los for rehabilitation. Hospital Case Management. 1996:135-138. exclusion reason - not relevant. [pmid: 10160149].
340 Coutts P, Sibbald RG, Inman K, Maltby-Stephens N. The use of an adhesive hydrocellular foam compared to a hydrocolloid dressing for the treatment of stage ii and iii pressure ulcers. 13th Annual Symposium on Advanced Wound Care and 10th Annual Medical Research Forum on Wound Repair. 2000. exclusion reason - not relevant.
341 Cox-Martin B, Shaw P. Development of an outreach service to promote surgical/non-surgical treatment of pressure ulcers. Wounds UK. 2010:54-64. exclusion reason - not relevant.
342 Craig LD, Nicholson S, Silverstone FA, Kennedy RD. Use of a reduced-carbohydrate, modified-fat enteral formula for improving metabolic control and clinical outcomes in long-term care residents with type 2 diabetes: Results of a pilot trial. Nutrition. 1998:529-534. exclusion reason - wrong outcome. [pmid: 9646297].
343 Crowe T, Brockbank C. Nutrition therapy in the prevention and treatment of pressure ulcers. Wound Practice & Research. 2009:90. exclusion reason - no original data.
344 Cruse JM, Wang H, Lewis RE, Cespedes J, Morrison RS III, Lineaweaver WC, Dilioglou S. Cellular and molecular alterations in spinal cord injury patients with pressure ulcers: A preliminary report. Experimental and Molecular Pathology. 2002:124-131. exclusion reason - background. [pmid: 11890721].
345 Cubit K. Get behind it! Sacral dressing may prevent pressure injury in ‘at risk’ medical patients. exclusion reason - Scientific Information Packets, not directly used.
346 Cuddigan J, Dealey C, Langemo D. International pressure ulcer prevention and treatment guidelines. exclusion reason - background.
347 Cullen A. Spinal cord injury: Using maggots to ease the pressure. Wounds UK. 2009:82. exclusion reason - wrong intervention.
348 Cullum N, Deeks J, Sheldon TA, Song F, Fletcher AW. Beds, mattresses and cushions for pressure sore prevention and treatment. Journal of Tissue Viability. 1999:138. exclusion reason - Systematic Review, not directly used. [pmid: 10808844].
349 Cullum N, Nelson EA, Flemming K, Sheldon T. Systematic reviews of wound care management: (5) beds; (6) compression; (7) laser therapy, therapeutic ultrasound, electrotherapy and electromagnetic therapy. Health Technology Assessment (Winchester, England). 2001:1-221. exclusion reason - Systematic Review, not directly used. [pmid: 11368833].
350 Cullum N, Petherick E. Pressure ulcers. Clinical Evidence. 2008. exclusion reason - Systematic Review, not directly used. [pmid: 19450317].
351 Cutler NR, Seifert RD, Sramek JJ, Boyd WM, St Clair P. Fleroxacin treatment of stage iv pressure ulcers with associated osteomyelitis. Annals of Pharmacotherapy. 1994:117-8. exclusion reason - no original data. [pmid: 8123950].
352 Cutting KF. Revising wound dressing classification. Wounds UK. 2011:135. exclusion reason - Scientific Information Packets, not directly used.
353 Cuzzoni G, Ferrero E. The treatment of severe pressure sores in the elderly. Rivista Italiana di Chirurgia Plastica. 1993:361-367. exclusion reason - not relevant.
354 D’Agostino DiasM, Fontes B, Poggetti RS, Birolini D. Hyperbaric oxygen therapy: Types of injury and number of sessions-review of 1506 cases. Undersea & Hyperbaric Medicine. 2008:53-60. exclusion reason - wrong population. [pmid: 18351127].
355 Dalla ValleI, Ferrari MP, Lia C. Anallergic, sterilized lyophilized heterologous collagen and its effect in the treatment of neurogenic decubitus ulcers. Riabilitazione. 1985:37-53. exclusion reason - not relevant.
356 Danon D, Frenkel O, Diamandstein L, Winkler E, Orenstein A. Macrophage treatment of pressure sores in paraplegia. Journal of Wound Care. 1998:281-3. exclusion reason - not relevant. [pmid: 9697460].
357 Darouiche RO, Landon GC, Klima M, Musher DM, Markowski J. Osteomyelitis associated with pressure sores. Archives of Internal Medicine. 1994:753-8. exclusion reason - wrong intervention. [pmid: 8147679].
358 Darvall A. Multi-disciplinary approach to pressure ulcer management in the spinal cord injury population. 2008. exclusion reason - not relevant.
359 Dat AD, Poon F, Pham BTK, Doust J. Aloe vera for treating acute and chronic wounds. Cochrane Database of Systematic Reviews. 2012. exclusion reason - Systematic Review, not directly used.
360 Davidson J, Eremic LW. Critical care extra. Visible wounds. American Journal of Nursing. 2000:24AA. exclusion reason - wrong intervention.
361 Davies P, Rippon M. Evidence review: The clinical benefits of safetacrg technology in wound care. Ostomy Wound Management. 2008:4-31. exclusion reason - unable to find.
362 de Azevedo IB, Sampaio RF, Montes JC, Contreras RL. treatment of decubitus ulcers with propolis. Revista Brasileira de Enfermagem. 1986:33-7. exclusion reason - not relevant. [pmid: 3648838].
363 de la Fuente SG, Levin LS, Reynolds JD, Olivares C, Pappas TN, Ludwig KA, Mantyh CR. Elective stoma construction improves outcomes in medically intractable pressure ulcers. Diseases of the Colon & Rectum. 2003:1525-30. exclusion reason - wrong intervention. [pmid: 14605574].
364 de la Fuente TP, Gonzalez IG, Munoz FC. The igap flap for ischial pressure sore reconstruction in tetraplegic patients. International Journal Of Surgery. 2008:e1-e3. exclusion reason - no original data. [pmid: 19059123].
365 De Laat E, Van Achterberg T. Diagnostics and interventions aimed at wound-related complaints in patients with pressure ulcers: A review of the literature. 16th international nursing research congress.: Sigma Theta Tau International. 2005. 1p. exclusion reason - Systematic Review, not directly used.
366 de Laat EHEW, Scholte op Reimer WJ, van Achterberg T. Pressure ulcers: Diagnostics and interventions aimed at wound-related complaints: A review of the literature. Journal of Clinical Nursing. 2005:464-72. exclusion reason - Systematic Review, not directly used. [pmid: 15807753].
367 de Laat EHEW, van den Boogaard MHWA, Spauwen PHM, van Kuppevelt DHJM, van Goor H, Schoonhoven L. Faster wound healing with topical negative pressure therapy in difficult-to-heal wounds: A prospective randomized controlled trial. Annals of Plastic Surgery. 2011:626-31. exclusion reason - not relevant. [pmid: 21629111].
368 de Leon J. Negative pressure wound therapy in pressure ulcer management. Ostomy Wound Management. 2005:3S-8S. exclusion reason - not relevant. [pmid: 15699557].
369 De Luis Roman D, Aller R. Systematic review of nutricional support in pressure ulcer. Anales de Medicina Interna. 2007:342-345. exclusion reason - not relevant. [pmid: 18020893].
370 Dealey C. A prevention and management aid. Evaluation of the nimbus ii mattress. Professional Nurse. 1994:798-804. exclusion reason - no original data. [pmid: 7938061].
371 Dealey C. Pressure sores and incontinence: A study evaluating the use of topical agents in skin care. Journal of Wound Care. 1995:103-5. exclusion reason - wrong population. [pmid: 7600345].
372 Dealey C, Brooks R, Thomson J, Bliss MR. Pressure area care and estimating the cost of pressure sores. Journal of Wound Care. 1997:134-8. exclusion reason - no original data. [pmid: 9256710].
373 Dealey C, KA. A randomized, controlled, parallel-group clinical trial of a new polyurethane foam island dressing versus a hydrocolloid island dressing in the treatment of grade ii and iii pressure sores. Proceedings of the 6th European Conference on Advances in Wound Management. 1995. exclusion reason - no original data.
374 Defloor T. less frequent turning intervals and yet less pressure ulcers. Tijdschrift voor Gerontologie en Geriatrie. 2001:174-7. exclusion reason - not relevant. [pmid: 11565421].
375 DeHart D. Osteomyelitis associated with pressure sores. Archives of Internal Medicine. 1994:2501. exclusion reason - no original data. [pmid: 7979847].
376 Delemarle D, Nadaud F. a joint physical therapy-nursing intervention. Soins; La Revue de Reference Infirmiere. 2006:26. exclusion reason - not relevant. [pmid: 16771284].
377 deLeon JM, Nagel M, Fudge M, Lucius A, Garcia B. Use of radiofrequency and negative pressure wound therapy in chronic pressure ulcers. 3rd Congress of the World Union of Wound Healing Societies. 2008. exclusion reason - no original data.
378 DelGiorno TG Jr, Gross CP. Advisor forum. Minoxidil for poorly healing ulcers?. Clinical Advisor for Nurse Practitioners. 2004:75-75. exclusion reason - no original data.
379 Demirseren ME, Gokrem S, Ozdemir OM, Katircioglu A, Can Z, Serel S. Hatchet-shaped tensor fascia lata musculocutaneous flap for the coverage of trochanteric pressure sores: A new modification. Annals of Plastic Surgery. 2003:419-22. exclusion reason - not relevant. [pmid: 14520072].
380 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986/09/01. 1986:177-88. exclusion reason - background. [pmid: 3802833].
381 Deshmukh GR, Barkel DC, Sevo D, Hergenroeder P. Use or misuse of colostomy to heal pressure ulcers. Diseases of the Colon & Rectum. 1996:737-8. exclusion reason - wrong intervention. [pmid: 8674363].
382 Desneves K. Effect of an arginine-containing supplement on the healing of pressure ulcers in community spinal patients. 2010. Conference of the Australian Wound Management Association (AWMA 2010). 2010. [pmid: 20616774]. exclusion reason - not relevant.
383 Deva AK, Buckland GH, Fisher E, Liew SCC, Merten S, McGlynn M, Gianoutsos MP, Baldwin MAR, Lendvay PG. Topical negative pressure in wound management. Medical Journal of Australia. 2000:128-131. exclusion reason - not relevant. [pmid: 10979377].
384 Di DomenicoG, Leonardi GM, Mottola M, Vaccaro G, Nocera C. Platelet gel and wound care: The weight of the platelets concentration in the cliniciantherapeutic practice. Vox Sanguinis. 2009:249. exclusion reason - not relevant.
385 Di Giulio P. topical treatment of decubitus lesions. Rivista dell Infermiere. 1985:35-47. exclusion reason - not relevant. [pmid: 3933085].
386 Di GiulioP, Saiani L, Laquintana D, Palese A, Perli S, Andreatta M, Rosa F, Chini P, Soraperra F, Ventura I, Suriani C, Romani S, Zancarli M, Martini M, Partel F, Bassetti S, Kaisermann R, Bortolotti C, Gianordoli M, Rizzoli I, Nardelli R, Pellizzari E, Valduga E, Castaman M, Pordenon M, Beltrame M, Bertolo C, Casasola E, Del Pin P, Giolo S, Marcatti E, Pecini D, Rodaro M, Zanon C, Stefanon L, Covre L, Babbo C, Martin I, Roilo A, Zanutel M, Sabbadin S, Boin L, Caron A, Martignago E, Venturin V, Greggio A, Frigo P, Lazzaron D, Tonietto A, Zanin B, Zorzi S, Zuanon A, Salmaso D, Frison T, Marin I, Buosi A, Fiorese E, Gasparin D, Goat B, Saccardo G, Simonetto O, Gomiero S, Baccara N, Ghirardello L, Niolu M, Silvestri S, Buffon ML, Casson P, Santantonio R, Albore P, Mazzorana E, Terziariol L, Bulgarelli G, Barani E, Gasparini P, Migliori S, Sasso E, Marfisi RM, Tognoni G, Sgaroni G, Noro G, Mattiuzzo M, Gruppo P-E. a double blind randomised clinical trial to assess the efficacy of the treatments of the superficial pressure sores. Assistenza Infermieristica e Ricerca Air. 2004:201-8. exclusion reason - not relevant. [pmid: 15709463].
387 Diamant-Berger F, Kerangall C. treatment of bedsores and trophic wounds with an absorbent dressing. Soins; La Revue de Reference Infirmiere. 1990:53-8. exclusion reason - not relevant. [pmid: 2326677].
388 Diaz Caro I. specific treatment of sacrococcygeal ulcers. Revista de Enfermeria. 2003:54-60. exclusion reason - not relevant. [pmid: 14502916].
389 Diekmann JM, Smith JM, Wilk JR. A double life for a dental irrigation device. American Journal of Nursing. 1985:1157. exclusion reason - no original data. [pmid: 3850722].
390 Disa JJ, Carlton JM, Goldberg NH. Efficacy of operative cure in pressure sore patients. Plastic & Reconstructive Surgery. 1992:272-8. exclusion reason - not relevant. [pmid: 1732895].
391 Dissemination, C. f. R. a. Why appraise the evidence: A case study of vitamin c and the healing of pressure sores (structured abstract). Database of Abstracts of Reviews of Effects. 2011. exclusion reason - Systematic Review, not directly used.
392 Dissemination, C. f. R. a. Treatment of pressure ulcers: A systematic review (structured abstract). Database of Abstracts of Reviews of Effects. 2011. exclusion reason - Systematic Review, not directly used.
393 Dissemination, C. f. R. a. A systematic review of the use of hydrocolloids in the treatment of pressure ulcers (structured abstract). Database of Abstracts of Reviews of Effects. 2011. exclusion reason - Systematic Review, not directly used.
394 Dissemination, C. f. R. a. Systematic review of repositioning for the treatment of pressure ulcers (brief record). Database of Abstracts of Reviews of Effects. 2011. exclusion reason - Systematic Review, not directly used.
395 Dissemination, C. f. R. a. A literature assessment of the use of miscellaneous topical agents, growth factors, and skin equivalents for the treatment of pressure ulcers (structured abstract). Database of Abstracts of Reviews of Effects. 2011. exclusion reason - Systematic Review, not directly used.
396 Dissemination, C. f. R. a. Enteral nutritional support in prevention and treatment of pressure ulcers: A systematic review and meta-analysis (structured abstract). Database of Abstracts of Reviews of Effects. 2011. exclusion reason - Systematic Review, not directly used.
397 Dissemination, C. f. R. a. Efficiency of the products for pressure ulcers treatment: A systematic review with meta-analysis (provisional abstract). Database of Abstracts of Reviews of Effects. 2011. exclusion reason - Systematic Review, not directly used.
398 Dissemination, C. f. R. a. Efficacy of advanced dressings in the treatment of pressure ulcers: A systematic review (structured abstract). Database of Abstracts of Reviews of Effects. 2011. exclusion reason - Systematic Review, not directly used.
399 Dissemination, C. f. R. a. Beds, mattresses and cushions for pressure sore prevention and treatment (brief record). Database of Abstracts of Reviews of Effects. 2011. exclusion reason - Systematic Review, not directly used.
400 Dissemination, C. f. R. a. Air-fluidized beds used for treatment of pressure ulcers in the home environment (structured abstract). Database of Abstracts of Reviews of Effects. 2011. exclusion reason - Systematic Review, not directly used.
401 Dissemination, C. f. R. a. The effectiveness of topical negative pressure in the treatment of pressure ulcers: A literature review (structured abstract). Database of Abstracts of Reviews of Effects. 2011. exclusion reason - background.
402 Dobson JL, Ellis SL. Creating an optimum healing environment for a grade v pressure ulcer. Journal of Wound Care. 2001:415-20. exclusion reason - not relevant. [pmid: 12964290].
403 Dolezal R, Cohen M, Schultz RC. The use of clinitron therapy unit in the immediate postoperative care of pressure ulcers. Annals of Plastic Surgery. 1985:33-6. exclusion reason - wrong outcome. [pmid: 3977238].
404 Doss M, Martens S, Wood JP, Wolff JD, Baier C, Moritz A. Vacuum-assisted suction drainage versus conventional treatment in the management ofpoststernotomy osteomyelitis. European Journal of Cardio-Thoracic Surgery. 2002:934-938. exclusion reason - wrong population. [pmid: 12467816].
405 Downs SH, Black N. The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions. JECH. 1998:377-384. exclusion reason - background. [pmid: 9764259].
406 Drimmer MA, Krasna MJ. The vastus lateralis myocutaneous flap. Plastic & Reconstructive Surgery. 1987:560-6. exclusion reason - not relevant. [pmid: 3823248].
407 Droste LR. Pressure ulcer prevention and treatment for high risk polytrauma, spinal cord injured and acute care patients: Practice innovation using an alternating support surface advanced features. Scientific and clinical abstracts from the 40th annual wound, ostomy and continence nurses annual conference. Journal of Wound, Ostomy & Continence Nursing. 2008:S35-S35. exclusion reason - wrong population.
408 Dumurgier C, Cottias P, Pujol G, Lantieri L, Gandon F, Rochebiliere A. The invaldes’ hospital flap: A report on 48 patients. Lyon Chirurgical. 1993:433-437. exclusion reason - not relevant.
409 Dzidic I. usefulness of the roho mattress in the prevention and therapy of decubitus ulcers. Reumatizam. 1991:75-6. exclusion reason - not relevant. [pmid: 1806965].
410 Dzwierzynski WW, Spitz K, Hartz A, Guse C, Larson DL. Improvement in resource utilization after development of a clinical pathway for patients with pressure ulcers. Plastic & Reconstructive Surgery. 1998:2006-11. exclusion reason - not relevant. [pmid: 9810998].
411 Economides NG, Skoutakis VA, Carter CA, Smith VH. Evaluation of the effectiveness of two support surfaces following myocutaneous flap surgery. Advances in Wound Care. 1995:49-53. exclusion reason - wrong population. [pmid: 7795873].
412 Edsberg LE, Brogan MS, Jaynes CD, Fries K. Reducing epibole using topical hyperbaric oxygen and electrical stimulation. Ostomy Wound Management. 2002:26-9. exclusion reason - not relevant. [pmid: 11993057].
413 Eginton MT, Brown KR, et al. A prospective randomized evaluation of negative-pressure wound dressings for diabetic foot wounds. Annals of Vascular Surgery. 2003:645-649. exclusion reason - wrong population. [pmid: 14534844].
414 Elizarov MN, Garkavi AV, Komissarova AL. Treatment of purulent-necrotic decubitus ulcers in spinal patients using alginate coating teralgim and algimaf. Sovetskaya Meditsina. 1991:25-26. exclusion reason - not relevant. [pmid: 1715609].
415 Elizarov MN, Garkavi AV, Sen’kevich SI. treatment of decubitus ulcer by “algimaf” preparation. Ortopediia Travmatologiia i Protezirovanie. 1990:47-8. exclusion reason - not relevant. [pmid: 2093864].
416 El-Sabbagh AH. The accordion gracilis muscle flap: A new design for coverage of recurrent and complicated ischeal pressure sores. International Wound Journal. 2011. exclusion reason - not relevant. [pmid: 21595831].
417 Eltorai I, Glantz G, Montroy R. The use of the carbon dioxide laser beam in the surgery of pressure sores. International Surgery. 1988:54-6. exclusion reason - wrong intervention. [pmid: 3360579].
418 Esch B, Raptis G. treatment of decubitus ulcer with crilanomer and dextranomer. Zeitschrift fur Hautkrankheiten. 1989:1135-8. exclusion reason - not relevant. [pmid: 2483786].
419 Eshaque AK, Nahar N. Management of sacral pressure sores with a myocutaneous flap. Contemporary Orthopaedics. 1994:353-6. exclusion reason - not relevant. [pmid: 10146777].
420 Esmaili R, Zadeh E, Nasiri E, Khalilian A, Dehghani O, Alipour S. Study regarding the effect of calendula officinal is cream in healing of pressure sores. 16th International Conference of Indian Association of Palliative Care (IAPCON 2009). exclusion reason - not relevant.
421 Esposito G, Di Caprio G, Ziccardi P, Scuderi N. Tissue expansion in the treatment of pressure ulcers. Plastic & Reconstructive Surgery. 1991:501-8. exclusion reason - not relevant. [pmid: 1998020].
422 Esposito G, Ziccardi P, Di Caprio G, Scuderi N. Reconstruction of ischial pressure ulcers by skin expansion. Scandinavian Journal of Plastic & Reconstructive Surgery & Hand Surgery. 1993:133-6. exclusion reason - not relevant. [pmid: 8351494].
423 European Pressure Ulcer Advisory Panel and National Pressure Ulcer Advisory Panel. Prevention and treatment of pressure ulcers: Quick reference guide. Washington, DC. National Pressure Ulcer Advisory Panel. 2009. exclusion reason - background.
424 Evans GR, Dufresne CR, Manson PN. Surgical correction of pressure ulcers in an urban center: Is it efficacious?. Advances in Wound Care. 1994:40-6. exclusion reason - not relevant. [pmid: 8149047].
425 Evans GR, Lewis VL Jr, Manson PN, Loomis M, Vander Kolk CA. Hip joint communication with pressure sore: The refractory wound and the role of girdlestone arthroplasty. Plastic & Reconstructive Surgery. 1993:288-94. exclusion reason - not relevant. [pmid: 8430143].
426 Evans JM, Andrews KL, Chutka DS, Fleming KC, Garness SL. Pressure ulcers: Prevention and management. Mayo Clinic Proceedings. 1995:789-99. exclusion reason - background. [pmid: 7630221].
427 EWMA. Systematic review of repositioning for the treatment of pressure ulcers. EWMA Journal. 2010:5-12. exclusion reason - Systematic Review, not directly used.
428 Feedar JA, Kloth LC, Gentzkow GD. Chronic dermal ulcer healing enhanced with monophasic pulsed electrical stimulation. Physical Therapy. 1991:639-49. exclusion reason - not relevant. [pmid: 1881954].
429 Ferrell BA, Artinian BM, Sessing D. The sessing scale for assessment of pressure ulcer healing. Journal of the American Geriatrics Society. 1995:37-40. exclusion reason - background. [pmid: 7806737].
430 Ferrell BA, Keeler E, Siu AL, Ahn SH, Osterweil D. Cost-effectiveness of low-air-loss beds for treatment of pressure ulcers. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 1995:M141-6. exclusion reason - background. [pmid: 7743399].
431 Finnegan MJ, Gazzerro L, Finnegan JO, Lo P. Comparing the effectiveness of a specialized alternating air pressure mattress replacement system and an air-fluidized integrated bed in the management of post-operative flap patients: A randomized controlled pilot study. Journal of Tissue Viability. 2008:2-9. exclusion reason - wrong population. [pmid: 18293765].
432 Flemister BG. A pilot study of interface pressure with heel protectors used for pressure reduction. Journal of ET Nursing. 1991:158-61. exclusion reason - wrong population. [pmid: 1892946].
433 Flemming K, Cullum N. Therapeutic ultrasound for pressure sores. Cochrane Database of Systematic Reviews. 2000:CD001275. exclusion reason - Systematic Review, not directly used. [pmid: 11034707].
434 Fleurence RL. Cost-effectiveness of pressure-relieving devices for the prevention and treatment of pressure ulcers. International Journal of Technology Assessment in Health Care. 2005:334-41. exclusion reason - background. [pmid: 16110713].
435 Foglia E, Restelli U, Napoletano AM, Coclite D, Porazzi E, Bonfanti M, Croce D. Pressure ulcers management: An economic evaluation. Journal of Preventive Medicine and Hygiene. 2012:30-36. exclusion reason - unable to find. [pmid: 22803317].
436 Fox GN. Management of pressure ulcers. JAMA. 2003:2210. author reply 2210–1. exclusion reason - no original data. [pmid: 12734129].
437 Francis KD, Hendler SL, Byrne EF. Semirigid dressings for treatment of pressure sores after spinal cord injury. Archives of Physical Medicine and Rehabilitation World Meeting. 1991. exclusion reason - unable to find.
438 Franek A, Franek E, Grzesik J. electrically enhanced damaged tissues healing. Part ii: Direct and pulse current in soft tissue healing. Polski Merkuriusz Lekarski. 1999:198-201. exclusion reason - not relevant. [pmid: 10835915].
439 Franek A, Kostur R, Polak A, Taradaj J, Szlachta Z, Blaszczak E, Dolibog P, Dolibog P, Koczy B, Kucio C. Using high-voltage electrical stimulation in the treatment of recalcitrant pressure ulcers: Results of a randomized, controlled clinical study. Ostomy Wound Management. 2012:30-44. exclusion reason - wrong intervention. [pmid: 22391955].
440 Franek A, Kostur R, Taradaj J, Blaszczak E, Szlachta Z, Dolibog P, Dolibog P, Polak A. Effect of high voltage monophasic stimulation on pressure ulcer healing: Results from a randomized controlled trial. Wounds: A Compendium of Clinical Research & Practice. 2011:15-23. exclusion reason - wrong intervention.
441 Franek A, Kostur R, Taradaj J, Blaszczak E, Szlachta Z, Dolibog P, Dolibog P, Polak A. Effect of high voltage monophasic stimulation on pressure ulcer healing: Results from a randomized controlled trial. Wounds: A Compendium of Clinical Research & Practice. 2011:15-23. exclusion reason - wrong intervention.
442 Frank GC. Wound care means nutritional care. Advance for Long-Term Care Management. 2010:32. exclusion reason - background.
443 Franks PJ. The cost of pressure ulceration. EWMA Journal. 2007:15. exclusion reason - wrong intervention.
444 Frantz R. The effect of tens on healing of pressure ulcers. 4th Annual Meeting of the Wound Healing Society. 1994. exclusion reason - no original data.
445 Frantz RA. Pressure ulcer costs in long term care. Decubitus. 1989:56-7. exclusion reason - wrong intervention. [pmid: 2505809].
446 Frantz RA, Bergquist S, Specht J. The cost of treating pressure ulcers following implementation of a research-based skin care protocol in a long-term care facility. Advances in Wound Care. 1995:36-45. exclusion reason - wrong outcome. [pmid: 7795870].
447 Frantz RA, Gardner S, Harvey P, Specht J. The cost of treating pressure ulcers in a long-term care facility. Decubitus. 1991:37-8. 40. 42 passim. exclusion reason - wrong intervention. [pmid: 1908247].
448 Frantz RA, Gardner S, Specht JK, McIntire G. Integration of pressure ulcer treatment protocol into practice: Clinical outcomes and care environment attributes. Outcomes Management for Nursing Practice. 2001:112-20. exclusion reason - no original data. [pmid: 11898671].
449 Fratino L. Treatment of decubitus ulcers and of venous ulcer with intralesion mielogen in elderly patients with or without cancer. ESMO Congress Secretariat. Soldino 22, 6900 Lugano, Switzerland. 1998. exclusion reason - wrong population.
450 Freedman G, Cean C, Duron V, Tarnovskaya A, Brem H. Pathogenesis and treatment of pain in patients with chronic wounds. Surgical Technology International. 2003:168-79. exclusion reason - wrong population. [pmid: 12931299].
451 French ET, Ledwell-Sifner K. method of documentation in decubitus. Decubitus protocol allows for more effective treatment. Krankenpflege - Soins Infirmiers. 1992:10-4. exclusion reason - not relevant. [pmid: 1740912].
452 Frias SorianoL, Lage Vazquez MA, Maristany CP-P, Xandri Graupera JM, Wouters-Wesseling W, Wagenaar L. The effectiveness of oral nutritional supplementation in the healing of pressure ulcers. Journal of Wound Care. 2004:319-22. exclusion reason - not relevant. [pmid: 15469215].
453 Frisbie JH. Wound healing in acute spinal cord injury: Effect of anticoagulation. Archives of Physical Medicine & Rehabilitation. 1986:311-3. exclusion reason - not relevant. [pmid: 3707315].
454 Fromantin I, Routkovsky-Norval C. decubitus ulcers in oncology, first results of a study. Soins; La Revue de Reference Infirmiere. 2003:22-3. exclusion reason - not relevant. [pmid: 12724987].
455 Fromantin I, Teot L, Meaume S. a wound, wound healing ... And many ways to achieve this. Soins; La Revue de Reference Infirmiere. 2007:15-9. exclusion reason - not relevant. [pmid: 18335828].
456 Frykberg RG, Driver VR, Carman D, Lucero B, Borris-Hale C, Fylling CP, Rappl LM, Clausen PA. Chronic wounds treated with a physiologically relevant concentration of platelet-rich plasma gel: A prospective case series. Ostomy Wound Management. 2010:36-44. exclusion reason - wrong population. [pmid: 20567053].
457 Fu X, Shen Z, Chen Y. basic fibroblast growth factor (bfgf) and wound healing: A multi-centers and controlled clinical trial in 1024 cases. Chung-Kuo Hsiu Fu Chung Chien Wai Ko Tsa Chih/Chinese Journal of Reparative & Reconstructive Surgery. 1998:209-11. exclusion reason - not relevant. [pmid: 10437068].
458 Fuentelsaz GallegoC, Hernandez Faba E, Bermejo Caja C, Hermoso Villar P, Gallart Vive E, Blasco Garcia C, Cantalejo IB, Garcia JC, Cortes PC, Casbas TM, Yarnoz AZ, Catalan RA, Jimenez PC, Zerolo BE, Aguilar GE, Caminero GG, Pisa RML, Jimenez TM, Blanco EN, Soler RS. Review of literature on pressure ulcers in people aged 65 or over. Gerokomos. 2005:166-173. exclusion reason - not relevant.
459 Fugazza G, Bona F. decubitus ulcer in the calcaneus region: Rapid development, difficult recovery. Minerva Medica. 1996:89-92. exclusion reason - not relevant. [pmid: 8668293].
460 Furth P. example of standardized decubitus therapy (stage i–iii). Krankenpflege Journal. 1994:221-4. exclusion reason - not relevant. [pmid: 8028260].
461 Fuster PuigdomenechA, Moraleda Perez S, Fernandez Delgado J, Martinez Moreno M. Surgical treatment of bedsores in spinal cord lesions: Descriptive study. [spanish]. Rehabilitacion. 1999:316-320. exclusion reason - not relevant.
462 Gallois A, Dhelemme C, Lefebvre I, Fontalirand C, Richez S, Robert H. Comparative study of bed sores in a psychiatric hospital. Journal de Pharmacie Clinique. 1988:425-456. exclusion reason - not relevant.
463 Garber SL, Rintala DH. Pressure ulcers in veterans with spinal cord injury: A retrospective study. Journal of Rehabilitation Research & Development. 2003:433-41. exclusion reason - background. [pmid: 15080228].
464 Garber SL, Rintala DH, Rossi CD, Hart KA, Fuhrer MJ. Reported pressure ulcer prevention and management techniques by persons with spinal cord injury. Archives of Physical Medicine & Rehabilitation. 1996:744-9. exclusion reason - wrong intervention. [pmid: 8702366].
465 Garcia Fernandez FP, Martinez Cuervo F, Pancorbo Hidalgo PL, Rueda Lopez J, Santamaria Andres E, Soldevilla Agreda JJ, Verdu Soriano J. Debridement of pressure ulcers and other chronic wounds. Gerokomos. 2005:158-165. exclusion reason - not relevant.
466 Garcia Fernandez FP, Pancorbo Hidalgo PL, Verdu Soriano J, Soldevilla Agreda JJ, Rodriguez Palma M, Gago Fornells M, Martinez Cuervo F, Rueda Lopez J. Efficiency of the products for pressure ulcers treatment: A systematic review with meta-analysis. Gerokomos. 2007:36-48. exclusion reason - not relevant.
467 Gardner SE, Frantz RA, Bergquist S, Shin CD. A prospective study of the pressure ulcer scale for healing (push). Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2005:93-7. exclusion reason - wrong intervention. [pmid: 15741289].
468 Gardner SE, Frantz RA, Schmidt FL. Effect of electrical stimulation on chronic wound healing: A meta-analysis. Wound Repair & Regeneration. 1999:495-503. exclusion reason - Systematic Review, not directly used. [pmid: 10633009].
469 Garg M, Rubayi S, Montgomerie JZ. Postoperative wound infections following myocutaneous flap surgery in spinal injury patients. Paraplegia. 1992:734-9. exclusion reason - not relevant. [pmid: 1448302].
470 Gazzerro L, Finnegan M. Comparing the effectiveness of alternating air pressure mattress replacement systems and air fluidized integrated beds in the management of flap and graft patients: Ten case studies. Scientific and clinical abstracts from the 40th annual wound, ostomy and continence nurses annual conference. Journal of Wound, Ostomy & Continence Nursing. 2008:S63-S63. exclusion reason - no original data.
471 Genecov DG, Schneider AM, Morykwas MJ, et al. A controlled subatmospheric pressure dressing increases the rate of skin graft donor site reepithelialization. Annals of Plastic Surgery. 1998:219-25. exclusion reason - not relevant. [pmid: 9523602].
472 Genoud C, Weller J. protocol for the evaluation and treatment of chronic wounds in the home care setting. Praxis. 2008:317-21. exclusion reason - not relevant. [pmid: 18548939].
473 GENTILELLO L, THOMPSON DA, TONNESEN AS, HERNANDEZ D, KAPADIA AS, ALLEN SJ, HOUTCHENS BA, MINER ME. Effect of a rotating bed on the incidence of pulmonary complications in critically ill patients. Critical Care Medicine. 1988:783-786. exclusion reason - wrong population. [pmid: 3396372].
474 Gentzkow GD, Alon G, Taler GA, Eltorai IM, Montroy RE. Healing of refractory stage iii and iv pressure ulcers by a new electrical stimulation device. Wounds: A Compendium of Clinical Research & Practice. 1993:160-172. exclusion reason - wrong outcome.
475 George-Saintilus E, Tommasulo B, Cal CE, Hussain R, Mathew N, Dlugacz Y, Pekmezaris R, Wolf-Klein G. Pressure ulcer push score and traditional nursing assessment in nursing home residents: Do they correlate?. Journal of the American Medical Directors Association. 2009:141-4. exclusion reason - wrong intervention. [pmid: 19187884].
476 Gethin G. Right track. World of Irish Nursing & Midwifery. 2009:46-46. exclusion reason - no original data.
477 Gilchrist B. Using eggs to treat pressure sores. Nursing Times. 1990:72-72. exclusion reason - no original data.
478 Gilchrist B, Hutchinson J. Journal of the wound care society. Does occlusion lead to infection? Nursing Times. 1990:70-1. exclusion reason - no original data. [pmid: 2367232].
479 Gillespie C. Keeping pup on a short leash. Scientific and clinical abstracts from the 40th annual wound, ostomy and continence nurses annual conference. Journal of Wound, Ostomy & Continence Nursing. 2008:S38-S38. exclusion reason - no original data.
480 Giongo F, Biraghi M. New therapeutical prospects in the treatment of decubitus ulcers: The cadexomer iodine. Gazzetta Medica Italiana Archivio per le Scienze Mediche. 1991:67-73. exclusion reason - not relevant.
481 Girouard K, Harrison MB, VanDenKerkof E. The symptom of pain with pressure ulcers: A review of the literature. Ostomy Wound Management. 2008:30-40. 42. exclusion reason - Systematic Review, not directly used. [pmid: 18493092].
482 Gjersvik P. to cure chronic bed sores. Tidsskrift for Den Norske Laegeforening. 2005:867. exclusion reason - not relevant. [pmid: 15815731].
483 Glasco K, Rappl LM. Relating the support surface to improved wound healing and lower costs. 39th annual wound, ostomy and continence nurses annual conference. Journal of Wound, Ostomy & Continence Nursing. 2007:S58-S58. exclusion reason - no original data.
484 Glover D, Wicks G. Suprasorb x + phmb: The clinical evidence... Polyhexamethylene biguanide. Journal of Wound Care. 2009:15-21. exclusion reason - not relevant.
485 Gobbi P. patients admitted with decubital lesions: The experience of the milanese hospital in garbagnate. Assistenza Infermieristica e Ricerca Air. 2002:22-7. exclusion reason - not relevant. [pmid: 11998342].
486 Gogia. Effects of high voltage galvanic stimulation on wound healing. Ostomy Wound Manage. 1992:29-35. exclusion reason - wrong population.
487 Goldberg NH. Outcomes in surgical intervention. Advances in Wound Care. 1995:suppl 69-70. exclusion reason - not relevant. [pmid: 7627410].
488 Goldstein RD, Hall CD, Buzard RA. A simple method for improving skin graft take in patients on clinitron therapy. Plastic & Reconstructive Surgery. 1987:743. exclusion reason - not relevant. [pmid: 3313456].
489 Gonzalez JimenezF, Pareja Illeras M, Jimenez Lopez P, Carmona Sanchez M. how to evaluate nursing procedures for bedsores, or decubitus ulcers by means of a codified and computerized record-keeping system. Revista de Enfermeria. 2005:23-6. exclusion reason - not relevant. [pmid: 15768955].
490 Gonzalez MonterrubioG, Martin MMT, Gomez NM, Revilla Trujillo ER, Ruiz Pato J. Efficacy of a protocol treatment of decubitus ulcer in critical patients. [spanish]. Metas de Enfermería. 1998:27-33. exclusion reason - not relevant.
491 Gonzalez SarasuaJ, Perez Arias A, Fueyo Lorente A, Arranz JL, Alzaga FB, Campano JG. Choice of surgical techniques and the prevention of complications in the treatment of pressure sores. Cirugia Plastica Ibero-Latinoamericana. 1992:411-418. exclusion reason - no original data. [pmid: 18158437].
492 Gonzalez SarasuaJ, Perez Lopez S, Alvarez Viejo M, Perez Basterrechea M, Fernandez Rodriguez A, Ferrero Gutierrez A, Garcia Gala J, Menendez Menendez Y, Escudero Augusto D, Perez Arias A, Otero Hernandez J. Treatment of pressure ulcers with autologous bone marrow nuclear cells in patients with spinal cord injury. Journal of Spinal Cord Medicine. 2011:301-307. exclusion reason - wrong population. [pmid: 21756569].
493 Goodman CM, Cohen V, Armenta A, Thornby J, Netscher DT. Evaluation of results and treatment variables for pressure ulcers in 48 veteran spinal cord-injured patients. Annals of Plastic Surgery. 1999:665-72. exclusion reason - not relevant. [pmid: 10382806].
494 Gorecki C, Brown J, Lamping D, Madill A, Nixon J. Health-related quality of life in pressure ulceration: Development of a conceptual framework. 16th Annual Conference of the International Society for Quality of Life Research. New Orleans. 2009. [pmid: 20554279]. exclusion reason - no original data.
495 Gorecki C, Brown JM, Nelson EA, Briggs M, Schoonhoven L, Dealey C, Defloor T, Nixon J. Impact of pressure ulcers on quality of life in older patients: A systematic review: Clinical investigations. Journal of the American Geriatrics Society. 2009:1175-1183. exclusion reason - background. [pmid: 19486198].
496 Gorecki C, Nixon J, Madill A, Firth J, Brown JM. What influences the impact of pressure ulcers on health-related quality of life? A qualitative patient-focused exploration of contributory factors. Journal of tissue viability. 2012:3-12. exclusion reason - wrong outcome. [pmid: 22137874].
497 Goren D. Use of omiderm in treatment of low-degree pressure sores in terminally ill cancer patients. Cancer Nursing. 1989:165-9. exclusion reason - wrong population. [pmid: 2743299].
498 Gosnell DJ, Pontius C. A model of quality assurance for decubitus ulcer monitoring. Decubitus. 1988:24-9. exclusion reason - not relevant. [pmid: 3254241].
499 Gottrup F, Holstein P, Jorgensen B, Lohmann M, Karlsmar T. A new concept of a multidisciplinary wound healing center and a national expert function of wound healing. Archives of Surgery. 2001:765-72. exclusion reason - not relevant. [pmid: 11448387].
500 Gottwald C. improved management of decubitus ulcer is advantageous to the patient as well as to the economy. Pflege Zeitschrift. 2000:471-4. exclusion reason - not relevant. [pmid: 11022565].
501 Gould WL, Montero N, Cukic J, Hagerty RC, Hester TR. The split gluteus maximus musculocutaneous flap. Plastic & Reconstructive Surgery. 1994:330-6. exclusion reason - not relevant. [pmid: 8310025].
502 Governa M, Bortolani A, Piubello Q, Ghimenton C, Sanna A, Barisoni D. Spinocellular carcinoma arising from scars (marjolin ulcer): Our experience. Rivista Italiana di Chirurgia Plastica. 1994:151-156. exclusion reason - not relevant.
503 Gradon J, Adamson C. Infections of pressure ulcers: Management and controversies. Infectious Diseases in Clinical Practice. 1995:11-16. exclusion reason - background.
504 Granick MS, Eisner AN, Solomon MP. Surgical management of decubitus ulcers. Clinics in Dermatology. 1994:71-9. exclusion reason - background. [pmid: 8180947].
505 Granick MS, Ladin DA. The multidisciplinary in-hospital wound care team: Two models. Advances in Wound Care. 1998:80-3. exclusion reason - no original data. [pmid: 9729938].
506 Granick MS, Long CD. Outcome assessment of an in-hospital cross-functional wound care team. Plastic & Reconstructive Surgery. 2004:671-2. exclusion reason - no original data. [pmid: 14758234].
507 Granick MS, Posnett J, Jacoby M, Noruthun S, Ganchi PA, Datiashvili RO. Efficacy and cost-effectiveness of a high-powered parallel waterjet for wound debridement. Wound Repair & Regeneration. 2006:394-7. exclusion reason - wrong population. [pmid: 16939565].
508 Graves N, Ashby AE. The use of opal001 filtrate and cream in the treatment of chronic pressure ulcers. Wound Practice & Research. 2008:22. exclusion reason - not relevant.
509 Graves N, Birrell F, Whitby M. Effect of pressure ulcers on length of hospital stay. Infection Control & Hospital Epidemiology. 2005:293-297. exclusion reason - background. [pmid: 15796283].
510 Gray D. Pressure ulcer prevention and treatment: The transair range. British Journal of Nursing. 1999:454-8. exclusion reason - no original data. [pmid: 10531827].
511 Gray DG, Smith M. Comparison of a new foam mattress with the standard hospital mattress. Journal of Wound Care. 2000:29-31. exclusion reason - wrong outcome. [pmid: 10827665].
512 Gray M. Does oral zinc supplementation promote healing of chronic wounds?. Journal of Wound, Ostomy, & Continence Nursing. 2003:295-9. exclusion reason - background. [pmid: 14615757].
513 Gray M. Does oral supplementation with vitamins a or e promote healing of chronic wounds?. Journal of Wound, Ostomy, & Continence Nursing. 2003:290-4. exclusion reason - background. [pmid: 14615755].
514 Gray M. Context for woc practice. Pressure ulcer risk assessment, negative pressure wound therapy, and suprapubic catheters. Journal of Wound, Ostomy, & Continence Nursing. 2007:356-8. exclusion reason - no original data. [pmid: 17667081].
515 Gray M. Is larval (maggot) debridement effective for removal of necrotic tissue from chronic wounds?. Journal of Wound, Ostomy, & Continence Nursing. 2008:378-84. exclusion reason - Systematic Review, not directly used. [pmid: 18635985].
516 Gray M, Jones DP. The effect of different formulations of equivalent active ingredients on the performance of two topical wound treatment products. Ostomy Wound Management. 2004:34-8. 40. 42. 4. exclusion reason - no original data. [pmid: 15206088].
517 Gray M, Ratliff CR. Is hyperbaric oxygen therapy effective for the management of chronic wounds?. Journal of Wound, Ostomy, & Continence Nursing. 2006:21-5. exclusion reason - Systematic Review, not directly used. [pmid: 16444099].
518 Gray M, Whitney JD. Does vitamin c supplementation promote pressure ulcer healing?. Journal of Wound, Ostomy, & Continence Nursing. 2003:245-9. exclusion reason - background. [pmid: 14560282].
519 Greener M. Octenidine: Antimicrobial activity and clinical efficacy. Wounds UK. 2011:74-78. exclusion reason - wrong outcome.
520 Greer DM, Morris J, Walsh NE, Glenn AM, Keppler J. Cost-effectiveness and efficacy of air-fluidized therapy in the treatment of pressure ulcers. Journal of Enterostomal Therapy. 1988:247-51. exclusion reason - not relevant. [pmid: 3060503].
521 Greer SE, Argenta LC. Whither subatmospheric pressure dressing?. Annals of Plastic Surgery. 2000:332-336. exclusion reason - no original data. [pmid: 10987538].
522 Greer SE, Longaker MT, Margiotta M. Preliminary results from a multicenter, randomized, controlled study of the use of subatmospheric pressure dressing for pressure ulcer healing. Wound Repair and Regeneration. 1999:A255. exclusion reason - no original data.
523 Gregor S, Maegele M, Sauerland S, Krahn JF, Peinemann F, Lange S. Negative pressure wound therapy: A vacuum of evidence?. Archives of Surgery. 2008:189-96. exclusion reason - Systematic Review, not directly used. [pmid: 18283145].
524 Grimm A, Loos B, Horch RE. optimizing vacuum therapy in extensively undermined wounds. Zentralblatt fur Chirurgie. 2006:S19-23. exclusion reason - not relevant. [pmid: 16575639].
525 Grimm MR. Stage i pressure ulcers: Catching pressure injury before skin breakdown... Including commentary by ferris mtg. Corp. Ostomy Wound Management. 2009:10-10. exclusion reason - no original data.
526 Grinnell F, Toda K, Takashima A. Role of fibronectin in epithelialization and wound healing. Progress in Clinical & Biological Research. 1988:259-72. exclusion reason - wrong intervention. [pmid: 3289046].
527 Gross EB. New treatment option for wounds and pressure ulcers. 2008. exclusion reason - no original data.
528 Grosse W, Gerner HJ. mesalt--a new possibility for wound treatment in decubitus ulcer. Rehabilitation. 1985:100-2. exclusion reason - not relevant. [pmid: 4012022].
529 Gude D. Management of pressure ulcers - what is new?. Journal of Mid-life Health. 2011:91-2. exclusion reason - background. [pmid: 22408340].
530 Guihan M. Characteristics of veterans with sci hospitalized for the treatment of severe pressure ulcers. 52nd Annual Conference of American Paraplegia Society. Riviera Hotel, Las Vegas, Nevada. 2006. exclusion reason - no original data.
531 Guihan M, Garber SL, Bombardier CH, Durazo-Arizu R, Goldstein B, Holmes SA. Lessons learned while conducting research on prevention of pressure ulcers in veterans with spinal cord injury. Archives of Physical Medicine and Rehabilitation. 2007:858-861. exclusion reason - wrong intervention. [pmid: 17601465].
532 Guirini J. [commentary on] healing of diabetic foot ulcers and pressure ulcers with human skin equivalent: A new paradigm in wound healing. [original article by brem h et al appears in arch surg 2000;135:627–634]. Foot & Ankle Quarterly--The Seminar Journal. 2000:107. exclusion reason - wrong population.
533 Gunes UY. A prospective study evaluating the pressure ulcer scale for healing (push tool) to assess stage ii, stage iii, and stage iv pressure ulcers. Ostomy Wound Management. 2009:48-52. exclusion reason - wrong intervention. [pmid: 19471048].
534 Gunnewicht BR. Management of pressure sores in a spinal injuries unit. Journal of Wound Care. 1996:36-9. exclusion reason - wrong intervention. [pmid: 8697127].
535 Gunningberg L, Lindholm C, Carlsson M, Sjoden PO. Risk, prevention and treatment of pressure ulcers - nursing staff knowledge and documentation. Scandinavian Journal of Caring Sciences. 2001:257-263. exclusion reason - background. [pmid: 11564234].
536 Gupta N, Loong B, Leong G. Comparing and contrasting knowledge of pressure ulcer assessment, prevention and management in people with spinal cord injury among nursing staff working in two metropolitan spinal units and rehabilitation medicine training specialists in a three-way comparison. Spinal Cord. 2012:159-64. exclusion reason - wrong intervention. [pmid: 21894165].
537 Gupta S, Gabriel A. Improving pressure ulcer outcomes using an algorithmic approach to negative pressure wound therapy. 2008. [pmid: 17601465]. exclusion reason - no original data.
538 Gurcay E. Pressure sores in patients with spinal cord injuries. Marmara Medical Journal. 2009:162-168. exclusion reason - background.
539 Gusenoff JA, Redett RJ, Nahabedian MY. Outcomes for surgical coverage of pressure sores in nonambulatory, nonparaplegic, elderly patients. Annals of Plastic Surgery. 2002:633-40. exclusion reason - not relevant. [pmid: 12055434].
540 Guthrie J. Wound care. Using air fluidised therapy. Nursing Times. 1993:82-8. exclusion reason - not relevant. [pmid: 8474913].
541 Gutierrez A. Pressure lessons: Choosing the correct specialty mattress is integral to preventing and healing pressure ulcers. Rehab Management: The Interdisciplinary Journal of Rehabilitation. 2002:44. exclusion reason - no original data.
542 Haalboom JRE. The guideline ‘decubitus’ [pressure ulcer] of the dutch college of general practitioners; reaction from internal medicine. Nederlands Tijdschrift voor Geneeskunde. 2000:645-646. exclusion reason - background. [pmid: 10774290].
543 Hai H, Dai H, Xu Y. combined treatment of refractory decubitus ulcers. Chung-Kuo Hsiu Fu Chung Chien Wai Ko Tsa Chih/Chinese Journal of Reparative & Reconstructive Surgery. 2006:909-11. exclusion reason - not relevant. [pmid: 17036979].
544 Haisfield ME, Heckman C, Day T. Improving care of pressure sores. Oncology Nursing Forum. 1995:989-90. exclusion reason - no original data. [pmid: 7567624].
545 Hale C. Pressure sores: Assessing the cost. Nursing Times. 1990:66-71. exclusion reason - not relevant. [pmid: 2113672].
546 Hale JS, Smith SH. Pressure reduction mattresses versus pressure reduction overlays: A cost analysis. Journal of Enterostomal Therapy. 1990:241-3. exclusion reason - not relevant. [pmid: 2122995].
547 Halfens RJ, Bours GJ, Van Ast W. Relevance of the diagnosis ‘stage 1 pressure ulcer’: An empirical study of the clinical course of stage 1 ulcers in acute care and long-term care hospital populations. Journal of Clinical Nursing. 2001:748-57. exclusion reason - background. [pmid: 11822846].
548 Hallouet P, Eggers J, Malaquin-Pavan E. care of decubitus ulcers. Soins. 2007:45-7. exclusion reason - not relevant. [pmid: 17983004].
549 Hamilton L, Quek P, Lew N, Li K, Topp R. Pressure ulcers: An interdisciplinary protocol for prevention and treatment. Perspectives. 1989:9-15. exclusion reason - no original data. [pmid: 2497617].
550 Hampton. Evaluation of the new cairwave therapy system in one hospital trust. 1997:167-170. exclusion reason - no original data.
551 Hampton S. Efficacy and cost-effectiveness of the thermo contour mattress. British Journal of Nursing. 1999:990-6. exclusion reason - wrong outcome. [pmid: 10711028].
552 Hampton S. The pressure ulcer benchmark: Will it improve patient care?. Journal of Wound Care. 2001:210-2. exclusion reason - not relevant. [pmid: 12964355].
553 Hampton S. Pressure ulcer care: Can we learn from poorer countries?. British Journal of Nursing. 2001:S4. exclusion reason - no original data. [pmid: 12070395].
554 Hampton S. Unisoft: Pressure relief with price relief. Nursing & Residential Care. 2002:434. exclusion reason - no original data.
555 Hampton S. An evaluation of a silicone adhesive shaped heel dressing. British Journal of Nursing. 2010:S30-3. exclusion reason - not relevant. [pmid: 20335927].
556 Hampton S. Wound care: The science of healing. Nursing in Practice: The Journal for Today’s Primary Care Nurse. 2010:60. exclusion reason - background.
557 Han H, Few J, Fine NA. Use of the tumescent technique in presssure ulcer closure. Plastic & Reconstructive Surgery. 2002:711-2. exclusion reason - not relevant. [pmid: 12142710].
558 Han H, Lewis VL Jr, Wiedrich TA, Patel PK. The value of jamshidi core needle bone biopsy in predicting postoperative osteomyelitis in grade iv pressure ulcer patients. Plastic and Reconstructive Surgery. 2002:118-122. exclusion reason - wrong intervention. [pmid: 12087241].
559 Harada K, Yamahara K, Ohnishi S, Otani K, Kanoh H, Ishibashi-Ueda H, Minamino N, Kangawa K, Nagaya N, Ikeda T. Sustained-release adrenomedullin ointment accelerates wound healing of pressure ulcers. Regulatory Peptides. 2011:21-26. exclusion reason - wrong population. [pmid: 21362442].
560 Harding K, Cutting K, Price P. The cost-effectiveness of wound management protocols of care. British Journal of Nursing. 2000:S6. S8. S10 passim. exclusion reason - not relevant. [pmid: 12271239].
561 Harding KG, Bale S, Llewellyn M, Baggott J, Robbins K. A pilot study of clostridium collagenase (collagenase abc(registered trademark)) ointment in the debridement of dermal ulcers. Clinical Drug Investigation. 1996:139-144. exclusion reason - not relevant.
562 Harker J. Pressure ulcer classification: The torrance system. Journal of Wound Care. 2000:275-277. exclusion reason - background. [pmid: 11933341].
563 Harris C, Damkat-Thomas L, Black CE. The superior gluteal artery perforator flap to reconstruct lumbar soft tissue defects in the non-ambulatory patient. Journal of Plastic, Reconstructive and Aesthetic Surgery. 2012:408-409. exclusion reason - not relevant.
564 Harris RP, Helfand M, Woolf SH, Lohr KN, Mulrow CD, Teutsch SM, Atkins D. T. U. S. P. S. T. F. Methods Work Group. Current methods of the us preventive services task force: A review of the process. Am J Prev Med. 2001:21-35. exclusion reason - background. [pmid: 11306229].
565 Harrison JE. Polymeric membrane dressings* bring brisk healing to bilateral pressure ulcers. 2008. exclusion reason - not relevant.
566 Harrison MB, Mackey M, Friedberg E. National patient safety goals. Pressure ulcer monitoring: A process of evidence-based practice, quality, and research. Joint Commission Journal on Quality & Patient Safety. 2008:355-359. exclusion reason - background. [pmid: 18595382].
567 Hartgrink HH, Wille J, Konig P, Hermans J, Breslau PJ. Pressure sores and tube feeding in patients with a fracture of the hip: A rondomized clinical trial. Clinical Nutrition. 1998:287-292. exclusion reason - wrong population. [pmid: 10205352].
568 Hartling L, McAlister FA, Rowe BH, Ezekowitz J, Friesen C, Klassen TP. Challenges in systematic reviews of therapeutic devices and procedures. Ann Intern Med. 2005:1100-1111. exclusion reason - background. [pmid: 15968035].
569 Hartmann M, Schulz D, Gundermann C, Norgauer J. economic aspects of standardization of modern wound care. Hautarzt. 2007:970-4. exclusion reason - not relevant. [pmid: 17618408].
570 Hartoch RS, McManus JG, Knapp S, Buettner MF. Emergency management of chronic wounds. Emergency Medicine Clinics of North America. 2007:203-21. exclusion reason - background. [pmid: 17400082].
571 Harvey C. Wound healing. Orthopaedic Nursing. 2005:143-57. quiz 158–9. exclusion reason - background. [pmid: 15902014].
572 Hausman LL. Cost containment through reducing pressure ulcers. Nursing Management. 1994:88R. 88T. 88V. exclusion reason - not relevant. [pmid: 8044480].
573 Hawkins E. Using activheal® in a traffic light system wound care formulary. Wounds UK. 2010:177-182. exclusion reason - no original data.
574 Hayashi T, Honda K, Kimura C, Yamamoto Y, Oyama A, Sugihara T. Treatment of ischial pressure sores by means of sclerotherapy using absolute ethanol. Annals of Plastic Surgery. 2004:554-9. exclusion reason - not relevant. [pmid: 15602252].
575 HAYES and Inc. Pressure-reducing support surfaces for pressure ulcers (structured abstract). Health Technology Assessment Database. 2011. exclusion reason - unable to find.
576 Heasley DD. Evaluation of a silver collagen based amorphous gel in expedience of wound debridement. Journal of Wound, Ostomy & Continence Nursing. 2011:S18-S18. exclusion reason - wrong population.
577 Helaly P, Vogt E, Schneider G. wound healing disorders and their enzymatic therapy--a multicenter double-blind study. Schweizerische Rundschau fur Medizin Praxis. 1988:1428-34. exclusion reason - not relevant. [pmid: 2851160].
578 Helberg D, Mertens E, Halfens RJ, Dassen T. Treatment of pressure ulcers: Results of a study comparing evidence and practice. Ostomy Wound Management. 2006:60-72. exclusion reason - background. [pmid: 16896239].
579 Heller B. a hammock against decubitus ulcer on the heel. 2. Nursing award for treatment of decubitus ulcers. Pflege Aktuell. 1997:540-1. exclusion reason - not relevant. [pmid: 9386546].
580 Henderson CT, Trumbore LS, Mobarhan S, Benya R, Miles TP. Prolonged tube feeding in long-term care: Nutritional status and clinical outcomes. J Am Coll Nutr. 1992:309-325. exclusion reason - background. [pmid: 1619183].
581 Henderson V, Anthony D, Tolmie EP. A study of the prevention and management of pressure sores. Clinical Effectiveness in Nursing. 2002:155-157. exclusion reason - no original data.
582 Hendrickson MA. Optimizing wound care by integrating negative pressure wound therapy (npwt) adjunctive topical treatments and surgical debridement. 41st annual wound, ostomy and continence nurses annual conference. st. Louis, missouri. june 6–10, 2009. Journal of Wound, Ostomy & Continence Nursing. 2009:S15-S15. exclusion reason - no original data.
583 Henriques MS, Simoes SCO. application of honey in the treatment of stage 4 pressure ulcers. [portuguese]. Nursing Revista de Formacao Continua em Enfermagem. 2008:37-40. exclusion reason - not relevant.
584 Hermans MHE, Neto M. Reducing heel pressure with a vpf/smt polyurethane support surface. exclusion reason - Scientific Information Packets, not directly used.
585 Hermans MHE, Neto M. Reducing the chances of pressure ulcers on the occiput. exclusion reason - Scientific Information Packets, not directly used.
586 Hermans MHE, Neto M, Warren S. Surface modification technology: Increasing envelopment in polyurethane foam pressure relief mattress. exclusion reason - Scientific Information Packets, not directly used.
587 Hermans MHE, Neto M, Warren S. Surface modification technology results in an increase in envelopment in pressure redistribution mattresses. exclusion reason - Scientific Information Packets, not directly used.
588 Hermans MHE, Neto M, Warren S. Measuring pinch shear forces on the occiput and the heels using pressure mapping: Results of a study in volunteers. exclusion reason - Scientific Information Packets, not directly used.
589 Hermans MHE, Warren S, McCabe K, Contreras R, Niederoest B, Neto M. Variable pressure foaming in polyurethane systems shows a clear reduction of pressure in an ‘in vevo’ test model. exclusion reason - Scientific Information Packets, not directly used.
590 Hermans MHE, Warren S, Neto M, Reger SI. Evaluation of the efficacy of a new mattress technology by mapping the pressure on the trochanter major in healthy volunteers. exclusion reason - Scientific Information Packets, not directly used.
591 Hernandez Ortiz JA. Prevention and care in pressure ulcers. Where are we?. [spanish]. Gerokomos. 2009:132-140. exclusion reason - not relevant.
592 Hess CT Managed care and wound care: Proactive strategies for successful outcomes Ostomy Wound Management 19969496 98 exclusion reason - no original data. 8716036
593 Hess CT. Managing a pressure ulcer. Nursing. 2001:68. exclusion reason - no original data. [pmid: 11216248].
594 Hewitt H, Wint Y, Talabere L, Lopez S, Bailey E, Parshad O, Weaver S. The use of papaya on pressure ulcers. American Journal of Nursing. 2002:73-7. exclusion reason - no original data. [pmid: 12473933].
595 Hey S. Pressure-sore care and cure. Lancet. 1996:1511. exclusion reason - no original data. [pmid: 8942786].
596 Heyneman A, Beele H, Vanderwee K, Defloor T. A systematic review of the use of hydrocolloids in the treatment of pressure ulcers. Journal of Clinical Nursing. 2008:1164-73. exclusion reason - Systematic Review, not directly used. [pmid: 18416792].
597 Heywood AJ, Quaba AA. Modified gluteus maximus v-y advancement flaps. British Journal of Plastic Surgery. 1989:263-5. exclusion reason - background. [pmid: 2758198].
598 Hierner R. Operative treatment of pressure sores: How and when?. Zeitschrift fur Wundheilung. 2005:110-123. exclusion reason - background.
599 Hierner R, Flour M, Notebaert M, Tombeur M, Kiekens C, Degreef H, Veckman L, Vandermersch E, Joosten E. Update on plastic surgical management of pressure sores. Chirurgische Gastroenterologie Interdisziplinar. 2006:155-168. exclusion reason - background.
600 Hill-Brown S. Reduction of pressure ulcer incidence in the home healthcare setting: A pressure-relief seating cushion project to reduce the number of community-acquired pressure ulcers. Home Healthcare Nurse. 2011:575-9. exclusion reason - wrong population. [pmid: 21956013].
601 Hinshaw JR, Herrera HR, Lanzafame RJ, Pennino RP. The use of the carbon dioxide laser permits primary closure of contaminated and purulent lesions and wounds. Lasers in Surgery & Medicine. 1987:581-3. exclusion reason - not relevant. [pmid: 3573932].
602 Hirano A, Tanaka N, Itano N. Coccygeal pressure sores in paraplegics. Japanese Journal of Plastic and Reconstructive Surgery. 1990:849-855. exclusion reason - not relevant.
603 Hisashige A, Ohura T. Cost-effectiveness of nutritional intervention on healing of pressure ulcers. Clinical Nutrition. 2012. exclusion reason - background. [pmid: 22626888].
604 Hofman D, Burgess B, Cherry GW, Robinson BJ, Ryan TJ. Management of pressure sores and leg ulcers with duoderm hydroactive gel. 4th Annual Meeting of the European Tissue Repair Society. 1994. exclusion reason - no original data.
605 Holman PD. Preservation of the lower extremity in the treatment of massive pressure ulcers. Arizona Medicine. 1985:93-9. exclusion reason - not relevant. [pmid: 3977620].
606 Homma K, Murakami G, Fujioka H, Fujita T, Imai A, Ezoe K. Treatment of ischial pressure ulcers with a posteromedial thigh fasciocutaneous flap. Plastic & Reconstructive Surgery. 2001:1990-6. discussion 1997. exclusion reason - not relevant. [pmid: 11743389].
607 Hommel A, Bjorkelund KB, Thorngren K, Ulander K. A study of a pathway to reduce pressure ulcers for patients with a hip fracture. Journal of Orthopaedic Nursing. 2007:151-159. exclusion reason - wrong population.
608 Honaker JS, Forston MR, Davis EA, Wiesner MM, Morgan JA. Effects of non contact low-frequency ultrasound on healing of suspected deep tissue injury: A retrospective analysis. International Wound Journal. 2012. exclusion reason - wrong population.
609 Honda S. Use of comfeel ulcus sheet and pressure relief dressing in the treatment of pressure sores in patients with spinal cord injuries. Japanese Pharmacology and Therapeutics. 1990:289-296. exclusion reason - not relevant.
610 Honda S, Uchida R, Kimura T, Moriai T, Magara A, Hayashi Y, Ebata H, Saito E, Ono Y, Ijichi M, Tanaka H, Hayashi T, Noguchi T, Yoshimi S, Nakashima A, Takada S. Clinical results of new transparent hydrogel wound dressing clearsite(registered trademark) on decubitus. Japanese Pharmacology and Therapeutics. 1993:543-553. exclusion reason - not relevant.
611 Hopkins A, Gooch S, Danks F. A programme for pressure sore prevention and management. Journal of Wound Care. 1998:37-40. exclusion reason - wrong outcome. [pmid: 9510749].
612 Horch RE, Nord D, Augustin M, Germann G, Leffler M, Dragu A. economic aspects of surgical wound therapies. Chirurg. 2008:518-25. exclusion reason - not relevant. [pmid: 18458799].
613 Horn S, Sharkey S, Hudak S, Spector W. Practice-based evidence for pressure ulcer prevention and treatment in nursing homes. World Union Of Wound Healing Societies. Toronto, Canada. 2008. [pmid: 20177165]. exclusion reason - wrong intervention.
614 Horn SD. The business case for nursing in long-term care. Policy, Politics, & Nursing Practice. 2008:88-93. exclusion reason - not relevant. [pmid: 18650413].
615 Hornake J, Forston M, Davis E, Wiesner M, Morgan J. Effect of noncontact low frequency ultrasound treatment on suspected deep tissue injury healing. Journal of Wound, Ostomy & Continence Nursing. 2011:S8-9. exclusion reason - wrong population.
616 Hou CL. myocutaneous flap in the treatment of pressure sores. Chung-Hua Cheng Hsing Shao Shang Wai Ko Tsa Chih - Chinese Journal of Plastic Surgery & Burns. 1989:30-1. 77. exclusion reason - not relevant. [pmid: 2507107].
617 House MJ. Wheelchair seat angle and lumbar support are critical factors for resolution of flexible spinal deformity and decubitus ulcer in persons with spinal cord injury... Platforms, thematic posters, and posters for csm 2007. Journal of Neurologic Physical Therapy. 2006. 216-216. exclusion reason - not relevant.
618 Hu K-x, Zhang H-w, Zhou F, Yao G, Shi J-p, Cheng Z, Wang L-f, Hou Z-q. observation on the therapeutic effects of negative-pressure wound therapy on the treatment of complicated and refractory wounds. Zhonghua Shao Shang Za Zhi. 2009:249-52. exclusion reason - not relevant. [pmid: 19951540].
619 Hu TW, Stotts NA, Fogarty TE, Bergstrom N. Cost analysis for guideline implementation in prevention and early treatment of pressure ulcers. Decubitus. 1993:42-6. exclusion reason - not relevant. [pmid: 8318158].
620 Hung SJ, Chen HC, Wei FC. Free flaps for reconstruction of the lower back and sacral area. Microsurgery. 2000:72-6. exclusion reason - not relevant. [pmid: 10702740].
621 Hutchinson JJ, McGuckin M. Occlusive dressings: A microbiologic and clinical review. Am J Infect Control. 1990:257-268. exclusion reason - background. [pmid: 2206087].
622 Hyakusoku H, Murakami M, Ishimaru S. Surgical treatment of decubitus ulcers outside the sacral, ischial and trochanter region. Japanese Journal of Plastic and Reconstructive Surgery. 2003:587-594. exclusion reason - not relevant.
623 Ichioka S, Nakatsuka T, Ohura N, Shibata M, Ando J. Treating pressure ulcers with artificial dermis graft and new pressure relief air mattress. Chicago 2000 World Congress HQ. Chicago, IL. 2000. exclusion reason - unable to find.
624 Ichioka S, Ohura N, Nakatsuka T. Benefits of surgical reconstruction in pressure ulcers with a non-advancing edge and scar formation. Journal of Wound Care. 2005:301-5. exclusion reason - not relevant. [pmid: 16048214].
625 Ichioka S, Ohura N, Sekiya N, Shibata M, Nakatsuka T. Regenerative surgery for sacral pressure ulcers using collagen matrix substitute dermis (artificial dermis). Annals of Plastic Surgery. 2003:383-9. exclusion reason - not relevant. [pmid: 14520066].
626 Ichioka S, Okabe K, Ohura N, Yokogawa H, Nakajima M, Nakatsuka T. Versatility of the limberg flap and the v-y flap (based on a distal perforator) for covering sacral ulcers. Scandinavian Journal of Plastic & Reconstructive Surgery & Hand Surgery. 2007:65-9. exclusion reason - not relevant. [pmid: 17605438].
627 Ichioka S, Okabe K, Tsuji S, Ohura N, Nakatsuka T. Distal perforator-based fasciocutaneous v-y flap for treatment of sacral pressure ulcers. Plastic & Reconstructive Surgery. 2004:906-9. exclusion reason - not relevant. [pmid: 15468397].
628 Ichioka S, Okabe K, Tsuji S, Ohura N, Nakatsuka T. Triple coverage of ischial ulcers with adipofascial turnover and fasciocutaneous flaps. Plastic & Reconstructive Surgery. 2004:901-5. exclusion reason - not relevant. [pmid: 15468396].
629 Iglesias CP, Nixon J, Cranny G, Nelson A, Hawkins K, Philips A, Torgerson DJ, Mason S, Cullum N. The nhs health technology assessment programme. Pressure trial: Cost effectiveness analysis of two alternating pressure surfaces for the prevention of pressure ulcers. EWMA Journal. 2006:38-38. exclusion reason - not relevant.
630 Iizaka S, Sanada H, Matsui Y, Furue M, Tachibana T, Nakayama T, Sugama J, Furuta K, Tachi M, Tokunaga K, Miyachi Y. Serum albumin level is a limited nutritional marker for predicting wound healing in patients with pressure ulcer: Two multicenter prospective cohort studies. Clinical Nutrition. 2011:738-45. exclusion reason - background. [pmid: 21802178].
631 Institute of Medicine. Finding what works in health care: Standards for systematic reviews. Washington, DC. The National Academy of Sciences. 2011. exclusion reason - background.
632 Iordanou P, Christopoulou J, Siamaga E, Evagelou E, Vardaki Z. Factors affecting pressure ulcers healing. ICUs & Nursing Web Journal. 2002:15p. exclusion reason - background.
633 Iori I, Pizzini AM, Arioli D, Favali D, Leone MC. infected pressure ulcers: Evaluation and management. Infezioni in Medicina. 2009:88-94. exclusion reason - not relevant. [pmid: 20428024].
634 Isago T, Nozaki M, Kikuchi Y, Honda T, Nakazawa H. Negative-pressure dressings in the treatment of pressure ulcers. Journal of Dermatology. 2003:299-305. exclusion reason - wrong outcome. [pmid: 12707466].
635 Isago T, Shimoda K, Morita N, Takahashi Y, Tomoyasu Y. Treatment effects of the vacuum-assisted closure of skin ulcers. Japanese Pharmacology and Therapeutics. 2002:311-317. exclusion reason - not relevant.
636 Isenberg JS, Ozuner G, Restifo RJ. The natural history of pressure sores in a community hospital environment. Annals of Plastic Surgery. 1995:361-5. exclusion reason - background. [pmid: 8585677].
637 Isenberg R. Pulsed radio frequency energy therapy in elderly patients with stage iii and stage iv pressure ulcers in long-term care settings. Ostomy Wound Management. 2008:72-73. exclusion reason - no original data.
638 Isenberg RA. Cell proliferation induction (cpi) wound therapy in long-term care settings: An effective therapy for elderly patients with stage iv pressure ulcers. Scientific and clinical abstracts from the 40th annual wound, ostomy and continence nurses annual conference. Journal of Wound, Ostomy & Continence Nursing. 2008:S64-S64. exclusion reason - not relevant.
639 Isenberg RA. Pulsed radio frequency energy therapy in elderly patients with pressure ulcers in long-term care settings: An analysis of 224 wounds. 41st annual wound, ostomy and continence nurses annual conference. st. Louis, missouri. june 6–10, 2009. Journal of Wound, Ostomy & Continence Nursing. 2009:S63-S63. exclusion reason - no original data.
640 Ishida LH, Munhoz AM, Montag E, Alves HRN, Saito FL, Nakamoto HA, Ferreira MC. Tensor fasciae latae perforator flap: Minimizing donor-site morbidity in the treatment of trochanteric pressure sores. Plastic & Reconstructive Surgery. 2005:1346-52. exclusion reason - not relevant. [pmid: 16217478].
641 Ismail HEdA. Versatility of perforator sparing buttock rotation flap in repair of pressure sores. European Journal of Plastic Surgery. 2011:1-7. exclusion reason - not relevant.
642 Ito Y, Sumiya N, Hayakawa O, Ichikawa K, Kato Y, Tunashima A. Surgical treatment of sacral pressure sores using an ultrasonic surgical aspirator and a rubber compression fixing. Japanese Journal of Plastic and Reconstructive Surgery. 2003:1165-1172. exclusion reason - not relevant.
643 Itoh M, Montemayor JS Jr, Matsumoto E, Eason A, Lee MH, Folk FS. Accelerated wound healing of pressure ulcers by pulsed high peak power electromagnetic energy (diapulse). Decubitus. 1991:24-5. 29. 34. exclusion reason - Systematic Review, not directly used. [pmid: 1994961].
644 Iusim M, Kimchy J, Pillar T, Mendes DG. Evaluation of the degree of effectiveness of biobeam low level narrow band light on the treatment of skin ulcers and delayed postoperative wound healing. Orthopedics. 1992:1023-1026. exclusion reason - wrong population. [pmid: 1437861].
645 Iverson-Carpenter M. A descriptive study of the etiologies and defining characteristics of pressure sores. Carroll-Johnson RM, editor. Classification of nursing diagnoses: Proceedings of the eighth conference. st. Louis, mo. march,1988. J.B. Lippincott. 1989:275-280. exclusion reason - background.
646 Jack L. The use of low level laser therapy as a treatment for chronic wounds. Wounds UK. 2006:74-75. exclusion reason - not relevant.
647 Jakubietz RG, Jakubietz MG, Jakubietz DF, Koehler G, Zeplin PH, Meffert RH, Schmidt K. Ischial pressure sores: Reconstruction using the perforator-based reverse flow musculocutaneous 180 degrees propeller flap. Microsurgery. 2009:672-5. exclusion reason - not relevant. [pmid: 19530083].
648 James H. Tissue viability society. Exploring the role of the tissue viability specialist nurse. Nursing Standard. 1994:60-3. exclusion reason - no original data. [pmid: 7811622].
649 Jamshed N, Schneider EL. Is the use of supplemental vitamin c and zinc for the prevention & treatment of pressure ulcers evidence-based?. Annals of Long-Term Care. 2010:28-32. exclusion reason - Systematic Review, not directly used.
650 Janssen PA, Janssen H, Cauwenbergh G, De Doncker P, De Beule K, Lewi P, Tytgat HF, Lapiere CM. Use of topical ketanserin in the treatment of skin ulcers: A double-blind study. Journal of the American Academy of Dermatology. 1989:85-90. exclusion reason - wrong intervention. [pmid: 2663937].
651 Jaul E. Setting up a dedicated pressure ulcer unit in a geriatric ward. Journal of Wound Care. 2003:131-3. exclusion reason - wrong intervention. [pmid: 12715484].
652 Jedynak D, Montandon S, Berard P. experimentation with a hydrocolloid in an occlusive bandage in the treatment of cutaneous decubitus ulcers duoderm. Soins; La Revue de Reference Infirmiere. 1985:suppl 1-3. exclusion reason - not relevant. [pmid: 3848093].
653 Jepson BA. Relieving the pain of pressure sores. Lancet. 1992:503-4. exclusion reason - wrong outcome. [pmid: 1346867].
654 Jercinovic A, Karba R, Vodovnic L, Stefanovska A, Kroselj P, Turk R, et al. Low frequency pulsed current and pressure ulcer healing. IEEE Transactions on Rehabilitation Engineering. 1994:225-33. exclusion reason - wrong outcome.
655 Jester J, Weaver V. A report of clinical investigation of various tissue support surfaces used for the prevention, early intervention and management of pressure ulcers. Ostomy Wound Management. 1990:39-45. exclusion reason - no original data. [pmid: 2306326].
656 Jiang QX. study on close insulin wet compresses in treating bedsores. Chung-Hua Hu Li Tsa Chih Chinese Journal of Nursing. 1994:274-7. exclusion reason - not relevant. [pmid: 7788783].
657 Jiburum BC, Achebe JU, Akpuaka FC. Early results of operative closure of pressure sores in traumatic paraplegics. International Surgery. 1995:178-80. exclusion reason - not relevant. [pmid: 8530239].
658 Johnston PJ. Improvement in surgical wound status: A process improvement plan. Remington Report. 2006:18-20. exclusion reason - not relevant.
659 Johnstone A. Time -- principles of wound preparation. Journal of Wound, Ostomy & Continence Nursing. 2006:S11-S11. exclusion reason - unable to find.
660 Jones JT, Stenson MA, Spannagel BD, Robinson DD. Treatment of pressure ulcers with nitropaste. Journal of the American Geriatrics Society. 1997:895. exclusion reason - wrong outcome. [pmid: 9215351].
661 Jones KR. Identifying best practices for pressure ulcer management. Journal of Clinical Outcomes Management. 2009:375-381. exclusion reason - Systematic Review, not directly used.
662 Jones KR, Fennie K. Factors influencing pressure ulcer healing in adults over 50: An exploratory study. Journal of the American Medical Directors Association. 2007:378-87. exclusion reason - background. [pmid: 17619036].
663 Jones ML, Young T, Liptrot P. Improving pressure ulcer care through designer education. British Journal of Nursing. 2003:S28-35. exclusion reason - background. [pmid: 14593269].
664 Jones PL, Millman A. A three-part system to combat pressure sores. Geriatric Nursing. 1986:78-82. exclusion reason - wrong intervention. [pmid: 3633222].
665 Joseph E, Hamori CA. A prospective, randomized trial of vacuum-assisted closure versus standard therapy of chronic non-healing wounds. Wounds. 2000:60-67. exclusion reason - not relevant.
666 Josvay J, Donath A. Modified hamstring musculocutaneous flap for the coverage of ischial pressure sores. Plastic & Reconstructive Surgery. 1999:1715-8. exclusion reason - not relevant. [pmid: 10323711].
667 Josvay J, Donath A. 15 years experience in the surgical treatment of decubitus ulcers of the pelvic region. Magyar Sebeszet. 2002:301-5. exclusion reason - not relevant. [pmid: 12474515].
668 Josvay J, Donath A, Kertesz G, Klauber A. surgical treatment of decubitus ulcers of the pelvic area in patients with spinal cord injury. Ideggyogyaszati Szemle. 2003:58-62. exclusion reason - not relevant. [pmid: 12690792].
669 Josvay J, Sashegyi M, Kelemen P, Donath A. Clinical experience with the hatchet-shaped gluteus maximus musculocutaneous flap. Annals of Plastic Surgery. 2005:179-82. exclusion reason - not relevant. [pmid: 16034250].
670 Josvay J, Sashegyi M, Kelemen P, Donath A. Modified tensor fascia lata musculofasciocutaneous flap for the coverage of trochanteric pressure sores. Journal of Plastic, Reconstructive & Aesthetic Surgery:JPRAS. 2006:137-41. exclusion reason - not relevant. [pmid: 16703857].
671 Jull AB, Rodgers A, Walker N. Honey as a topical treatment for wounds. Cochrane Database of Systematic Reviews. 2008:CD005083. exclusion reason - Systematic Review, not directly used. [pmid: 18843679].
672 Jurado Hernandez R. Multicenter clinical evaluation of a new hydro-polymeric dressing. [spanish]. Metas de Enfermería. 2002:12-19. exclusion reason - not relevant.
673 Juri H, Palma A, Obeide A. The co2 laser in the treatment of decubitus ulcer. Journal of Neurological and Orthopaedic Medicine and Surgery. 1986:29-33. exclusion reason - not relevant. [pmid: 3683061].
674 Juszczyk K, Gollogly JG, Ngiep OC. Bilateral hip disarticulation in paraplegics. Asian Biomedicine. 2010:125-129. exclusion reason - not relevant.
675 Kalava UR, Cha SS, Takahashi PY. Association between vitamin d and pressure ulcers in older ambulatory adults: Results of a matched case-control study. Clinical Interventions In Aging. 2011:213-9. exclusion reason - wrong intervention. [pmid: 21966215].
676 Kallianinen LK, Hirshberg J, Marchant B, Rees RS. Role of platelet-derived growth factor as an adjunct to surgery in the management of pressure ulcers. Plastic & Reconstructive Surgery. 2000:1243-8. exclusion reason - not relevant. [pmid: 11083552].
677 Kaminski MV Jr, Pinchcofsky-Devin G, Williams SD. Nutritional management of decubitus ulcers in the elderly. Decubitus. 1989:20-30. exclusion reason - no original data. [pmid: 2510755].
678 Kamolz LP, Andel H, et al. Use of subatmospheric pressure therapy to prevent burn wound progression in human: First experiences. Burns. 2004:253-258. exclusion reason - wrong population. [pmid: 15082354].
679 Kanj LF, Wilking SV, Phillips TJ. Pressure ulcers. Journal of the American Academy of Dermatology. 1998:517-36. quiz 537–8. exclusion reason - background. [pmid: 9555790].
680 Kapoor A, Kader B, Berlowitz DR. Predicting pressure ulcer healing using the minimum data set. 29th Annual Meeting of the Society of General Internal Medicine. Los Angeles, California. 2006. exclusion reason - no original data.
681 Karabeg R, Dujso V, Jakirlic M. application of tensor fascia lata pedicled flap in reconstructing trochanteric pressure sore defects. Medicinski Arhiv. 2008:300-2. exclusion reason - not relevant. [pmid: 19469276].
682 Karadag M. Pressure sores due surgery. SENDROM. 2004:90-94. exclusion reason - background.
683 Karadakovan A, Basbakkal Z. Ice therapy for pressure sores. Rehabilitation Nursing. 1997:257-8. exclusion reason - not relevant. [pmid: 9341547].
684 Karba R, Semrov D, Vodovnik L, Benko H, Savrin R. Dc electrical stimulation for chronic wound healing enhancement. Part 1. Clinical study and determination of electrical field distribution in the numerical wound model. Bioelectrochemistry and Bioenergetics. 1997:265-270. exclusion reason - wrong outcome.
685 Karrer S. topical therapy of ulcers. Hautarzt. 2005:1165-78. quiz 1179. exclusion reason - not relevant. [pmid: 16283127].
686 Karrer S. how to treat chronic wounds. MMW Fortschritte der Medizin. 2010:81-3. 85. 7. quiz 88. exclusion reason - not relevant. [pmid: 20608135].
687 Karube S, Inamatu T, Kuzuhara S, Tabuchi KI, Handa O, Nakase SI. Clinical evaluation of nasent pad a for the patient with decubitus ulcer. Effectiveness of treatment and prevention. Japanese Pharmacology and Therapeutics. 1988:299-309. exclusion reason - not relevant.
688 Kauer C, Andourah A. perineal complications and gracilis musculocutaneous flap in patients with paraplegia. Apropos of 19 cases. Annales de Chirurgie Plastique et Esthetique. 1991:347-52. exclusion reason - not relevant. [pmid: 1724889].
689 Kauer C, Sonsino G. The need for skin and muscle saving techniques in the repair of decubitus ulcers. A consecutive series of 72 patients and 100 ulcers over 5 years (1979/1984). A case report. Scandinavian Journal of Plastic & Reconstructive Surgery. 1986:129-31. exclusion reason - background. [pmid: 3775282].
690 Kauffmann G, Davis A, Schulwolf E, Press V, Stupay K, Arora V. Ibcd: Development and testing of a checklist to improve quality of care for hospitalized general medical patients. Journal of Hospital Medicine. 2011:S117-S118. exclusion reason - wrong intervention.
691 Keast DH, Parslow N, Houghton PE, Norton L, Fraser C. Best practice recommendations for the prevention and treatment of pressure ulcers: Update 2006. Advances in Skin & Wound Care. 2007:447-60. quiz 461–2. exclusion reason - background. [pmid: 17762312].
692 Kegels F. Clinical evaluation of honey-based products for lower extremity wounds in a home care setting. Wounds UK. 2011:46-53. exclusion reason - wrong population.
693 Keller HP. surgical therapy of decubitus ulcers. Krankenpflege Journal. 1988:134-6. exclusion reason - not relevant. [pmid: 3374072].
694 Keller HP. surgical therapy of decubitus ulcers. Krankenpflege Journal. 1996:266-8. exclusion reason - not relevant. [pmid: 8717868].
695 Kemp MG, Kopanke D, Tordecilla L, Fogg L, Shott S, Matthiesen V, Johnson B. The role of support surfaces and patient attributes in preventing pressure ulcers in elderly patients. Research in Nursing & Health. Wiley Subscription Services, Inc., A Wiley Company. 1993:89-96. exclusion reason - wrong outcome.
696 Kerstein MD, Reis ED. Current surgical perspectives in wound healing. Kerstein MD, editor. Wounds: A Compendium of Clinical Research & Practice. 2001:53-58. exclusion reason - background.
697 Keys KA, Daniali LN, Warner KJ, Mathes DW. Multivariate predictors of failure after flap coverage of pressure ulcers. Plastic & Reconstructive Surgery. 2010:1725-34. exclusion reason - not relevant. [pmid: 20517098].
698 Kiemele LJ, Takahashi PY. Practical wound management in long-term care. Annals of Long Term Care. 2004:25-32. exclusion reason - background.
699 Kierney PC, Cardenas DD, Engrav LH, Grant JH, Rand RP. Limb-salvage in reconstruction of recalcitrant pressure sores using the inferiorly based rectus abdominis myocutaneous flap. Plastic & Reconstructive Surgery. 1998:111-6. exclusion reason - not relevant. [pmid: 9655415].
700 Kim YS, Lew DH, Roh TS, Yoo WM, Lee WJ, Tark KC. Inferior gluteal artery perforator flap: A viable alternative for ischial pressure sores. Journal of Plastic, Reconstructive & Aesthetic Surgery: JPRAS. 2009:1347-54. exclusion reason - not relevant. [pmid: 18799379].
701 Kimura T. Conservative treatment of decubitus ulcers for outpatients. IRYO - Japanese Journal of National Medical Services. 1985:735-738. 662. exclusion reason - not relevant.
702 King T, Gehrke R, Vazquez L. Using enhanced case management to improve wound outcomes. Sci Nursing. 2007:2. exclusion reason - no original data.
703 Kingsley A, Murray J. Esprit hr: Something safe to lie on. British Journal of Nursing. 2001;S63:S66. exclusion reason - no original data. [pmid: 12070401].
704 Kinjo M, Nishiyama N, Egashira K, Morise M, Shimazu S, Nemoto H, Kakita A. Local lipo prostaglandin e1 administrated therapy in the treatment of decubitus ulcer. Therapeutic Research. 1993:144-147. exclusion reason - not relevant.
705 Kish TD, Chang MH, Fung HB. Treatment of skin and soft tissue infections in the elderly: A review. American Journal of Geriatric Pharmacotherapy. 2010:485-513. exclusion reason - Systematic Review, not directly used. [pmid: 21356502].
706 Klein-Meding C. management of chronic wounds: Continuity makes the difference. Pflege Zeitschrift. 2003:164-5. exclusion reason - not relevant. [pmid: 12696333].
707 Kloth LC, Berman JE, Dumit-Minkel S, Sutton CH, Papanek PE, Wurzel J. Effects of a normothermic dressing on pressure ulcer healing. Advances in Skin & Wound Care. 2000:69-74. exclusion reason - wrong outcome. [pmid: 11074989].
708 Kloth LC, Berman JE, Nett MJ, Papanek PE. Twelve week randomized trial to evaluate noncontact normothermic wound therapy on full-thickness pressure ulcers. Wound Repair and Regeneration. 2001:399. exclusion reason - no original data.
709 Knight AL. Medical management of pressure sores. Journal of Family Practice. 1988:95-100. exclusion reason - background. [pmid: 3292696].
710 Knowles C, Horsey I. Clinical evaluation of an electronic pressure-relieving mattress. British Journal of Nursing. 1999:1392-5. exclusion reason - no original data. [pmid: 10887824].
711 Knudsen AM, Gallagher S. Care of the obese patient with pressure ulcers. Journal of Wound, Ostomy, & Continence Nursing. 2003:111-8. exclusion reason - not relevant. [pmid: 12658239].
712 Knudsen CW, Tonseth KA. Pressure ulcers--prophylaxis and treatment. Tidsskrift for Den Norske Laegeforening. 2011:464-7. exclusion reason - background. [pmid: 21383799].
713 Kohr R. Moist healing versus wet-to-dry. Canadian Nurse. 2001:17-9. exclusion reason - no original data. [pmid: 11865493].
714 Kolnaar BG, Chel VG. summary of ‘decubitus’ guideline of the dutch college of family practitioners. Nederlands Tijdschrift voor Geneeskunde. 2000:646-9. exclusion reason - not relevant. [pmid: 10774291].
715 Konya C, Sanada H, Sugama J, Okuwa M, Kitagawa A. Does the use of a cleanser on skin surrounding pressure ulcers in older people promote healing?. Journal of Wound Care. 2005:169-71. exclusion reason - wrong intervention. [pmid: 15835228].
716 Koonin AJ. Electro pressure regeneration therapy. Total Health. 2001:42-44. exclusion reason - background.
717 Kordestani S, Shahrezaee M, Tahmasebi MN, Hajimahmodi H, Haji Ghasemali D, Abyaneh MS. A randomised controlled trial on the effectiveness of an advanced wound dressing used in iran. Journal of Wound Care. 2008:323-7. exclusion reason - wrong outcome. [pmid: 18705234].
718 Koshima I, Moriguchi T, Soeda S, Kawata S, Ohta S, Ikeda A. The gluteal perforator-based flap for repair of sacral pressure sores. Plastic & Reconstructive Surgery. 1993:678-83. exclusion reason - not relevant. [pmid: 8446721].
719 Kostur R, Franek A, Polak A, Taradaj J, Szlachta Z. Analysis of the effects of pressure ulcer treatment using the existing electrical methods. [polish]. Przeglad Flebologiczny. 2007:73-80. exclusion reason - not relevant.
720 Krainski MM. Pressure ulcers and the elderly. A review of the literature, 1980–1990. Ostomy Wound Management. 1992:22-37. exclusion reason - Systematic Review, not directly used. [pmid: 1622536].
721 Krajnik M, Zylicz Z, Finlay I, Luczak J, van Sorge AA. Potential uses of topical opioids in palliative care--report of 6 cases. Pain. 1999:121-125. exclusion reason - no original data. [pmid: 10204724].
722 Kramer JD, Kearney M. Patient, wound, and treatment characteristics associated with healing in pressure ulcers. Advances in Skin & Wound Care. 2000:17-24. exclusion reason - background. [pmid: 11061706].
723 Kranke P, Bennett M, Roeckl-Wiedmann I, Debus S. Hyperbaric oxygen therapy for chronic wounds. Cochrane Database of Systematic Reviews. 2004:CD004123. exclusion reason - wrong population. [pmid: 15106239].
724 Krasner D. Ahcpr clinical practice guideline number 15, treatment of pressure ulcers: A pragmatist’s critique for wound care providers. Ostomy Wound Management. 1995:97S-101S. discussion 10–2S. exclusion reason - background. [pmid: 7669206].
725 Krastins K. Pressure ulcer treatment after femoral neck fracture surgery. 21st World Congress of Dermatology. La Rural Convention Center, Buenos Aires (Argentina). 2007. exclusion reason - no original data.
726 Krause T, Anders J, von Renteln-Kruse W. treatment of pressure sores: Rarely based on guidelines. Zeitschrift fur Arztliche Fortbildung und Qualitatssicherung. 2004:769-74. exclusion reason - not relevant. [pmid: 15646563].
727 Kravitz R. Development and implementation of a nursing skin care protocol. Journal of ET Nursing. 1993:4-8. exclusion reason - wrong intervention. [pmid: 8452919].
728 Kremer M, Berger A. plastic surgery of para-pelvic decubitus ulcers. Chirurg. 1999:726-40. exclusion reason - not relevant. [pmid: 10427463].
729 Kristi HenzelM, Bogie KM, Guihan M, Ho CH. Pressure ulcer management and research priorities for patients with spinal cord injury: Consensus opinion from sci queri expert panel on pressure ulcer research implementation. Journal of Rehabilitation Research and Development. 2011:xi-xxxi. exclusion reason - background.
730 Kroll SS, Hamilton S. Multiple and repetitive uses of the extended hamstring v-y myocutaneous flap. Plastic & Reconstructive Surgery. 1989:296-302. exclusion reason - not relevant. [pmid: 2748743].
731 Kroll SS, Rosenfield L. Perforator-based flaps for low posterior midline defects. Plastic & Reconstructive Surgery. 1988:561-6. exclusion reason - not relevant. [pmid: 3279442].
732 Krouskop TA, Williams R, Krebs M, Herszkowicz I, Garber S. Effectiveness of mattress overlays in reducing interface pressures during recumbency. Journal of Rehabilitation Research & Development. 1985:7-10. exclusion reason - wrong intervention. [pmid: 3835267].
733 Kuhn W, Luscher NJ, de Roche R, Krupp S, Zach GA. The neurosensory musculocutaneous tensor fasciae latae flap: Long term results. Paraplegia. 1992:396-400. exclusion reason - not relevant. [pmid: 1635788].
734 Kuipers T, Stark GB, Spilker G. costs and long-term results of plastic surgery treatment of decubitus ulcers in paraplegic patients. Handchirurgie, Mikrochirurgie, Plastische Chirurgie. 1995:161-5. exclusion reason - not relevant. [pmid: 7622133].
735 Kumar RN, Gupchup GV, Dodd MA, Shah B, Iskedjian M, Einarson TR, Raisch DW. Direct health care costs of 4 common skin ulcers in new mexico medicaid fee-for-service patients. Advances in Skin & Wound Care. 2004:143-9. exclusion reason - background. [pmid: 15194976].
736 Kung LG, Luscher NJ, Zach GA. surgical therapy of presacral decubitus ulcer. Indications and technic in 39 consecutive cases. Handchirurgie, Mikrochirurgie, Plastische Chirurgie. 1986:264-6. exclusion reason - not relevant. [pmid: 3770565].
737 Kuntscher MV, Erdmann D, Levin LS, Germann G. role of a sensory innervated plantar fillet free flap for reconstruction of sacral pressure sores in paraplegic patients. Last resort for reconstruction of sacral pressure sores in paraplegics. Chirurg. 2003:734-8. exclusion reason - not relevant. [pmid: 12928794].
738 Kurokawa M, Muneuchi G, Kusaka T. The surgical repair of dorsal pressure sores using bilateral overlapping flaps. Japanese Journal of Plastic and Reconstructive Surgery. 1999:317-321. exclusion reason - not relevant.
739 Kuwahara M, Tada H, Mashiba K, Yurugi S, Iioka H, Niitsuma K, Yasuda Y. Mortality and recurrence rate after pressure ulcer operation for elderly long-term bedridden patients. Annals of Plastic Surgery. 2005:629-32. exclusion reason - not relevant. [pmid: 15900149].
740 Labler L, Oehy K. vacuum sealing of problem wounds. Swiss Surgery. 2002:266-72. exclusion reason - not relevant. [pmid: 12520846].
741 Lagana G, Anderson EH. Moisture dressings: The new standard in wound care. Journal for Nurse Practitioners. 2010:366-370. exclusion reason - background.
742 Lagarde I, Taurand S. hydrocolloid dressings. Treatment of decubitus ulcers. Soins. 1996:17-20. exclusion reason - not relevant. [pmid: 8954494].
743 Lagden K, Attrell E. Evaluation of a hydrofibre dressing in calgary home care wound clinics. CAET Journal. 2000:12-13. exclusion reason - not relevant.
744 Laing TA, Ekpete N, Oon S, Carroll SM. Surgical reconstruction of pressure ulcer defects: A single- or two-stage procedure?. Journal of Wound, Ostomy, & Continence Nursing. 2010:615-8. exclusion reason - wrong intervention. [pmid: 21052028].
745 Lanaia C, Novara M, Campo G, Micale A, Veroux PF, Turrisi A, Lanaia F. Comfeel wound dressing in the treatment of decubitus ulcer. Acta Chirurgica Italica. 1989:469-477. exclusion reason - not relevant.
746 Landi F, Onder G, Russo A, Bernabei R. Pressure ulcer and mortality in frail elderly people living in community. Archives of Gerontology & Geriatrics. 2007:217-23. exclusion reason - background. [pmid: 17317456].
747 Landsman AS. [commentary on] becaplermin gel in the treatment of pressure ulcers: A phase ii randomized, double-blind, placebo-controlled study. [original article by rees rs et al appears in wound rep reg 1999;7(3):141–147]. Foot & Ankle Quarterly--The Seminar Journal. 2000:101. exclusion reason - no original data.
748 Langemo D. Npuap best practices for pressure ulcer care: Abstracts of presentations. Ostomy Wound Management. 2007:24-28. exclusion reason - background.
749 Langemo D, Anderson J, Hanson D, Hunter S, Thompson P, Posthauer ME. Nutritional considerations in wound care. Advances in Skin & Wound Care. 2006:297-8. 300. 303. exclusion reason - background. [pmid: 16885642].
750 Langemo D, Baranoski S. Key points on caring for pressure ulcers in home care. Home Healthcare Nurse. 2003:309-15. exclusion reason - background. [pmid: 12792412].
751 Langemo D, Black JM, Maklebust J, Posthauer ME. The npuap: Look who else is turning 20!. Advances in Skin & Wound Care. 88. 2007:84-9. exclusion reason - background. [pmid: 17287618].
752 Langemo D, Cuddigan J, Baharestani M, Ratliff CR, Posthauer ME, Black J, Garber S. Pressure ulcer guidelines: “Minding the gaps” when developing new guidelines. Advances in Skin & Wound Care. 2008:213-7. exclusion reason - background. [pmid: 18453847].
753 Langemo D, Thompson P, Hanson D, Anderson J, Hunter S. Topical anesthesia for pressure ulcer treatment. Advances in Skin & Wound Care. 2008:364-9. exclusion reason - no original data. [pmid: 18679084].
754 Langemo DK. When the goal is palliative care. Advances in Skin & Wound Care. 2006:148-54. exclusion reason - background. [pmid: 16639221].
755 Langemo DK, Black J. P National Pressure Ulcer Advisory. Pressure ulcers in individuals receiving palliative care: A national pressure ulcer advisory panel white paper. Advances in Skin & Wound Care. 2010:59-72. exclusion reason - background. [pmid: 20087072].
756 Langemo DK, Brown G. Skin fails too: Acute, chronic, and end-stage skin failure. Advances in Skin & Wound Care. 2006:206-11. exclusion reason - background. [pmid: 16641567].
757 Langer C. decubitus prevention and therapy. Krankenpflege Journal. 1985:12-3. exclusion reason - not relevant. [pmid: 3847660].
758 Langer G, Schloemer G, Knerr A, Kuss O, Behrens J. Nutritional interventions for preventing and treating pressure ulcers. Cochrane Database of Systematic Reviews. 2003:CD003216. exclusion reason - Systematic Review, not directly used. [pmid: 14583961].
759 Langer G, Schlomer G. nutrition as intervention in prevention and treatment of decubitus ulcer: Outcomes research. Pflege Zeitschrift. 2005:368-73. exclusion reason - not relevant. [pmid: 16013289].
760 Langer SW. testing the efficacy of a material for the relief of pressure in the prevention and treatment of decubitus ulcers. Krankenpflege Journal. 1996:263-5. exclusion reason - not relevant. [pmid: 8717867].
761 Lapsley HM, Vogels R. Cost and prevention of pressure ulcers in an acute teaching hospital. International Journal for Quality in Health Care. 1996:61-6. exclusion reason - background. [pmid: 8680818].
762 Lari AR, Rajacic N. One-stage repair of multiple bed sores. British Journal of Plastic Surgery. 1992:540-3. exclusion reason - not relevant. [pmid: 1446200].
763 Larichev AB, Antoniuk AV, Kuz’min VS. vacuum-therapy in treatment of festering wounds. Khirurgiia. 2008:22-6. exclusion reason - not relevant. [pmid: 18577940].
764 Larson DL, Hudak KA, Waring WP, Orr MR, Simonelic K. Protocol management of late-stage pressure ulcers: A 5-year retrospective study of 101 consecutive patients with 179 ulcers. Plastic & Reconstructive Surgery. 2012:897-904. exclusion reason - not relevant. [pmid: 22183500].
765 Laudanska H, Gustavson B. In-patient treatment of chronic varicose venous ulcers. A randomized trial of cadexomer iodine versus standard dressings. Journal of International Medical Research. 1988:428-435. exclusion reason - wrong population. [pmid: 2466712].
766 Lauterbach S, Pfeiffer A. Decubitus: Affliction and relief. Pharmazeutische Zeitung. 2010. exclusion reason - not relevant.
767 Laverre L. nurse consultant for decubitus ulcers. Revue de L’Infirmiere. 1990:23-4. exclusion reason - not relevant. [pmid: 2091215].
768 Lavrinec P, Mikus RP, Zajec AM, Lavrinec J. Nutritional support in patients with chronic wounds and pressure ulcers. [slovene]. Obzornik Zdravstvene Nege. 2007:111-124. exclusion reason - Systematic Review, not directly used.
769 Lawton RL, De Pinto V. Bilateral hip disarticulation in paraplegics with decubitus ulcers. Archives of Surgery. 1987:1040-3. exclusion reason - not relevant. [pmid: 3619617].
770 Lazar CC, Auquit-Auckbur I, Milliez PY. the total thigh flap in reconstructive surgery. Annales de Chirurgie Plastique et Esthetique. 2007:144-7. exclusion reason - background. [pmid: 17137699].
771 Lazovic G. The surgical treatment of decubitus ulcers in sacral and trochanteric area. 6th Congress of the Balkan Association for Plastic, Reconstructive Aesthetic Surgery. Hotel Gorica, Ohrid. 2009. exclusion reason - no original data.
772 Le ChapelainL, Fyad JP, Beis JM, Thisse MO, Andre JM. early surgery management of pelvic region pressure ulcers versus directed cicatrization in a population of spinal cord injured patients. Annales de Readaptation et de Medecine Physique. 2001:608-12. exclusion reason - not relevant. [pmid: 11788121].
773 Leaper D. Evidence-based wound care in the uk. International Wound Journal. 2009:89-91. exclusion reason - background. [pmid: 19432658].
774 Lechner JL, Ksiazekl S, Chang J, Rozek SL, Smith JM. Carrington dermal wound gel versus current treatments for the healing of decubitus ulcers and other dermal wounds. ASHP Midyear Clinical Meeting. 1991. P-294E. exclusion reason - unable to find.
775 Lee E-T. A new wound closure achieving and maintaining device using serial tightening of loop suture and its clinical applications in 15 consecutive patients for up to 102 days. Annals of Plastic Surgery. 2004:436-41. exclusion reason - not relevant. [pmid: 15502458].
776 Lee HB, Kim SW, Lew DH, Shin KS. Unilateral multilayered musculocutaneous v-y advancement flap for the treatment of pressure sore. Plastic & Reconstructive Surgery. 1997:340-5. discussion 346–9. exclusion reason - not relevant. [pmid: 9252600].
777 Lee HJ, Pyon JK, Lim SY, Mun GH, Bang SI, Oh KS. Perforator-based bilobed flaps in patients with a sacral sore: Application of a schematic design. Journal of Plastic, Reconstructive and Aesthetic Surgery. 2011:790-795. exclusion reason - not relevant. [pmid: 21144809].
778 Lee JT, Cheng LF, Lin CM, Wang CH, Huang CC, Chien SH. A new technique of transferring island pedicled anterolateral thigh and vastus lateralis myocutaneous flaps for reconstruction of recurrent ischial pressure sores. Journal of Plastic, Reconstructive and Aesthetic Surgery. 2007:1060-1066. exclusion reason - not relevant. [pmid: 17493884].
779 Lee JT, Hsiao HT, Tung KY, Ou SY. Gluteal perforator flaps for coverage of pressure sores at various locations. [9]. Plastic and Reconstructive Surgery. 2006:2507-2508. exclusion reason - no original data. [pmid: 16772972].
780 Lee K. The experience of applying silver-containing hydrofiber dressing on refractory problem wounds. World Council of Enterostomal Therapists Journal. 2009:29-29. exclusion reason - not relevant.
781 Lee MS, Seo SR, Kim JC. A (beta)-cyclodextrin, polyethyleneimine and silk fibroin hydrogel containing centella asiatica extract and hydrocortisone acetate: Releasing properties and in vivo efficacy for healing of pressure sores. Clinical and Experimental Dermatology. 2012. exclusion reason - wrong population.
782 Lee SK. The role of nutrition in treating and healing wounds. Nursing Homes: Long Term Care Management. 2006:26-30. exclusion reason - background.
783 Lee SK. Healing chronic wounds in long-term care: New technologies to get the job done. Director. 2007:19-23. exclusion reason - background. [pmid: 19343863].
784 Lee S-S, Huang S-H, Chen M-C, Chang K-P, Lai C-S, Lin S-D. Management of recurrent ischial pressure sore with gracilis muscle flap and v-y profunda femoris artery perforator-based flap. Journal of Plastic, Reconstructive & Aesthetic Surgery: JPRAS. 2009:1339-46. exclusion reason - not relevant. [pmid: 18595789].
785 Lefemine V, Enoch S, Boyce DE. Surgical and reconstructive management of pressure ulcers. European Journal of Plastic Surgery. 2009:63-75. exclusion reason - background.
786 Legassic M, Keast D, Wolfe D, Petrella R. Feasibility of an internet clinic for treating and preventing pressure ulcers in persons with spinal cord injury. exclusion reason - background.
787 Leigh IH, Bennett G. Pressure ulcers: Prevalence, etiology, and treatment modalities. A review. American Journal of Surgery. 1994:25S-30S. exclusion reason - background. [pmid: 8109681].
788 Leininger SM. The role of nutrition in wound healing. Critical Care Nursing Quarterly. 2002:13-21. exclusion reason - background. [pmid: 12211333].
789 Lemaire V, Boulanger K, Heymans O. Free flaps for pressure sore coverage. Annals of Plastic Surgery. 2008:631-4. exclusion reason - not relevant. [pmid: 18520197].
790 LeMaster KM. 5 million lives campaign. Reducing incidence and prevalence of hospital-acquired pressure ulcers at genesis medical center. Joint Commission Journal on Quality & Patient Safety. 2007:611-616. exclusion reason - background. [pmid: 18030863].
791 Leow M, Lim J, Lim TC. The superior gluteal artery perforator flap for the closure of sacral sores. Singapore Medical Journal. 2004:37-9. exclusion reason - not relevant. [pmid: 14976580].
792 Lepisto M, Lauri S, Eriksson E, Vahlberg T. Pressure ulcer patients in long-term care. A follow-up study. Reviews in Clinical Gerontology. 2004:91-103. exclusion reason - wrong outcome.
793 Lermusiaux P, Oxeda P, Lagrave G. The surgical treatment of pressure sores in paraplegic patients. Seventy-five cases. Annales de Chirurgie Plastique et Esthetique. 1985:166-170. exclusion reason - not relevant. [pmid: 2411196].
794 Lesavoy MA, Dubrow TJ, Korn HN, Cedars MG, Castro DJ. Sensibleflap coverage of pressure sores in patients with meningomyelocele. Plastic & Reconstructive Surgery. 1990:390-4. discussion 395–6. exclusion reason - background. [pmid: 2304990].
795 Lesourd B. Oral dietary supplements and aged patients. Nutrition Clinique et Metabolisme. 1997:55-60. exclusion reason - background.
796 Lessan-Salmassi D. Treatment of chronic decubital ulcers with fascio-cutaneous and cutaneous flaps in paraplegic patients. Unfallchirurg. 1989:358-362. exclusion reason - not relevant. [pmid: 2762823].
797 Levine JM. Pressure ulcer intervention goes far beyond physiological aspects of care. Caring for the Ages. 2007:21-21. exclusion reason - background.
798 Levine JM. Historical perspective: The impact of plaster-of-paris splints on pressure ulcer occurrence in world war ii. Advances in Skin & Wound Care. 2008:526-8. exclusion reason - background. [pmid: 18981756].
799 Levine JM, Lebovits S. Pearls for practice. Optimizing pressure ulcer care: A checklist for system change. Ostomy Wound Management. 2009:6-6. exclusion reason - background.
800 Levine JM, Peterson M, Savino F. Focus on: Pressure relief & wound care. Implementing the new cms guidelines for wound care. Nursing Homes: Long Term Care Management. 2005:110. exclusion reason - background.
801 Levine JM, Totolos E. Pressure ulcers: A strategic plan to prevent and heal them. Geriatrics. 1995:32-37. quiz 38–9. exclusion reason - background. [pmid: 7821827].
802 Lewandowicz E, Witmanowski H, Sobieszek D. Selection of surgical technique in treatment of pressure sores. Postepy Dermatologii i Alergologii. 2011:23-29. exclusion reason - not relevant.
803 Li Y-l, Xiao H-t, Qi Q, Zhou Z-p, Oka H, Moriguchi T. clinical efficacy of artery perforator-based flap in the repair of gluteal-sacral pressure sores. Zhonghua Shao Shang Za Zhi. 2007:32-5. exclusion reason - not relevant. [pmid: 17605251].
804 Li ZY, Cen Y, Gu MJ, Wang HS, Wang YJ. Rotating muscle flap in the treatment of refractory bedsore at sacrococcygeal region. Journal of Clinical Rehabilitative Tissue Engineering Research. 2007:10376-10377. exclusion reason - not relevant.
805 Liddle BJ. Reporting deaths to the coroner Pressure sores underreported. BMJ. 1993:1540. exclusion reason - background. [pmid: 8518695].
806 Lidman D, Ek AC, Dahllof AG, Eldh J, Palmer B, Hultling C. bedsores--etiology, prevention and treatment. Lakartidningen. 1989:3880-2. exclusion reason - not relevant. [pmid: 2811536].
807 Lidowski H. Namp: A system for preventing and managing pressure ulcers. Decubitus. 1988:28-37. exclusion reason - no original data. [pmid: 3254236].
808 Lievens PC, Delforge AL. Efficiency of infrared laser treatment examined in the healing of bedsores. Clinical Laser Monthly. 1992:159-60. exclusion reason - no original data. [pmid: 10148275].
809 Lile JL, Pase MN, Hoffman RG, Mace MK. The neuman systems model as applied to the terminally ill client with pressure ulcers. Advances in Wound Care. 1994:44-8. exclusion reason - background. [pmid: 7827747].
810 Lim R, Sirett R, Conine TA, Daechsel D. Clinical trial of foam cushions in the prevention of decubitis ulcers in elderly patients. Journal of Rehabilitation Research & Development. 1988:19-26. exclusion reason - wrong population. [pmid: 3361457].
811 Lima ACB, Guerra DM. evaluation of the cost of treating pressure ulcers in hospitalized patients using industrialized dressings. Ciencia & Saude Coletiva. 2011:267-77. exclusion reason - not relevant. [pmid: 21180834].
812 Lin H, Hou C, Chen A, Xu Z. Treatment of ischial pressure sores using a modified gracilis myofasciocutaneous flap. Journal of Reconstructive Microsurgery. 2010:153-7. exclusion reason - not relevant. [pmid: 19902407].
813 Lin H, Hou C, Chen A, Xu Z. Long-term outcome of using posterior-thigh fasciocutaneous flaps for the treatment of ischial pressure sores. Journal of Reconstructive Microsurgery. 2010:355-8. exclusion reason - not relevant. [pmid: 20183787].
814 Lin H, Hou C, Xu Z, Chen A. Treatment of ischial pressure sores with double adipofascial turnover flaps. Annals of Plastic Surgery. 2010:59-61. exclusion reason - not relevant. [pmid: 19801917].
815 Lin JY, Wu XH. the effect of bactroban cream for treating bedsores. Contemporary Nurse Issue. 1997:38-38. exclusion reason - not relevant.
816 Lin M-T, Chang K-P, Lin S-D, Lai C-S, Yang Y-L. Tensor fasciae latae combined with tangentially split vastus lateralis musculocutaneous flap for the reconstruction of pressure sores. Annals of Plastic Surgery. 2004:343-7. exclusion reason - not relevant. [pmid: 15385768].
817 Linder RM, Morris D. The surgical management of pressure ulcers: A systematic approach based on staging. [erratum appears in decubitus 1990 aug;3(3):8]. Decubitus. 1990:32-8. exclusion reason - background. [pmid: 2357277].
818 Lindholm C, Bergsten A, Berglund E. Chronic wounds and nursing care. Journal of Wound Care. 1999:5-10. exclusion reason - not relevant. [pmid: 10214192].
819 Lipschitz DA. Approaches to the nutritional support of the older patient. Clinics in Geriatric Medicine. 1995:715-24. exclusion reason - background. [pmid: 8556696].
820 Lisito P, Rousson B, Hocquart J. Surgical treatment of pelvic pressure ulcers. Annales de Readaptation et de Medecine Physique. 1986:385-393. exclusion reason - not relevant.
821 Liu G. Progress on prevention and treatment of patients with bed sore. [chinese]. Chinese Nursing Research. 2005:2082-2084. exclusion reason - background.
822 Liu Y. Clinical effect on yousuo mixed solution to treat decubitus ulcer. [chinese]. Shanxi Nursing Journal. 1999:174-175. exclusion reason - not relevant.
823 Liu Y, Chen QQ, Hou CL. Treatment of decubitus ulcers in sacrum region with fasciocutaneous flaps. Chinese Journal of Clinical Rehabilitation. 2002:834-845. exclusion reason - not relevant.
824 Liu Y, Zhang X, Zhang C. clinical typing and surgical principle of pressure sore. Chung-Kuo Hsiu Fu Chung Chien Wai Ko Tsa Chih/Chinese Journal of Reparative & Reconstructive Surgery. 2007:932-6. exclusion reason - not relevant. [pmid: 17933225].
825 Livesley NJ, Chow AW. Infected pressure ulcers in elderly individuals. Clinical Infectious Diseases. 2002:1390-6. exclusion reason - background. [pmid: 12439803].
826 Livne M, Steinmann M. Pressure ulcer prevention project: An international outcomes report from israel. Outcomes Management. 2002:99-102. exclusion reason - background. [pmid: 12134380].
827 Ljungberg S. Comparison of dextranomer paste and saline dressings for management of decubital ulcers. Clinical Therapeutics. 1998:737-43. exclusion reason - wrong outcome. [pmid: 9737833].
828 Llagostera Pages M. care of the skin. Atencion Primaria. 2006:65-71. exclusion reason - background. [pmid: 17286938].
829 Llanos S, Calderon W, Searle S, Quintas M. Improvement of the bipedicled fascial flap with a cutaneous v and y island for coverage of the heel. Plastic & Reconstructive Surgery. 2006:297-8. exclusion reason - no original data. [pmid: 16816744].
830 Lloyd-Jones M. The role of eclypse adherent sacralâ® in managing sacral pressure ulcers. British Journal of Community Nursing. 2011:S38-42. exclusion reason - not relevant.
831 Loehne HB. A trial of a heel pressure relieving device proves efficacious in a long term care facility, addressing complete heel suspension 24/7 with patient comfort, leading to use throughout the continuum of care. 39th annual wound, ostomy and continence nurses annual conference. Journal of Wound, Ostomy & Continence Nursing. 2007:S45-S45. exclusion reason - no original data.
832 Loehner D. Why use a film dressing?. Advances in Wound Care. 1995:6. exclusion reason - background.
833 Lokhvitskii SV, Klimova NV. the diagnosis and treatment of chronic osteomyelitis in patients with spinal cord trauma. Vestnik Khirurgii Imeni i - i - Grekova. 1996:60-2. exclusion reason - not relevant. [pmid: 8753963].
834 Lomas C Pct leads by example on community ‘never events’ Nursing Times 20101exclusion reason - background. 20608436
835 Lontoft E, Kjeldsen H. long-term results after surgical treatment of pressure sores. Ugeskrift for Laeger. 1986:1148-9. exclusion reason - not relevant. [pmid: 12187948].
836 Lopez RodriguezL, Garrido Diaz I, Seda Diestro J, Rodriguez Hurtado A, Fernandez Cordon I. what to do when there is no evidence. Revista de Enfermeria. 2007:58-61. exclusion reason - background. [pmid: 17380636].
837 Lopez TC, Porta UF, Antunez MDR, Nadal MJN. the best introduced measures for the prevention and treatment of pressure sores in corporacion sanitaria clinic of barcelona. Revista de Enfermeria. 2008:34-5. exclusion reason - background. [pmid: 18564785].
838 Lowthian P. Pegasus airwave and bi-wave plus. British Journal of Nursing. 1022. 1995:1020-4. exclusion reason - background. [pmid: 7580086].
839 Lowthian P. ‘Last-resort’ dressings for intractable pressures sores. British Journal of Nursing. 1995:1183-4. 1186. 1188. 9. exclusion reason - background. [pmid: 8696085].
840 Lowthian P. The egerton convertible ii and the elite 3 bed system. British Journal of Nursing. 120. 1996:118-3. exclusion reason - background. [pmid: 8680245].
841 Lu CX. use of a dufourmentel flap in repairing lumbosacral bed sore (a report of 7 cases). Chung-Hua Cheng Hsing Shao Shang Wai Ko Tsa Chih - Chinese Journal of Plastic Surgery & Burns. 1989:197-8. 238. exclusion reason - not relevant. [pmid: 2514027].
842 Lubin BS, Powell T. Pressure sores and specialty beds: Cost containment and ensurance of quality care. Journal of ET Nursing. 1991:190-7. exclusion reason - background. [pmid: 1954298].
843 Lucas C, Stanborough RW, Freeman CL, De Haan RJ. Efficacy of low-level laser therapy on wound healing in human subjects: A systematic review. Lasers in Medical Science. 2000:84-93. exclusion reason - Systematic Review, not directly used.
844 Lucich S, Haan J. Ankle foot orthoses in prevention and treatment of heel pressure ulcers: A physical therapy perspective. 2008. exclusion reason - no original data.
845 Lucke K, Jarlsberg C. How is the air-fluidized bed best used?. American Journal of Nursing. 1985:1338. 1340. exclusion reason - background. [pmid: 3852639].
846 Lukanc C, Kramer E, King RB, Carle TV, Yarkony GM. Duoderm super(tm): A new treatment for pressure sores. exclusion reason - unable to find.
847 Lum C, Cheung W, Chow PM, Woo J, Hui E, Or KH. Use of a hydrogel in pressure sore management: A randomized, controlled clinical trial. Proceedings of the 5th European Conference on Advances in Wound Management. 1995. exclusion reason - no original data.
848 Luscher NJ. decubitus ulcers of the pelvic area. Diagnosis and surgical therapy. Aktuelle Probleme in Chirurgie und Orthopadie. 1989:3-152. exclusion reason - not relevant. [pmid: 2567125].
849 Luscher NJ. value of surgical treatment of decubitus ulcer in geriatric patients. Therapeutische Umschau. 1991:341-6. exclusion reason - not relevant. [pmid: 1871689].
850 Luscher NJ, de Roche R, Krupp S, Kuhn W, Zach GA. The sensory tensor fasciae latae flap: A 9-year follow-up. Annals of Plastic Surgery. 1991:306-10. discussion 311. exclusion reason - not relevant. [pmid: 1872535].
851 Luscher NJ, Kuhn W, Zach GA. Rhomboid flaps in surgery for decubital ulcers: Indications and results. Annals of Plastic Surgery. 1986:415-21. exclusion reason - not relevant. [pmid: 3273059].
852 Lyder C, van Rijswijk L. Pressure ulcer prevention and care: Preventing and managing pressure ulcers in long-term care: An overview of the revised federal regulation. Ostomy Wound Management. 2005:2-6. exclusion reason - background. [pmid: 16089049].
853 Lyder CAE. Chapter 12 Pressure ulcers: A patient safety issues. Hughes rg, editor. P H S Agency for Health Care Policy and Research, U.S. Department of Health and Human Services. Patient safety and quality: An evidence-based handbook for nurses. Rockville, MD. 2008. exclusion reason - background.
854 Lyder CH. Conceptualization of the stage 1 pressure ulcer. Journal of ET Nursing. 1991:162-5. exclusion reason - background. [pmid: 1892947].
855 Lyder CH. Examining the inclusion of ethnic minorities in pressure ulcer prediction studies. Journal of Wound, Ostomy, & Continence Nursing. 1996:257-60. exclusion reason - background. [pmid: 9043271].
856 Lyder CH. Pressure ulcer prevention and management. Annual Review of Nursing Research. 2002:35-61. exclusion reason - Systematic Review, not directly used. [pmid: 12092517].
857 Lyder CH. Pressure ulcer prevention and management. JAMA. 2003:223-6. exclusion reason - background. [pmid: 12517234].
858 Lyder CH. Is pressure ulcer care evidence based or evidence linked?. Journal of Wound Care. 2005:2-3. exclusion reason - background.
859 Lyder CH. Implications of pressure ulcers and its relation to federal tag 314. Annals of Long Term Care. 2006:19-24. exclusion reason - background.
860 Lyder CH. Effective management of pressure ulcers. A review of proven strategies. Advance for Nurse Practitioners. 2006:32-7. quiz 38. exclusion reason - wrong population. [pmid: 16977895].
861 Lyder CH, Ayello EA. Annual checkup: The cms pressure ulcer present-on-admission indicator. Advances in Skin & Wound Care. 2009:476-84. exclusion reason - background. [pmid: 20026923].
862 Lyder CH, Empleo-Frazier O, McGee D. Evaluating the clinical and economic outcomes of implementing a standardized algorithm to heal stage ii pressure ulcers. Fourth Australian Wound Management Association Conference. 2002. exclusion reason - no original data.
863 Lydon P. The local treatment of pressure sores. Irish Medical Journal. 1994:72-3. exclusion reason - no original data. [pmid: 8056542].
864 Lyons YJ. Wound care--monitoring practice. Nursing Times. 1994:69-78. exclusion reason - background. [pmid: 8177778].
865 Macario A. Economic evaluation of noncontact normothermic wound therapy for treatment of pressure ulcers. Expert Review of Pharmacoeconomics & Outcomes Research. 2002:211-7. exclusion reason - wrong outcome. [pmid: 19807413].
866 Macario A, Dexter F. Is noncontact normothermic wound therapy cost effective for the treatment of stages 3 and 4 pressure ulcers?. Wounds: A Compendium of Clinical Research & Practice. 2002:93-106. exclusion reason - wrong outcome.
867 Mackey D. Support surfaces: Beds, mattresses, overlays-oh my!. Nursing Clinics of North America. 2005:251-65. exclusion reason - background. [pmid: 15924893].
868 Maehata Y, Matsuda H, Miyajima Y, Takasaki M. Experience in use of solcoseryl ointment in elderly patients suffering from decubitus. Japanese Pharmacology and Therapeutics. 1999:99-105. exclusion reason - not relevant.
869 Maeshige N, Terashi H, Aoyama M, Torii K, Sugimoto M, Usami M. Effect of ultrasound irradiation on alpha-sma and tgf-beta1 expression in human dermal fibroblasts. Kobe Journal of Medical Sciences. 2011:E242-52. exclusion reason - wrong intervention. [pmid: 21937873].
870 Maguina P, Kalimuthu R. Posterior rectal hernia after vacuum-assisted closure treatment of sacral pressure ulcer. Plastic & Reconstructive Surgery. 2008:46e-47e. exclusion reason - not relevant. [pmid: 18594380].
871 Maida V, Ennis M, Corban J. Wound outcomes in patients with advanced illness. International Wound Journal. 2012. exclusion reason - wrong population.
872 Maklebust J. Treating pressure ulcers in the home. Home Healthcare Nurse. 1999:307-15. quiz 316. exclusion reason - background. [pmid: 10562004].
873 Maklebust J. An update on horizontal patient support surfaces. Ostomy Wound Management. 1999:70S-77S. quiz 78S-79S. exclusion reason - background. [pmid: 10085977].
874 Maklebust JA, Mondoux L, Sieggreen M. Pressure relief characteristics of various support surfaces used in prevention and treatment of pressure ulcers. Journal of Enterostomal Therapy. 1986:85-9. exclusion reason - wrong population. [pmid: 3635540].
875 Malm M, Lundeberg T. Effect of low power gallium arsenide laser on healing of venous ulcers. Scandinavian Journal of Plastic & Reconstructive Surgery & Hand Surgery. 1991:249-251. exclusion reason - wrong population. [pmid: 1780722].
876 Mandal A. Role of topical negative pressure in pressure ulcer management. Journal of Wound Care. 2007:33-5. exclusion reason - background. [pmid: 17334144].
877 Mandracchia VJ, Sanders SM, Frerichs JA. The use of becaplermin (rhpdgf-bb) gel for chronic nonhealing ulcers. A retrospective analysis. Clinics in Podiatric Medicine & Surgery. 2001:189-209. viii. exclusion reason - no original data. [pmid: 11344978].
878 Mandrekas AD, Mastorakos DP. The management of decubitus ulcers by musculocutaneous flaps: A five-year experience. Annals of Plastic Surgery. 1992:167-74. exclusion reason - not relevant. [pmid: 1567119].
879 Manesh AO, Flemming K, Cullum NA, Ravaghi H. Electromagnetic therapy for treating pressure ulcers. Cochrane Database of Systematic Reviews. 2009. exclusion reason - Systematic Review, not directly used.
880 Manzanero-Lopez E, P-LB. Evaluation of a new dressing in the management of pressure sores. 2nd World Union of Wound Healing Societies Meeting. 2004. exclusion reason - no original data.
881 Mao CL, Rivet AJ, Sidora T, Pasko MT. Update on pressure ulcer management and deep tissue injury. Annals of Pharmacotherapy. 2010:325-32. exclusion reason - background. [pmid: 20118142].
882 Marchina MD, Renzi G. A new antiseptic preparation used for the disinfection of cutaneous distrophic ulcers. Chronica Dermatologica. 1997:873-885. exclusion reason - wrong intervention.
883 Margara A, Merlino G, Bergamin F, Borsetti M, Borsetti G. Surgical treatment of pressure sores: Experience in 333 cases. Chirurgia. 2002:143-145. exclusion reason - not relevant.
884 Margara A, Merlino G, Borsetti M, Bergamin F, Borsetti G. A proposed protocol for the surgical treatment of pressure sores based on a study of 337 cases. European Journal of Plastic Surgery. 2003:57-61. exclusion reason - wrong intervention.
885 Margolis DJ. Utility of direct current in decubitus ulcers. Archives of Dermatology. 1994:660-1. exclusion reason - no original data. [pmid: 8179350].
886 Margolis DJ, Lewis VL. A literature assessment of the use of miscellaneous topical agents, growth factors, and skin equivalents for the treatment of pressure ulcers. Dermatologic Surgery. 1995:145-8. exclusion reason - Systematic Review, not directly used. [pmid: 7894932].
887 Marinho AdM. drug combinations in the care of bed sores. Revista Brasileira de Enfermagem. 1997:257-74. exclusion reason - not relevant. [pmid: 9775937].
888 Martin SJ, Corrado OJ, Kay EA. Enzymatic debridement for necrotic wounds. Journal of Wound Care. 1996:310-1. exclusion reason - wrong outcome. [pmid: 8954418].
889 Martinez Cuervo F, Pateras Galofre E. The effectiveness of hyperoxygenated fatty acids in the care of skin perilesional, the prevention of the pressure ulcers, vascular ulcers and diabetic foot. Gerokomos. 2009:41-46. exclusion reason - background.
890 Martinez CuervoF, Segovia Gomez T, Alonso Perez F, Verdu Soriano J, De Con Redondo J, Lahuerta Garcia T. evaluation of the clinical effectiveness of the dressing permafoam for the treatment of chronic ulcers. Revista de Enfermeria. 2005:29-34. exclusion reason - not relevant. [pmid: 16060325].
891 Masanovic MG, Roques C, Meaume S, Rochet J-M. supports to help the prevention and treatment of sores. Soins; La Revue de Reference Infirmiere. 2009:40-3. exclusion reason - not relevant. [pmid: 19306559].
892 Maslauskas K, Samsanavicius D, Rimdeika R, Kaikaris V. Surgical treatment of pressure ulcers: An 11-year experience at the department of plastic and reconstructive surgery of hospital of kaunas university of medicine. Medicina (Kaunas, Lithuania). 2009:269-75. exclusion reason - not relevant. [pmid: 19423957].
893 Masquelet AC, Nordin JY, Pages C. Closure of sacral and ischiatic raw areas with musculo-cutaneous flaps. Presse Medicale. 1985:277-279. exclusion reason - not relevant. [pmid: 3157110].
894 Mathewson C, Adkins VK, Lenyoun MA, Schmidt AM, Jones ML. Using telemedicine in the treatment of pressure ulcers. Ostomy Wound Management. 1999:58-62. exclusion reason - background. [pmid: 10687659].
895 Mathiesen J. from times gone by--treatment of bed sores. Tidsskriftet Sykepleien. 1997:29. exclusion reason - background. [pmid: 9355644].
896 Mathus-Vliegen EMH. Nutritional status, nutrition, and pressure ulcers. Nutrition in Clinical Practice. 2001:286-291. exclusion reason - background.
897 Matsumoto H, Oshima Y, Yoneda M. Effect of compressive stress on the extracellular matrix in human fibroblasts and endothelial cells -- relation to body pressure when pressure ulcers develop. [japanese]. Journal of Japan Academy of Nursing Science. 2009:3-12. exclusion reason - background.
898 Matsumoto H, Oshima Y, Yoneda M. Analysis of specific distribution of ecm degraded-product in wound surface of pressure ulcer. [japanese]. Journal of Japan Academy of Nursing Science. 2009:13-23. exclusion reason - background.
899 Matsuzaki K, Kumagai N. Minimum invasive surgery for the treatment of pressure sores under local anesthesia. 3rd Congress of the World Union of Wound Healing Societies. Metro Toronto Convention Centre, Toronto, Ontario (Canada). 2008. exclusion reason - no original data.
900 Mattie AS, Webster BL. Centers for medicare and medicaid services’ “never events”: An analysis and recommendations to hospitals. Health Care Manager. 2008:338-49. exclusion reason - background. [pmid: 19011417].
901 Mauckner P. the treatment of heel pressure ulcer with v. A.C. Therapy using the new v. A.C. Granufoam heel-dressing. Zentralblatt fur Chirurgie. 2004:S104-7. exclusion reason - background. [pmid: 15168303].
902 Mawson AR, Siddiqui FH, Biundo JJ Jr. Enhancing host resistance to pressure ulcers: A new approach to prevention. Preventive Medicine. 1993:433-50. exclusion reason - background. [pmid: 8327423].
903 Mayer S. Nutritional therapy in decubitus. Journal fur Ernahrungsmedizin. 2002:11-12. exclusion reason - not relevant.
904 McCormack J. Double jeopardy: Answers to wound care cost questions. Materials Management in Health Care. 1996:46. exclusion reason - background. [pmid: 10156374].
905 McCowan M, Aitken F. Pressure sore protocol. Journal of Wound Care. 1997:248. author reply 249. exclusion reason - background. [pmid: 9256735].
906 McCulloch JM. The role of physiotherapy in managing patients with wounds. Journal of Wound Care. 1998:241-4. exclusion reason - background. [pmid: 9677994].
907 McGaughey H, Dhamija S, Oliver L, Porter-Armstrong A, McDonough S. Pulsed electromagnetic energy in management of chronic wounds: A systematic review. Physical Therapy Reviews. 2009:132-146. exclusion reason - Systematic Review, not directly used.
908 McGinnis E, Stubbs N. Pressure relieving devices for treating heel pressure ulcers. Cochrane Database of Systematic Reviews. 2009. exclusion reason - background.
909 McGinnis E, Stubbs N. Pressure-relieving devices for treating heel pressure ulcers. Cochrane Database of Systematic Reviews. 2011. [pmid: 21901698]. exclusion reason - background.
910 McGregor JC. An audit of mortality in patients with pressure sores admitted to a regional plastic surgery unit over a 20-year period (1972–92). Journal of the Royal College of Surgeons of Edinburgh. 1995:313-4. exclusion reason - background. [pmid: 8523309].
911 McGregor JC, Hoogbergen MM. Audit of pressure sores treated in a regional plastic surgery unit (1971–1990). Journal of the Royal College of Surgeons of Edinburgh. 1991:399-401. exclusion reason - not relevant. [pmid: 1774709].
912 McInnes E, Jammali-Blasi A, Bell-Syer SE, Dumville JC, Cullum N. Support surfaces for pressure ulcer prevention. Cochrane Database of Systematic Reviews. 2011:CD001735. exclusion reason - background. [pmid: 21491384].
913 McInnes E. E National Institite for Clinical. The use of pressure-relieving devices (beds, mattresses and overlays) for the prevention of pressure ulcers in primary and secondary care. Journal of Tissue Viability. 2004:4-6. 8, 10 passim. exclusion reason - background. [pmid: 14768130].
914 McLeod AG. Principles of alternating pressure surfaces. Advances in Wound Care. 1997:30-6. exclusion reason - background. [pmid: 9450404].
915 McMullen D. Clinical experience with a calcium alginate dressing. Dermatology Nursing. 1991:216-9. 270. exclusion reason - not relevant. [pmid: 1831374].
916 McNees P. Pressure ulcers and other chronic wounds in patients with and patients without cancer: A retrospective, comparative analysis of healing patterns. Ostomy Wound Management. 2007:70-8. exclusion reason - wrong outcome. [pmid: 17293631].
917 Meaume S. A randomized controlled study to compare a sequential treatment using alginate-cmc and hydrocolloid dressing or hydrocolloid dressing alone in decubitus ulcer management. 9th European Conference on Advances in Wound Management. 1999. exclusion reason - no original data.
918 Meaume S. leg and decubitus ulcers, unreserved treatment. Soins; La Revue de Reference Infirmiere. 2004:S5-7. exclusion reason - not relevant. [pmid: 15384752].
919 Meaume S. 9--clinical aspects: Decubitus ulcers. Local treatment of decubitus ulcers. Soins; La Revue de Reference Infirmiere. 2004:23-5. exclusion reason - not relevant. [pmid: 15551634].
920 Meaume S. nursing considerations of bedsore dressings. Revue de L’Infirmiere. 2010:23-4. exclusion reason - not relevant. [pmid: 20536087].
921 Meaume S, Bohbot S. healing of chronic wounds. Use of dressings. Soins; La Revue de Reference Infirmiere. 1995:10-4. exclusion reason - not relevant. [pmid: 7716575].
922 Meaume S, Bonnefoy M, Guihur B, De Montalembert C, Remy F, Bohbot S. decubitus ulcers in the aged. Local care and results of a randomized multicenter study. Soins; La Revue de Reference Infirmiere. 1996:40-5. exclusion reason - not relevant. [pmid: 8954476].
923 Meaume S, Faucher N, Henry O, Belmin J. A randomised controlled study to compare a sequential treatment using alginate-cmc and hydrocolloid dressing to hydrocolloid dressing alone in decubitus ulcers management. 12th Conference of the European Wound Management Association. 2002. exclusion reason - no original data.
924 Meaume S, Gemmen E. Cost-effectiveness of wound management in france: Pressure ulcers and venous leg ulcers. Journal of Wound Care. 2002:219-24. exclusion reason - background. [pmid: 12096580].
925 Meaume S, Guihur B. local treatments of confirmed decubitus ulcers. Revue de L’Infirmiere. 1995:30-2. 37. 42. exclusion reason - not relevant. [pmid: 7659937].
926 Meaume S Hamon-Mekki F Teot L wounds and bedsores 2000 Soins; La Revue de Reference Infirmiere 20001exclusion reason - background. 11040816
927 Meaume S, Sayag J, Bonnefoy M, Brasseur C, Drunat O, Sebbane G, et al. Calcium alginate dressing (algosteril) in the management of full-thickness pressure sores: A controlled, randomized study on elderly patients. Proceedings of the 5th European Conference on Advances in Wound Management. 1995. exclusion reason - no original data.
928 Meaume S, Vallet D, Morere MN, Teot L. Evaluation of a silver-releasing hydroalginate dressing in chronic wounds with signs of local infection. Zeitschrift fur Wundheilung. 2006:236-245. exclusion reason - not relevant. [pmid: 16240620].
929 Medeiros ABF, AdF Lopes CH, Jorge MSB. analysis of prevention and treatment of the pressure ulcers proposed by nurses. Revista Da Escola de Enfermagem Da Usp. 2009:223-8. exclusion reason - background. [pmid: 19437876].
930 Medina A, Scott PG, Ghahary A, Tredget EE. Pathophysiology of chronic nonhealing wounds. Journal of Burn Care & Rehabilitation. 2005:306-19. exclusion reason - background. [pmid: 16006837].
931 Meesterberends E, Halfens R, Lohrmann C, de Wit R. Pressure ulcer guideline development and dissemination in europe. Journal of Clinical Nursing. 2010:1495-503. exclusion reason - background. [pmid: 20579194].
932 Mehta A, Baker TA, Shoup M, Brownson K, Amde S, Doren E, Shah S, Kuo P, Angelats J. Biplanar flap reconstruction for pressure ulcers: Experience in patients with immobility from chronic spinal cord injuries. American Journal of Surgery. 2012:303-6. discussion 306–7. exclusion reason - not relevant. [pmid: 22364900].
933 Mehta S, Teasell RW, Foulon B, Warburton DER, Connolly S, Wolfe DL, Hsieh JTC, Regan M, Lam T, Krassioukov A, Craven BC. Effectiveness of electrical stimulation therapy in sci: Systematic review. Journal of Spinal Cord Medicine. 2009:478. exclusion reason - Systematic Review, not directly used.
934 Meier K, Nanney LB. Emerging new drugs for wound repair. Expert Opinion on Emerging Drugs. 2006:23-37. exclusion reason - background. [pmid: 16503824].
935 Meijers JMM, Schols JMGA, Jackson PA, Langer G, Clark M, Halfens RJG. Evaluation of the dissemination and implementation of a nutritional guideline for pressure ulcer care. Journal of Wound Care. 2007:201-5. exclusion reason - background. [pmid: 17552402].
936 Melo PG, Pedrozo MC, Felice TD, Mendes RCD, Schmitz WO. The effect of nifedipine gel in the treatment for pressure sores. Latin American Journal of Pharmacy. 2008:410-414. exclusion reason - not relevant.
937 Meltem C, Esra C, Hasan F, Ali D. The gluteal perforator-based flap in repair of pressure sores. British Journal of Plastic Surgery. 2004:342-7. exclusion reason - not relevant. [pmid: 15145738].
938 Mendonca DA, Papini R, Price PE. Negative-pressure wound therapy: A snapshot of the evidence. International Wound Journal. 2006:261-71. exclusion reason - background. [pmid: 17199762].
939 Meuleneire F. Local treatment of heel pressure ulcers with a silicone foam dressing. exclusion reason - no original data.
940 Michael J. Topical use of pvp-i (betadine) preparations in patients with spinal cord injury. Drugs Under Experimental & Clinical Research. 1985:107-9. exclusion reason - wrong intervention. [pmid: 3836120].
941 Michael Rieger U. Correspondence (letter to the editor): Treatment principles for decubitus ulcers. Deutsches Arzteblatt International. 2011:354-5. exclusion reason - background. [pmid: 21655463].
942 Miller S. Can pimecrolimus enhance wound healing?. Journal of the American Podiatric Medical Association. 2009:173-4. exclusion reason - not relevant. [pmid: 19299357].
943 Miller T, Draper S, White M. Development and implementation of an evidenced-based pressure ulcer reduction program in a multi-center health care facility in canada. exclusion reason - background.
944 Milne C, Coccarelli A, Lassy M. A comparison of collagenase to hydrogel dressings in wound debridement. Journal of Wound, Ostomy & Continence Nursing. 2011:S3-S3. exclusion reason - wrong outcome.
945 Milne C, Saucier D, Motta G. A one year evaluation of a variable pressure foaming (vpf) mattress with surface modification technology (smt) for prevention and treatment of pressure ulcers in general medical-surgical patients. exclusion reason - Scientific Information Packets, not directly used.
946 Minabe T. Versatility of the gluteus maximus musculocutaneous flap for repair of pressure sores. Japanese Journal of Plastic and Reconstructive Surgery. 1998:1103-1111. exclusion reason - not relevant.
947 Minagawa T, Kimura C, Shichinohe R, Ricia O, Takano T. Treatment of trochanteric pressure ulcers with undermined edges using negative pressure wound therapy combined with skin graft. Japanese Journal of Plastic and Reconstructive Surgery. 2006:565-572. exclusion reason - not relevant.
948 Minakata T, Kyutoku S, Kurooka S. A pulsatile jet irrigation system for bedside refractory ulcer treatment. Japanese Journal of Plastic and Reconstructive Surgery. 2003:1173-1177. exclusion reason - background.
949 Minatel DG, Pereira AMS, Chiaratti TM, Pasqualin L, Oliveira JCN, Couto LB, Lia RCC, Cintra JM, Bezzon MFA, Franca SC. Clinical study for the validation of the efficacy of ointment containing barbatimao (stryphnodendron adstringens (mart.) coville)* on healing of decubitus ulcers. Revista Brasileira de Medicina. 2010:250-256. exclusion reason - not relevant.
950 Minato S, Nara T, Koizumi R, Honjo S, Kashiwa K, Suzuki H, Sodei B, Shiraishi N, Kuriyagawa A, Hakozaki M, Kimura H, Okutu E, Aoyama K. Follow-up study of pressure ulcers treated by a musculocutaneous flap, muscle flap and other. Japanese Journal of Plastic and Reconstructive Surgery. 1990:555-562. exclusion reason - not relevant.
951 Minato S, Tochinai H, Aoyama K, Yamataka H, Usui T. Choice of operative method for decubitus ulcer. Japanese Journal of Plastic and Reconstructive Surgery. 1998:1095-1101. exclusion reason - background.
952 Miner KJ, Salome N. Papain-urea chlorophyllin copper complex sodium ointment (puc) and trypsin, balsam peru, and castor oil (tbc) in the treatment and healing of recurrent stage ii and stage iii pressure ulcers. Journal of Wound, Ostomy & Continence Nursing. 2006:S11-S11. exclusion reason - not relevant.
953 Mirkovitch V, Macarone-Palmieri R, Sorges L. Treatment of skin wounds, open and contaminated with a polyvinyl-alcohol powder. Helvetica Chirurgica Acta. 1987:103-106. exclusion reason - not relevant.
954 Mitchell SL, Kiely DK, Lewis A, Lipsitz LA. The risk factors and impact of survival of feeding tube placement in nursing home residents with severe cognitive impairment. Archives of Internal Medicine. 1997:327-332. exclusion reason - wrong population. [pmid: 9040301].
955 Mithat AkanI, Sungur N, Ozdemir R, Kilinc H, Sensoz O. “Pac man” flap for closure of pressure sores. Annals of Plastic Surgery. 2001:421-5. exclusion reason - not relevant. [pmid: 11324886].
956 Mitish VA, Svetukhin AM, Glyantsev SP. Pressure sores in pregnancy. British Journal of Plastic Surgery. 1998:573. exclusion reason - background. [pmid: 9924423].
957 Mitiuk OI. the use of extracorporeal stimulation of venous flow in the treatment of trophic ulcer in elderly and senile patients. Klinicheskaia Khirurgiia. 1999:22-4. exclusion reason - not relevant. [pmid: 10370312].
958 Mitsukawa N, Hori S, Mukai H. The surgical treatment of methicillin-resistant staphylococcus aureus-infected pressure sores. Japanese Journal of Plastic and Reconstructive Surgery. 1995:155-159. exclusion reason - not relevant.
959 Mittmann N, Chan BC, Craven BC, Isogai PK, Houghton P. Evaluation of the cost-effectiveness of electrical stimulation therapy for pressure ulcers in spinal cord injury. Archives of Physical Medicine & Rehabilitation. 2011:866-72. exclusion reason - background. [pmid: 21621661].
960 Miyachi Y. Recent trend in pressure ulcer treatment in japan. Japan Medical Association Journal. 2006:62-69. exclusion reason - background.
961 Miyachi Y, Imamura S. Improved healing of pressure sores with sugar and povidone-iodine. Current Therapeutic Research - Clinical and Experimental. 1991:81-87. exclusion reason - wrong intervention.
962 Miyaji H, Sakurai H, Kikawada M, Yamaguchi K, Kimura A, Fujiwara T, Imada N, Imai M, Iwamoto T, Takasaki M. treatment of bedsores--combination of therapies depended the experimental design method. Nippon Ronen Igakkai Zasshi - Japanese Journal of Geriatrics. 2005:90-8. exclusion reason - not relevant. [pmid: 15732367].
963 Miyamoto S, Minabe T, Harii K. A gluteal thigh flap based on cruciate anastomosis for the repair of ischial pressure ulcers. Japanese Journal of Plastic and Reconstructive Surgery. 2005:1027-1034. exclusion reason - not relevant.
964 Miyauchi H, Shimada T, Nishii M, Shikai T, Hisadome H, Tashiro m. Comparative study for treatment of decubitus using three ointments; reflap, providone iodine sugar and a combination of both ingredients. Skin Research. 1990:547-563. exclusion reason - not relevant.
965 Miyazaki K, Yoshioka K, Hayase M, Ohkawa N, Kitazawa E, Nakade S. Wound management for pressure ulcer developed on neurofibroma : Negative pressure therapy using multiple ddressings. exclusion reason - no original data.
966 Modenes Casillas JC, Porras Pastor JM, Pelet Larres M, Camara Diaz S, Jove Lance E, Santalo Rios I, Palacio Pellon JL. Assessment of the satisfaction and effectiveness of the hydrocoloid [sic] dressing sureskin ii in the treatment of acute and chronic wounds. [spanish]. Gerokomos. 2006:225-234. exclusion reason - not relevant.
967 Mody GN, Nirmal IA, Duraisamy S, Perakath B. A blinded, prospective, randomized controlled trial of topical negative pressure wound closure in india. Ostomy/wound management. 2008:36-46. exclusion reason - wrong population. [pmid: 19104122].
968 Moher D, Liberati A, Tetzlaff J, Altman DG. Preferred reporting items for systematic reviews and meta-analyses: The prisma statement. PLoS Med. 2009/07/22 ed. 2009:e1000097. [pmid: 19621072]. exclusion reason - background.
969 Moisidis E, Heath T, et al. A prospective, blinded, randomized, controlled clinical trial of topical negative pressure use in skin grafting. Plastic & Reconstructive Surgery. 2004:917-922. exclusion reason - wrong population. [pmid: 15468399].
970 Mol BJP, Hermans MBM, Lambregts RPM, Mortel v, Wesseling GJM. Ultraviolet light in the treatment of pressure sores. Nederlands Tijdschrift Fysiotherapie. 1994:28-34. exclusion reason - not relevant.
971 Monetta L. use of papain in curative nursing actions. Revista Brasileira de Enfermagem. 1987:66-73. exclusion reason - not relevant. [pmid: 3504013].
972 Monsbakken JA, Wangensteen S. pressure sores--occurrence, prevention and treatment. Sykepleien. 1986:13-6. 38. exclusion reason - not relevant. [pmid: 3633649].
973 Montorio L, Vicari GB, Ferraro M. The use of iruxol cream in the treatment of cutaneous ulceration of various origins. Giornale Italiano di Dermatologia e Venereologia. 1985:XXIX-XXXIV. exclusion reason - not relevant. [pmid: 2995244].
974 Moody M. Tissue viability. Illuminating research. Nursing Times. 1987:62. exclusion reason - background. [pmid: 3684650].
975 Moody M. The role of a pressure relief dressing in the prevention and treatment of pressure sores. 3rd European Conference on Advances in Wound Management. 1993. exclusion reason - no original data.
976 Moody M. Review of the stm range of pressure distribution products. British Journal of Nursing. 1998:1078-80. exclusion reason - background. [pmid: 9830917].
977 Mookhoek EJ. pressure sores in a psychiatric hospital: A report of 10 years of systematic decubitus treatment. Tijdschrift voor Gerontologie en Geriatrie. 1994:54-7. exclusion reason - not relevant. [pmid: 8197596].
978 Moore JH Jr. The role of plastic surgery in the treatment of pressure ulcers. Topics in Spinal Cord Injury Rehabilitation. 1996:26-36. exclusion reason - background.
979 Moore Z, Cowman S. A systematic review of wound cleansing for pressure ulcers. Journal of Clinical Nursing. 2008:1963-72. exclusion reason - Systematic Review, not directly used. [pmid: 18705777].
980 Moore Z, Ramanelli M. Topical management of infected grade 3 and 4 pressure ulcers. Ewma position document: Management of wound infection. London, United Kingdom. Medical Education Partnership Ltd. 2006:11-13. exclusion reason - no original data.
981 Moore ZE, Cowman S. Repositioning for treating pressure ulcers. Cochrane Database of Systematic Reviews. 2009:CD006898. exclusion reason - Systematic Review, not directly used. [pmid: 19370658].
982 Moore ZEH, Cowman S. Wound cleansing for pressure ulcers. Cochrane Database of Systematic Reviews. 2005:CD004983. exclusion reason - Systematic Review, not directly used. [pmid: 16235386].
983 Morand JJ. management of ulcerated graft in patients with joint prosthesis. Annales de Dermatologie et de Venereologie. 1999:91-5. exclusion reason - not relevant. [pmid: 10095905].
984 Moreno-Guerin BanosA, Pelaez Nora Y, Perez-Godoy Diaz E, Paredes Gonzalez D. approach and control of pressure ulcer infected in the heel. Revista de Enfermeria. 2008:16-7. exclusion reason - not relevant. [pmid: 18497001].
985 Morison MJ. Delayed pressure sore healing can be prevented. Professional Nurse. 1989:332-6. exclusion reason - background. [pmid: 2717631].
986 Morley M. Managing decubitus ulcers. Canadian Nurse. 1990:19-20. exclusion reason - background. [pmid: 2224819].
987 Morris L. Clinical efficacy of c-view transparent film wound dressing. British Journal of Nursing. 2001:616-20. exclusion reason - not relevant. [pmid: 12066036].
988 Mosher BA, Cuddigan J, Thomas DR, Boudreau DM. Outcomes of 4 methods of debridement using a decision analysis methodology. Advances in Wound Care. 1999:81-8. exclusion reason - Systematic Review, not directly used. [pmid: 10326360].
989 Moss C, Taylor AEM, Shuster S. Comparison of cadexomer iodine and dextranomer for chronic venous ulcers. Clinical and Experimental Dermatology. Blackwell Publishing Ltd. 1987:413-418. [pmid: 2462473]. exclusion reason - wrong population.
990 Motta G, Milne C, Saucier D. A prospective evaluation of the bodyzone variable pressure foaming mattress with surface modification technology in hospitalized general medical-surgical patients. exclusion reason - Scientific Information Packets, not directly used.
991 Motta G, Milne C, Saucier D. Prevention and treatment of pressure ulcers with a new viscoelastic foam mattress with surface modification technology in general medical-surgical patients. exclusion reason - Scientific Information Packets, not directly used.
992 Motta GJ. The effectiveness of dermagran topical therapy for treating chronic wounds in nursing facility residents. Ostomy Wound Management. 1991:35-8. exclusion reason - not relevant. [pmid: 1930582].
993 Motta GJ, Martin K, Miller P, Marshall M, Zink J. Cost-effective technology for pressure relief. Ostomy Wound Management. 1991:29-37. exclusion reason - no original data. [pmid: 1764157].
994 Motta GJ, Milne CT, Corbett LQ. Impact of antimicrobial gauze on bacterial colonies in wounds that require packing. Ostomy Wound Management. 2004:48-62. exclusion reason - not relevant. [pmid: 15356368].
995 Motta GJ, Thimsen-Whitaker K, Demoor MA. Documenting outcomes of wound care. Continuing Care. 1995:16-7. exclusion reason - background. [pmid: 10163375].
996 Moues C, Margreet CV, et al. Bacterial load in relation to vacuum-assisted closure wound therapy: A prospective randomized trial. Wound Repair & Regeneration. 2004:11-17. exclusion reason - wrong outcome. [pmid: 14974959].
997 Mouthuy B, Calteux N, Bienfait B, Schoofs M, Rossillon D, Verheecke G, de Coninck A. value of the gluteus maximus musculocutaneous flap in the treatment of sacral and ischiatic ulcers. Apropos of 40 cases. Annales de Chirurgie Plastique et Esthetique. 1986:143-8. exclusion reason - not relevant. [pmid: 2429601].
998 Mowlavi A, Brown RE. Suction lipectomy during flap reconstruction provides immediate and safe debulking of the skin island. Annals of Plastic Surgery. 2003:189-93. exclusion reason - background. [pmid: 12897524].
999 Muehlberger T, Buschmann A, Toman N. Extended free deep inferior epigastric flap for closure of a thoracolumbar defect. Journal of Reconstructive Microsurgery. 2007:521-2. exclusion reason - not relevant. [pmid: 18189211].
1000 Muguti GI. Early experience with reconstructive surgery at mpilo central hospital, zimbabwe. Journal of the Royal College of Surgeons of Edinburgh. 1990:248-51. exclusion reason - not relevant. [pmid: 2231500].
1001 Mulder GD. A prospective controlled randomized study of the efficacy of clearsite, duoderm, and wet-to-dry gauze dressing in the management of pressure ulcers. 2nd European Conference on Advances in Wound Management. 1992. exclusion reason - no original data.
1002 Mulder GD, Albert SF, Grimwood RE. Clinical evaluation of a new occlusive hydrocolloid dressing. Cutis. 1985:396-7. 400. exclusion reason - not relevant. [pmid: 3996043].
1003 Mulgrew S, Khoo A, Newton RM, Rajan R, Kumar K. Pressure necrosis secondary to negative pressure dressing. Annals of the Royal College of Surgeons of England. 2011:e27-8. exclusion reason - not relevant. [pmid: 21943441].
1004 Mullner T, Mrkonjic L, Kwasny O, Vecsei V. The use of negative pressure to promote the healing of tissue defects: A clinical trial using the vacuum sealing technique. British Journal of Plastic Surgery. 1997:194-9. exclusion reason - not relevant. [pmid: 9176007].
1005 Mumcuoglu KY, Ingber A, Gilead L, Stessman J, Friedmann R, Schulman H, Bichucher H, Ioffe-Uspensky I, Miller J, Galun R, Raz I. Maggot therapy for the treatment of intractable wounds. International Journal of Dermatology. 1999:623-7. exclusion reason - not relevant. [pmid: 10487456].
1006 Mun G-H, Jo Y-W, Lim S-Y, Hyon W-S, Bang S-I, Oh K-S. Pedicled perforator flap of stellate design. Journal of Plastic, Reconstructive & Aesthetic Surgery: JPRAS. 2008:1332-7. exclusion reason - not relevant. [pmid: 18029241].
1007 Munter KC, Beele H. The contop study: Improved healing of delayed healing ulcers with sustained silver-releasing foam dressing versus other silver dressings. 39th annual wound, ostomy and continence nurses annual conference. Journal of Wound, Ostomy & Continence Nursing. 2007:S68-S68. exclusion reason - no original data.
1008 Munter KC, Beele H, Russell L, Crespi A, GrÃchenig E, Basse P, Alikadic N, Fraulin F, Dahl C, Jemma AP. Effect of a sustained silver-releasing dressing on ulcers with delayed healing: The contop study. Journal of Wound Care. 2006:199-206. exclusion reason - wrong intervention. [pmid: 16711173].
1009 Muro T, Onishi K, Inomata N, Yamada T, Saze M, Maruyama Y. The vacuum-assisted closure of pressure ulcers - clinical evaluation in combination with bfgf preparation. Japanese Pharmacology and Therapeutics. 2008:325-331. exclusion reason - not relevant.
1010 Musalatov KA, Silin LL, Elizarov MN, Elizarov PM, Garkavi AV. reconstructive operations on soft tissues in the treatment of bedsores in patients with spinal injuries. Vestnik Rossiiskoi Akademii Meditsinskikh Nauk. 1995:30-2. exclusion reason - not relevant. [pmid: 8601087].
1011 Musgrove E, Woodham C, Dearie P. Leg ulceration and clinical effectiveness: Nurse-led clinics. Nursing Standard. 1998:57. exclusion reason - background. [pmid: 9616627].
1012 Mustoe T, Upton J, Marcellino V. Carcinoma in chronic pressure sores: A fulminant disease process. Plastic and Reconstructive Surgery. 1986:116-121. exclusion reason - no original data. [pmid: 3941833].
1013 Naber TH, Schermer T, de Bree A, Nusteling K, Eggink L, Kruimel JW, Bakkeren J, van Heereveld H, Katan MB. Prevalence of malnutrition in nonsurgical hospitalized patients and its association with disease complications. American Journal of Clinical Nutrition. 1997:1232-1239. exclusion reason - wrong population. [pmid: 9356543].
1014 Nae S, Antohi N, Stingu C, Stan V, Parasca S. options for flap coverage in pressure sores. Chirurgia (Bucuresti). 2010:663-8. exclusion reason - not relevant. [pmid: 21141091].
1015 Nagano M, Kuroda T, Tomoe E, Megumi T, Ogata Y, Sakurai C, Keiko T, Tomoko S, Takehiko O. Pressure-reducing mattress to help take care of patients with pressure ulcers in large hospitals in japan. Journal of Wound, Ostomy & Continence Nursing. 2006:S45-6. exclusion reason - wrong outcome.
1016 Nagase T, Hisatomi T, Koshima I, Hattori N, Koyanagi H, Sanada H. Heterotopic ossification in the sacral pressure ulcer treated with basic fibroblast growth factor: Coincidence or side effect?. Journal of Plastic, Reconstructive & Aesthetic Surgery: JPRAS. 2007:327-9. exclusion reason - no original data. [pmid: 17293296].
1017 Nakagawa K, Ishii M, Kobayashi H, Tsuruta D, Iwamoto Y, Yashiro N, Ishidoh I, Hamada T, Terashima T, Shindo K, Suzuki S, Mizuno N, Katoh J, Shoji A, Kuniyuki S, Nishimura T, Abe Y, Kanetomo H, Kitajima J. Evaluation of the effects of tretinoin tocoferil ointment (olcenon(registered trademark) ointment) in the treatment of decubitus and skin ulcers. Skin Research. 1994:209-219. exclusion reason - not relevant.
1018 Nakayama M. Applying negative pressure therapy to deep pressure ulcers covered by soft necrotic tissue. International Wound Journal. 2010:160-6. exclusion reason - wrong outcome. [pmid: 20455957].
1019 Namiki Y, Torii S, Hayashi Y, Hasegawa M, Fukuta K. Gluteus maximus musculocutaneous v-y advancement flaps for the repair of pressure sores. Japanese Journal of Plastic and Reconstructive Surgery. 1989:21-29. exclusion reason - not relevant.
1020 Napier S, Cook M. A case report of rhabdomyolysis and pressure sores following hypotensive anaesthesia and prolonged surgery in the prone position. Anaesthesia. 2011:9. exclusion reason - wrong intervention.
1021 National Pressure Ulcer Advisory Panel. Pressure ulcer healing: Controversy to consensus assessment methods and outcomes. Advances in Wound Care. 1995:28/1-28/1. exclusion reason - wrong outcome.
1022 Naylor W. Malignant wounds: Aetiology and principles of management. Nursing Standard. 2002:45-56. exclusion reason - no original data. [pmid: 12271616].
1023 Nazarko L. Negative pressure wound therapy for older residents. Nursing & Residential Care. 2009:69. exclusion reason - background.
1024 Neander KD. current aspects of the therapy of chronic wounds. Zentralblatt fur Chirurgie. 2000:94-9. exclusion reason - background. [pmid: 10929657].
1025 Neander KD. dermatologic agents for preventing decubitus ulcer: Effectiveness could not be verified by the study. Pflege Zeitschrift. 2001:261-3. exclusion reason - not relevant. [pmid: 12025069].
1026 Nelson DB, Dilloway MA. Principles, products, and practical aspects of wound care. Critical Care Nursing Quarterly. 2002:33-54. exclusion reason - background.
1027 Nelson EA. Pressure sore treatment. 3. Clinical guidelines. Journal of Wound Care. 1997:402-4. exclusion reason - background. [pmid: 9341435].
1028 Nelson SE. Pearls for practice. Treating stage iii pressure ulcers... Including commentary by ferris mfg. Corp. Ostomy Wound Management. 2009:6-6. exclusion reason - background.
1029 Nemoto O, Ohkawara A. Clinical and bacteriological research of sucrose/povidone-iodine ointment (u-pasta kowa) for pressure sores and skin ulcers. Skin Research. 1996:538-548. exclusion reason - not relevant.
1030 Neubert TR, Fischer M, Toellner-Bauer U. from national standard to internal decubitus ulcerguideline--1: Algorithms promote transparency. Pflege Zeitschrift. 2005:376-9. exclusion reason - background. [pmid: 16013291].
1031 Neubert TR, Fischer M, Toellner-Bauer U. from national prevention standard to internal “decubitus ulcer” guideline--2: Standardizing wounds and still treating them individually. Pflege Zeitschrift. 2005:445-8. exclusion reason - background. [pmid: 16106833].
1032 Neumann V, Stoppard E, Kent R, Andrews K, Duport S, Larking AM, Clinton M, Hardy M. Letter to the editor: Re: Randomized control of extracorporeal shock wave therapy versus placebo for chronic decubitus ulceration... Randomized control of extracorporeal shock wave therapy versus placebo for chronic decubitus ulceration. Clinical Rehabilitation. 2010:1148-1149. exclusion reason - no original data. [pmid: 21115686].
1033 Neves RI, Kahler SH, Banducci DR, Manders EK. Tissue expansion of sensate skin for pressure sores. Annals of Plastic Surgery. 1992:433-7. exclusion reason - background. [pmid: 1444132].
1034 Newton H. A comprehensive guide to wound management.. Clinical resources efficiency support team (1998) clinical guidelines for wound management in northern ireland. Belfast: Crest wound management group. Nursing Times. 2000:17-17. exclusion reason - background.
1035 Newton M. Integrated care pathway: The prevention and management of pressure ulcers. Journal of Tissue Viability. 2003:126-9. exclusion reason - background. [pmid: 12889400].
1036 Niazi ZB, Salzberg CA. Operative repair of pressure ulcers. Clinics in Geriatric Medicine. 1997:587-97. exclusion reason - background. [pmid: 9227947].
1037 Niazi ZB, Salzberg CA. Surgical management of pressure ulcers. Ostomy Wound Management. 1997:44-8. 50. 2. exclusion reason - background. [pmid: 9385178].
1038 Nie X, Cai JK, Yang HM, Xiao HA, Wang JH, Wen N, Zhang YJ, Jin Y. Successful application of tissue-engineered skin to refractory ulcers. Clinical & Experimental Dermatology. 2007:699-701. exclusion reason - not relevant. [pmid: 17725663].
1039 Niezgoda JA. A comparison of vacuum assisted closure therapy to moist wound care in the treatment of pressure ulcers: Preliminary results of a multicenter trial. 2nd World Union of Wound Healing Societies Meeting. 2004. exclusion reason - no original data.
1040 Niezgoda JA. Incorporating negative pressure therapy into the management strategy for pressure ulcers. Ostomy Wound Management. 2004:5S-8S. exclusion reason - wrong population. [pmid: 15632459].
1041 Niitsu F. nursing technics in home care. 4. Symptoms common among aged patients and their nursing (1). Care of decubitus ulcer. Kango Gijutsu - Japanese Journal of Nursing Art. 1986:650-3. exclusion reason - not relevant. [pmid: 3636517].
1042 Nissen C, Gibson W, Snoder T, Martin K, Wassenaar D. Focus on research. Partners: A strategy for improving wound and skin care clinical outcomes in long term care. Chart. 1998:5-5. exclusion reason - background.
1043 Nixon J, Cranny G, Nelson A, Iglesias C, Phillips A, Hawkins K, Torgerson D, Mason S, Cullum N. The nhs health technology assessment programme. Pressure trial clinical and patient outcomes. EWMA Journal. 2006:38-38. exclusion reason - not relevant.
1044 Noda Y, Watanabe K, Sanagawa A, Sobajima Y, Fujii S. Physicochemical properties of macrogol ointment and emulsion ointment blend developed for regulation of water absorption. International Journal of Pharmaceutics. 2011:131-6. exclusion reason - wrong outcome. [pmid: 21820500].
1045 Nohara Y, Mizuno M, Kamei H, Yamadaz M, Fujii K, Satoh N, Nitao N, Renda A, Yuasa T, Hamazaki M, Shimauchi A, Hirai Y, Yasui H, Muramatsu S, Noda Y, Furuta K. preparation of a manual treatment of pressure ulcers which draws attention to moisture of the affected part. Gan to Kagaku Ryoho. Japanese Journal of Cancer & Chemotherapy. 2003:95-7. exclusion reason - not relevant. [pmid: 15311773].
1046 Nojima K. The surgical treatment of sacral pressure ulcers analyses of 92 cases. Tokyo Jikeikai Medical Journal. 2004:441-453. exclusion reason - not relevant.
1047 Nord D. cost-effectiveness in wound care. Zentralblatt fur Chirurgie. 2006:S185-8. exclusion reason - not relevant. [pmid: 16575679].
1048 Norton L, Rappl L, Sibbald G. Thinking outside the bed: Managing interface pressure... Including commentary by rappl l. International Journal of Therapy & Rehabilitation. 2005:165. exclusion reason - background.
1049 NPUAP, N. P. U. A. Panel. Pressure ulcer prevention and treatment: Clinical practice guidline. Ver. 01/29/2007 ed. National Pressure Ulcer Advisory Panel. 2007. exclusion reason - background.
1050 NPUAP. Terms and definitions related to support surfaces. National pressure Ulcer Advisory Panel Support Surface Standards Initiative. ver. 01/29/2001 ed. National Pressure Ulcer Advisory Panel. 2007. exclusion reason - background.
1051 NPUAP. Pressure ulcer prevention and treatment: Clinical practice guidline. National Pressure Ulcer Advisory Panel and European Pressure Ulcer Advisory Panel. 2009. exclusion reason - background.
1052 Oberlin C, Azoulay B, Bhatia A. The posterolateral malleolar flap of the ankle: A distally based sural neurocutaneous flap--report of 14 cases. Plastic & Reconstructive Surgery. 1995:400-5. discussion 406–7. exclusion reason - not relevant. [pmid: 7624414].
1053 Oberringer M, Baum HP, Jung V, Welter C, Frank J, Kuhlmann M, Mutschler W, Hanselmann RG. Differential expression of heat shock protein 70 in well healing and chronic human wound tissue. Biochemical & Biophysical Research Communications. 1995:1009-14. exclusion reason - background. [pmid: 7575503].
1054 O’Brien SP, Gahtan V, Wind S, Kerstein MD. What is the paradigm: Hospital or home health care for pressure ulcers?. American Surgeon. 1999:303-6. exclusion reason - wrong intervention. [pmid: 10190350].
1055 Obuchi R, Matsumoto S, Tobari Y, Tsukada S, Yoshimi T. an iatrogenic incident concerning decubitus ulcer. Decubitus ulcer encountered at clinical scenes: A discussion. Kangogaku Zasshi - Japanese Journal of Nursing. 1986:899-906. exclusion reason - not relevant. [pmid: 3639174].
1056 Oechies J. The treatment of poorly healing wounds with ultraviolet b-c. Physiotherapy Theory and Practice. 1991:259. exclusion reason - no original data.
1057 Ohry A, GO. The effects of bst electro-stimulation on healing of pressure ulcers: Results of a multi-center, double blind, randomized, placebo controlled study. [oral presentation no: 66]. 17th Conference of the European Wound Management Association. 2007. exclusion reason - not relevant.
1058 Ohura T, Nakajo T, Moriguchi T, Oka H, Tachi M, Ohura N Jr, Nogami R, Murayama S. Clinical efficacy of basic fibroblast growth factor on pressure ulcers: Case-control pairing study using a new evaluation method. Wound Repair and Regeneration. 2011:542-551. exclusion reason - wrong outcome. [pmid: 22092792].
1059 Ohura T, Sanada H, Mino Y. clinical study using activity-based costing to assess cost-effectiveness of a wound management system utilizing modern dressings in comparison with traditional wound care. Nippon Ronen Igakkai Zasshi - Japanese Journal of Geriatrics. 2004:82-91. exclusion reason - not relevant. [pmid: 14999922].
1060 Ohura T, Sanada H, Mino Y. Clinical activity-based cost effectiveness of traditional versus modern wound management in patients with pressure ulcers. Wounds: A Compendium of Clinical Research & Practice. 2004:157. exclusion reason - not relevant.
1061 Oien RF. Registering ulcer treatment through a national quality register: Rut -- a winning concept for both patients and the health care sector. EWMA Journal. 2009:41-44. exclusion reason - background.
1062 Okabe K, Satoh K, Takushima A, Eguchi T, Takushima M, Niu A, Minegisi M, Asatani M. Indications and selection of the surgical repair method for recurrent and intractable pressure sores. Japanese Journal of Plastic and Reconstructive Surgery. 1998:933-946. exclusion reason - not relevant.
1063 Oliva TorrasE, Subirana Casacuberta M, Sebastia MP, Jover Sancho C, Sola Sole N. care plan for patients in prone decubitus. An experience from practice. Enfermeria Intensiva. 1995:149-58. exclusion reason - not relevant. [pmid: 8715358].
1064 Oliveri L, Lavagnino G, Gliori A, Rossi GL. Treatment of ulcers: Application of a new product. Rivista Italiana di Chirurgia Plastica. 1991:498-503. exclusion reason - not relevant.
1065 Olsen L, Kallehave FL, Gottrup F. methods for measurement of wound extent. Ugeskrift for Laeger. 1994:7345-8. exclusion reason - not relevant. [pmid: 7801394].
1066 Olshanksy K. Multivariate predictors of failure after flap coverage of pressure ulcers. Plastic & Reconstructive Surgery. 2011:486-7. author reply 487. exclusion reason - no original data. [pmid: 21200260].
1067 Olshansky K Rethinking our approach to pressure ulcers Ostomy Wound Management 20016exclusion reason - no original data. 11889723
1068 Olshansky K. Long-term outcomes of full-thickness pressure ulcers: Healing and mortality. Ostomy Wound Management. 2004:12. 77. author reply 77. exclusion reason - background. [pmid: 15366146].
1069 Olshansky K. The 10 most important questions concerning pressure ulcers and quality of care. Advances in Skin & Wound Care. 2008:505-8. exclusion reason - background. [pmid: 18981749].
1070 Olshansky K. Kennedy terminal ulcer and “skin failure,” where are the data?. Journal of Wound, Ostomy, & Continence Nursing. 2010:466. author reply 466–7. exclusion reason - background. [pmid: 20838313].
1071 Olson A. The hard truth. PN. 2011:14-16. exclusion reason - background.
1072 Olyaee ManeshA, Flemming K, Cullum NA, Ravaghi H. Electromagnetic therapy for treating pressure ulcers. Cochrane Database of Systematic Reviews. 2006:CD002930. exclusion reason - Systematic Review, not directly used. [pmid: 16625564].
1073 O’Meara S, Cullum N, Majid M, Sheldon T. Systematic reviews of wound care management: (3) antimicrobial agents for chronic wounds; (4) diabetic foot ulceration (structured abstract). Health Technology Assessment Database. 2012. exclusion reason - not relevant.
1074 O’Meara SM, Cullum N, Majid M, Sheldon T. Systematic reviews of wound care management: (3) anitmicrobial agents for chronic wounds; (4) diabetic foot ulceration. Health Technology Assessment. 2000:1-237. exclusion reason - background.
1075 O’Meara SM, Cullum NA, Majid M, Sheldon TA. Systematic review of antimicrobial agents used for chronic wounds. British Journal of Surgery. 2001:4-21. exclusion reason - Systematic Review, not directly used. [pmid: 11136304].
1076 Omote S, Sugama J, Sanada H, Konya C, Okuwa M, Kitagawa A. Healing process of pressure ulcers after a change in the nutrition regimen of bedridden elderly: A case series. Japan Journal of Nursing Science. 2005:85-93. exclusion reason - not relevant.
1077 O’Neil CK. Prevention and treatment of pressure ulcers. Journal of Pharmacy Practice. 2004:137-148. exclusion reason - background.
1078 Onigbinde AT, Adedoyin RA, Ojoawo OA, Johnson OE, Obembe AO, Olafimihan FK, Omiyale OM, Oniyangi S. Effects of ultraviolet radiation (type b) on wound exudates, appearance and depth description. Technology & Health Care. 2010:297-302. exclusion reason - wrong outcome. [pmid: 21209478].
1079 Onizuka T, Jinnouchi T, Haraguchi W, Tanaka R, Udagawa K, Gyotoku H. treatment of decubitus ulcer. Nippon Seikeigeka Gakkai Zasshi - Journal of the Japanese Orthopaedic Association. 1986:1037-46. exclusion reason - not relevant. [pmid: 3537167].
1080 Oot-Giromini B, Bidwell FC, Heller NB, Parks ML, Prebish EM, Wicks P, Williams PM. Pressure ulcer prevention versus treatment, comparative product cost study. Decubitus. 1989:52-4. exclusion reason - wrong intervention. [pmid: 2505808].
1081 Ooura T. Treatment of deep pressure ulcers (stage iii iv). Japanese Journal of Plastic and Reconstructive Surgery. 1999:1067-1078. exclusion reason - not relevant.
1082 Orgill DP, Pribaz JJ, Morris DJ. Local fasciocutaneous flaps for olecranon coverage. Annals of Plastic Surgery. 1994:27-31. exclusion reason - not relevant. [pmid: 8141533].
1083 Orkiszewski M. maggots of lucilia sericata in treatment of intractable wounds. Wiadomosci Lekarskie. 2007:381-5. exclusion reason - not relevant. [pmid: 18175560].
1084 Orlando PL. Pressure ulcer management in the geriatric patient. Annals of Pharmacotherapy. 1998:1221-7. exclusion reason - Systematic Review, not directly used. [pmid: 9825090].
1085 Ormiston MC, Seymour MT, Venn GE, Cohen RI, Fox JA. Controlled trial of iodosorb in chronic venous ulcers. BMJ. 1985:308-310. exclusion reason - wrong outcome. [pmid: 3926169].
1086 Orsted HL, Poulson R, Baum J, Christensen D, Despatis M, Goettl K, Haligowski D, Ho C, Louis K, O’Sullivan-Drombolis D, Winberg V, Woo KY. Evidence-based practice standards for the use of topical pressurised oxygen therapy. International Wound Journal. 2012:271-284. exclusion reason - no original data. [pmid: 22494402].
1087 Osterbrink J, Mayer H, Schroder G. Clinical evaluation of the effectiveness of a multimodal statis pressure relieving device. Journal of Wound Healing European Wound Conference. 2005. exclusion reason - unable to find.
1088 Othman T, Friese G, Gierth T, Ziegler G, Scherbaum W. the treatment of heel pressure ulcer with the vacuum therapy (v.A.C. System). Zentralblatt fur Chirurgie. 2004:S116-8. exclusion reason - not relevant. [pmid: 15168306].
1089 Ourabah Z, Meaume S. Infected bed sores: New recommendations. Medecine et Maladies Infectieuses. 2003:78-80. exclusion reason - background.
1090 Ovington LG. Dressings and ajunctive therapies: Ahcpr guidelines revisited. Ostomy Wound Management. 1999:94S-106S. quiz 107S–108S. exclusion reason - background. [pmid: 10085980].
1091 Ovington LG. Evolution in the rainforest: The case for hydropolymer dressings. Advances in Skin & Wound Care. 2000:4-8. exclusion reason - background.
1092 Ovington LG. Wound care products: How to choose. Advances in Skin & Wound Care. 2001:259-64. quiz 265–6. exclusion reason - background. [pmid: 11905974].
1093 Oyama A, Murazumi M, Tsutsumida A, Fujii S, Hata S, Sugihara T. The gluteal perforator-based island fasciocutaneous flap for sacral pressure sores. Japanese Journal of Plastic and Reconstructive Surgery. 1997:963-968. exclusion reason - not relevant.
1094 Ozdemir F, Rodoplu M, Oymak F, Sut N. The effect of linear polarized polychromatic light therapies applied according to biochemical values on pressure ulcers. Turkiye Fiziksel Tip ve Rehabilitasyon Dergisi. 2007:100-103. exclusion reason - not relevant.
1095 Pacifici A, Cordellini M, Duranti F, Murgolo V, Bovani B, Coccaro A, Dominici C. Clinical use of the katomed dressing. Rivista Italiana di Chirurgia Plastica. 1992:421-425. exclusion reason - not relevant.
1096 Page J, Newswander B, et al. Retrospective analysis of negative pressure wound therapy in open foot wounds with significant soft tissue defects. Advances in Skin & Wound Care. 2004:354-364. exclusion reason - wrong population. [pmid: 15343085].
1097 Paghetti A, Bellingeri A, Pomponio G, Sansoni J, Paladino D. topic efficacy of ialuronic acid associated with argentic sulphadiazine (connettivina plus) in the treatment of pressure sores: A prospective observational cohort study. Professioni Infermieristiche. 2009:67-77. exclusion reason - not relevant. [pmid: 19664355].
1098 Pagnamenta F. Is fluid filled mattress technology compatible with nice guidance?. British Journal of Community Nursing. 2007:S35-8. exclusion reason - background. [pmid: 18361173].
1099 Pai CH, Toussaints S. Surgical treatment of pressure sores in patients with traumatic spinal cord injury: With relative emphasis on multiple and recurrent sores. Formosan Journal of Surgery. 1999:11-17. exclusion reason - not relevant.
1100 Paillaud E, Herbaud S, Caillet P, Lejonc JL, Campillo B, Bories PN. Relations between undernutrition and nosocomial infections in elderly patients. Age & Ageing. 2005:619-625. exclusion reason - wrong population. [pmid: 16267189].
1101 Paletta C, Bartell T, Shehadi S. Applications of the posterior thigh flap. Annals of Plastic Surgery. 1993:41-7. exclusion reason - not relevant. [pmid: 8101434].
1102 Palmieri B. Heterologous collagen in wound healing: A clinical study. International Journal of Tissue Reactions. 1992:21-5. exclusion reason - no original data. [pmid: 1639582].
1103 Panfil E-M. “;nursing patients with chronic wounds” expert standard: Qualification of needs. Pflege Zeitschrift. 2008:134-7. exclusion reason - not relevant. [pmid: 18450257].
1104 Paris A, Horvath R, Basset P, Thiery S, Couturier P, Franco A, Bosson JL. Nitrous oxide-oxygen mixture during care of bedsores and painful ulcers in the elderly: A randomized, crossover, open-label pilot study. Journal of Pain and Symptom Management. 2008:171-176. exclusion reason - wrong intervention. [pmid: 18226725].
1105 Parish LC, Dryjski M, Cadden S, Versiva XCPUSG. Prospective clinical study of a new adhesive gelling foam dressing in pressure ulcers. International Wound Journal. 2008:60-7. exclusion reason - wrong outcome. [pmid: 18336380].
1106 Parish LC, Lowthian PT, Witkowski JA. The infected decubitus ulcer: Superman’s kryptonite. SKINmed. 2005:7-8. exclusion reason - background. [pmid: 15654157].
1107 Parish LC, Witkowski JA, Crissey JT. Unusual aspects of the decubitus ulcer. Decubitus. 1988:22-4. exclusion reason - background. [pmid: 3254235].
1108 Park C, Park BY. Fasciocutaneous v-y advancement flap for repair of sacral defects. Annals of Plastic Surgery. 1988:23-6. exclusion reason - not relevant. [pmid: 3048182].
1109 Park S. Muscle-splitting approach to superior and inferior gluteal vessels: Versatile source of recipient vessels for free-tissue transfer to sacral, gluteal, and ischial regions. Plastic & Reconstructive Surgery. 2000:81-6. exclusion reason - not relevant. [pmid: 10883616].
1110 Park S, Koh KS. Superior gluteal vessel as recipient for free flap reconstruction of lumbosacral defect. Plastic & Reconstructive Surgery. 1998:1842-9. exclusion reason - not relevant. [pmid: 9623825].
1111 Parkash S, Banerjee S. The total gluteus maximus rotation and other gluteus maximus musculocutaneous flaps in the treatment of pressure ulcers. British Journal of Plastic Surgery. 1986:66-71. exclusion reason - not relevant. [pmid: 3947796].
1112 Parpex P. Local treatment of ulceration on white atrophy. Phlebologie. 1986:603-604. exclusion reason - not relevant. [pmid: 3786433].
1113 Partridge CJ. Evaluation of the efficacy of ultrasound. Physiotherapy. 1987:166-168. exclusion reason - no original data.
1114 Pasquini G, Caglioni C, Pandolfi P. Surgical repair of decubitus ulcers. Rivista Italiana di Chirurgia Plastica. 1988:178-185. exclusion reason - not relevant.
1115 Pasternak NS, Rau LAL, Hensley BJ. From chaos to consistency: The implementation of wound treatment tiers in home care. Home Health Care Management & Practice. 2003:314-324. exclusion reason - background.
1116 Patrick MM. Specialty beds and wound care products: A new cost-saving role. Hospital Materiel Management Quarterly. 1994:48-62. exclusion reason - background. [pmid: 10137782].
1117 Patterson JA, Bennett RG. Prevention and treatment of pressure sores. Journal of the American Geriatrics Society. 1995:919-27. exclusion reason - no original data. [pmid: 7636103].
1118 Paulson R, Guthmiller P, Rustvang D. The latest in cutaneous ulcer care. Patient Care. 2005:13-16. exclusion reason - background.
1119 Payne W, Ochs D, Wolcott R, Morrow L, Jameson G, Alvarez O, Kalinski C, Brown-Etris M, Hartwell S, Dharma H. A prospective, multi-center, randomized and comparative evaluation to assess the relative cost effectiveness of treatment of stage ii pressure ulcers with a self-adhesive polyurethane foam dressing* and saline soaked gauze. 50-5. exclusion reason - no original data. [pmid: 19246785].
1120 Payne WG, Bhalla R, Hill DP, Pierpont YN, Robson MC. Wound healing trajectories to determine pressure ulcer treatment efficacy. Eplasty [Electronic Resource]. 2011:e1. exclusion reason - background. [pmid: 21245984].
1121 Pearl M. Ahcpr recommendations for assessment and treatment of pressure ulcers. Acute Care Perspectives. 1996:6-7. exclusion reason - background.
1122 Pedrolli C, Cereda E. Dramatic pressure ulcers. e-SPEN. 2010:e45-e46. exclusion reason - background.
1123 Peirce B, Gray M. Radiant heat dressings for chronic wounds. Journal of Wound, Ostomy, & Continence Nursing. 2001:263-6. exclusion reason - background. [pmid: 11707756].
1124 Pelham FR, Minn W, Wise B, Morton T, Powell G, Egol K. Staged surgical closure in combination with negative pressure wound therapy using open cell foam (npwt/ocf) increases closure success of stage iii and iv pressure ulcers (prus). exclusion reason - no original data.
1125 Pemberton V, Turner V, VanGilder C. Early results of a pilot surface evaluation of a bariatric therapy support surface. 39th annual wound, ostomy and continence nurses annual conference. Journal of Wound, Ostomy & Continence Nursing. 2007:S75-S75. exclusion reason - not relevant.
1126 Pena MM, Drew GS, Smith SJ, Given KS. The inferiorly based rectus abdominis myocutaneous flap for reconstruction of recurrent pressure sores. Plastic & Reconstructive Surgery. 1992:90-5. exclusion reason - not relevant. [pmid: 1727268].
1127 Peng YH, Ye CT, Zou HY, Dai LB. A new kind of material for curing bedsore: Acidic fibroblast growth factor-collagen sponge. Chinese Journal of Clinical Rehabilitation. 2005:88-89. exclusion reason - not relevant.
1128 Perrero L, Persico D, Bellora A, Laguzzi E, Sacchi MC. Pressure ulcers in the elderly: Advanced treatments and use of platelet gel (prp/gel). Giornale di Gerontologia. 2003:12-17. exclusion reason - not relevant.
1129 Perrouin-Verbe B, Poirier P, Touchais S, Richard I, Mathe JF, Bainvel JV. Hip sepsis associated with pressure sore in paraplegic patients. Value of one-time surgical treatment. Annales de Readaptation et de Medecine Physique. 1994:297-304. exclusion reason - not relevant.
1130 Pers M. Plastic surgery for pressure sores. Paraplegia. 1987:275-8. exclusion reason - background. [pmid: 2439973].
1131 Pers M, Snorrason K, Nielsen IM. Primary results following surgical treatment of pressure sores. Scandinavian Journal of Plastic & Reconstructive Surgery. 1986:123-4. exclusion reason - not relevant. [pmid: 3490685].
1132 Peschardt A, Alsbjorn B, Gottrup F. A comparative randomized study on performance characteristics of a new hydrogel versus saline gauze for the treatment of pressure sores. Proceedings of the 6th European Conference on Advances in Wound Management. 1995. exclusion reason - no original data.
1133 Peters JW, Johnson GE. Proximal femurectomy for decubitus ulceration in the spinal cord injury patient. Paraplegia. 1990:55-61. exclusion reason - not relevant. [pmid: 2152395].
1134 Petrovici V. surgical treatment of decubitus ulcers. Handchirurgie, Mikrochirurgie, Plastische Chirurgie. 1986:242-8. exclusion reason - not relevant. [pmid: 3527890].
1135 Pettit KL, Wendt K. Across the care continuum: Taking a pro-active approach to pressure ulcer care. Remington Report. 2007:7-10. exclusion reason - background.
1136 Pfeffer F, von Dobschuetz E, Riediger H, Moosmann C, Hopt UT. the non-healing wound. MMW Fortschritte der Medizin. 2004:45-8. exclusion reason - not relevant. [pmid: 15566249].
1137 Pham C, Middleton P, Maddern G. Vacuum-assisted closure for the management of wounds: An accelerated systematic review (structured abstract). Health Technology Assessment Database. 2011. exclusion reason - Systematic Review, not directly used.
1138 Phan TQV, Spilker G, Theodorou P, Gossmann A, Heiss M, Weinand C. Combined latissimus dorsi and serratus anterior flaps for pelvic reconstruction. Microsurgery. 2011:529-34. exclusion reason - wrong intervention. [pmid: 21766332].
1139 Philbeck TE Jr, Whittington KT, Millsap MH, Briones RB, Wight DG, Schroeder WJ. The clinical and cost effectiveness of externally applied negative pressure wound therapy in the treatment of wounds in home healthcare medicare patients. Ostomy Wound Management. 1999:41-50. exclusion reason - background. [pmid: 10687657].
1140 Phillips D, Davey C. Wound cleaning versus wound disinfection: A challenging dilemma. Perspectives. 1997:15-6. exclusion reason - background. [pmid: 9460442].
1141 Phillips EM. Evidence-based practice: Pressure ulcer management guidelines for spinal cord injury. Topics in Spinal Cord Injury Rehabilitation. 2003:16-19. exclusion reason - background.
1142 Phillips L. Pressure ulcers--prevention and treatment guidelines. Nursing Standard. 1999:56-8. 60. 62. exclusion reason - background. [pmid: 11971342].
1143 Phillips L. Cost-effective strategy for managing pressure ulcers in critical care: A prospective, non-randomised, cohort study. Journal of Tissue Viability. 2000:2-6. exclusion reason - background. [pmid: 11299575].
1144 Phillips TjPW. Clinial trial of cultured autologous keratinocyte grafts in the treatment of long-standing pressure ulcers. Wounds: A Compendium of Clinical Research and Practice. 1994:113. exclusion reason - not relevant.
1145 Phipps M, Bauman B, Berner D, Butler M, Kalinoski A, Looby M, Malacaria N, Pratt L, Reiley P, Sullivan M. Staging care for pressure sores. American Journal of Nursing. 1984:999-1003. exclusion reason - background. [pmid: 6565467].
1146 Piatkowski A, Ulrich D, Seidel S, Abel M, Pallua N, Andriessen A. Randomized controlled pilot comparing collagen and foam dressings in pressure ulcer patients evaluating their influence on healing time, angiogenesis and proinflammatory cells. 15th Conference Nationale Des Plaies Et Cicatrisations Prevention Et Traitement. 2011. exclusion reason - no original data.
1147 Pieper B, Mikols C, Adams W, Mance B. Low and high air-loss beds in acute care hospitals. Journal of Enterostomal Therapy. 1990:131-6. exclusion reason - wrong outcome. [pmid: 2347992].
1148 Pierce GF, Tarpley JE, Allman RM, Goode PS, Serdar CM, Morris B, Mustoe TA, Berg JV. Tissue repair processes in healing chronic pressure ulcers treated with recombinant platelet-derived growth factor bb. American Journal of Pathology. 1994:1399-1410. exclusion reason - duplicate. [pmid: 7992843].
1149 Pieroni RE, Hanson ES. Use of galvanic stimulation in the treatment of decubitus ulcers in the elderly. exclusion reason - unable to find.
1150 Pilarski D. protocol of care and prevention of decubitus ulcers. Soins; La Revue de Reference Infirmiere. 1986:51-3. exclusion reason - not relevant. [pmid: 3645791].
1151 Pinchcofsky-Devin GD, Kaminski MV. Correlation of pressure sores and nutritional status. Journal of the American Geriatrics Society. 1986:435-440. exclusion reason - background. [pmid: 3084610].
1152 Pinter L, Vosmik J, Klein L, Talabova Z. use of myocutaneous flaps in the treatment of decubitus ulcer. Rozhledy V Chirurgii. 1988:723-8. exclusion reason - not relevant. [pmid: 3217839].
1153 Pistolesi C, Maffei E. Pressure sores treatment: An update and some operative proposals. Giornale Italiano di Farmacia Clinica. 1998:36-43. exclusion reason - background.
1154 Pohl M, Ruckriem S, Strik H, Hortinger B, Meissner D, Mehrholz J, Pause M. Treatment of pressure ulcers by serial casting in patients with severe spasticity of cerebral origin. Archives of Physical Medicine & Rehabilitation. 2002:35-9. exclusion reason - wrong population. [pmid: 11782830].
1155 Poirier P, Madezo P, Perrouin-Verbe B, Hepner-Lavergne D, Pannier M, Bainvel JV. Cover of trochanteric pressure sores by v-y tensor fascia latae musculocutaneous flap. Annales de Chirurgie Plastique et Esthetique. 1994:464-468. exclusion reason - not relevant. [pmid: 7755328].
1156 Popescu L, Petcu I. surgical treatment of decubitus eschars. Revista Medico-Chirurgicala a Societatii de Medici Si Naturalisti Din Iasi. 1987:685-8. exclusion reason - not relevant. [pmid: 3452861].
1157 Posma AN. The innervated tensor fasciae latae flap in patients with meningomyelocele. Annals of Plastic Surgery. 1988:594-6. exclusion reason - not relevant. [pmid: 3239938].
1158 Posnett J, Franks PJ. The burden of chronic wounds in the uk. Nursing Times. 2008:44-5. exclusion reason - no original data. [pmid: 18293879].
1159 Posthauer ME. Do patients with pressure ulcers benefit from oral zinc supplementation?. Advances in Skin & Wound Care. 2005:471-2. exclusion reason - no original data. [pmid: 16365542].
1160 Posthauer ME. When is enteral nutrition support an effective strategy?. Advances in Skin & Wound Care. 2006:257-60. exclusion reason - background. [pmid: 16732071].
1161 Posthauer ME. The role of nutrition in wound care. Adv Skin Wound Care. 2006:43-52. exclusion reason - no original data. [pmid: 16477165].
1162 Posthauer ME. The role of nutrition in wound care. Advances in skin & wound care. 2012:62-3. exclusion reason - background. [pmid: 22258214].
1163 Postigo S. care of skin ulcers in hospital and outside. Revista de Enfermeria. 1997:40. exclusion reason - background. [pmid: 9233262].
1164 Poteete V. Case study: Eliminating odors from wounds. Decubitus. 1993:43-6. exclusion reason - not relevant. [pmid: 8297491].
1165 Priesack W, Fuchs KH, Bauer E. primary immediate coverage of decubitus ulcers by musculocutaneous flaps and gentamicin pmma beads. Handchirurgie, Mikrochirurgie, Plastische Chirurgie. 1987:10-6. exclusion reason - not relevant. [pmid: 3557201].
1166 Protz K. the agony of choice in wound management. Pflege Zeitschrift. 2010:206-9. exclusion reason - not relevant. [pmid: 20426380].
1167 Pruss S. mis micro-stimulation system in general practice. Krankenpflege Journal. 2005:124-5. exclusion reason - not relevant. [pmid: 16171068].
1168 Qian X, Yuan H, Zhang M. Traditional chinese medicine to treat patients with pressure sore -- a meta analysis of randomized controlled trial. [chinese]. Chinese Nursing Research. 2004:568-570. exclusion reason - Systematic Review, not directly used.
1169 Quality AfHRa. Air-fluidized beds used for treatment of pressure ulcers in the home environment - systematic review (brief record). Health Technology Assessment Database. 2011. exclusion reason - Systematic Review, not directly used.
1170 Queen D. The emergence of a clinical specialty in wound care. International Wound Journal. 2010:3-4. exclusion reason - background. [pmid: 20409244].
1171 Quelard B, Cordier ME, Regent MC, Tenette M. Comparative study to determine the relative efficiency of two types of treatment of decubitus ulcers of sacro and ischial tuberosities: Topical ozone treatment versus the traditional methods. Annales Medicales de Nancy et de l’Est. 1985:329-334. exclusion reason - not relevant.
1172 Quillot M, Lodde JP, Pegorier O, Reynaud JP, Cormerais A. Variant of island flaps for cover of pressure sores: The hatchet flap. Report of a series of 31 cases. Annales de Chirurgie Plastique et Esthetique. 1994:469-472. exclusion reason - not relevant. [pmid: 7755329].
1173 Rabinovich OF, Epel’dimova EL. methods of diagnosis and local treatment of oral mucosa (lichen ruber planus, recurrent aphthous stomatitis, decubitus ulcers). Stomatologiia. 2005:58-63. exclusion reason - not relevant. [pmid: 16114139].
1174 Rabus MT, Dare F, Le Mouel LE, Meaume S. Sequential treatment using alginate-cmc and hydrocolloid dressing in pressure ulcers: Results of a controlled study (steps study). 2nd World Union of Wound Healing Societies Meeting. 2004. exclusion reason - no original data.
1175 Raffoul W. Advances in wound care. Schweizerische Rundschau fur Medizin - Praxis. 2008:257-260. exclusion reason - background.
1176 Rainfray M, Dehail P, Salles N. complications of immobility and bed rest. Prevention and management. Revue du Praticien. 2007:671-6. exclusion reason - background. [pmid: 17593793].
1177 Rajacic N, Gang RK, Dashti H, Behbehani A. Treatment of ischial pressure sores with an inferior gluteus maximus musculocutaneous island flap: An analysis of 31 flaps. British Journal of Plastic Surgery. 1994:431-4. exclusion reason - not relevant. [pmid: 7952811].
1178 Ramadan A. An optimum current intensity for healing. Journal of Wound Care. 2012:10-10. exclusion reason - wrong intervention.
1179 Ramirez OM, Swartz WM, Futrell JW. The gluteus maximus muscle: Experimental and clinical considerations relevant to reconstruction in ambulatory patients. British Journal of Plastic Surgery. 1987:1-10. exclusion reason - not relevant. [pmid: 3814892].
1180 Rasero L, Fabbri C, Cantasano L, Lotti T, Pucci T, Veratti M, Rossi M. prevention of pressure ulcers: Retrospective study regarding the effectiveness of an alternate pressure device. Professioni Infermieristiche. 2007:237-41. exclusion reason - not relevant. [pmid: 18289496].
1181 Rath E. treatment of decubitus ulcers/wound management: A dry wound is a dead wound. Pflege Zeitschrift. 1998:510-2. exclusion reason - not relevant. [pmid: 9752230].
1182 Ratliff C, Tomaselli N. Wocn update on evidence-based guidelines for pressure ulcers. Journal of Wound, Ostomy & Continence Nursing. 2011:S8-S8. exclusion reason - background. [pmid: 20838310].
1183 Ratliff CR, Rodeheaver GT. Use of the push tool to measure venous ulcer healing. Ostomy Wound Management. 2005:58-60. 62. 3. exclusion reason - background. [pmid: 16014985].
1184 Ratliff CR, Tomaselli N. Update on evidence-based guideline for pressure ulcers. Long-Term Living: For the Continuing Care Professional. 2010:14. exclusion reason - background.
1185 Ratliff CR, Tomaselli N. Wocn update on evidence-based guideline for pressure ulcers. Journal of Wound, Ostomy, & Continence Nursing. 2010:459-60. exclusion reason - background. [pmid: 20838310].
1186 Ratliff CR, Wocn. Wocn’s evidence-based pressure ulcer guideline. Advances in Skin & Wound Care. 2005:204-8. exclusion reason - background. [pmid: 15920372].
1187 Rawat SS, Mathur BS. Transverse lumbar flap for sacral bed sores. Plastic & Reconstructive Surgery. 1991:154-8. exclusion reason - not relevant. [pmid: 2052646].
1188 Reddy M. Pressure ulcers. Clinical Evidence. 2011. [pmid: 21524319]. exclusion reason - background.
1189 Reddy M, Gill SS, Kalkar SR, Wu W, Anderson PJ, Rochon PA. Treatment of pressure ulcers: A systematic review. JAMA. 2008:2647-62. exclusion reason - background. [pmid: 19066385].
1190 Redelings MD, Lee NE, Sorvillo F. Pressure ulcers: More lethal than we thought?. Advances in Skin & Wound Care. 2005:367-72. exclusion reason - background. [pmid: 16160463].
1191 Redelings MD, Wise M, Sorvillo F. Using multiple cause-of-death data to investigate associations and causality between conditions listed on the death certificate. [erratum appears in am j epidemiol. 2008 sep 15;168(6):666]. American Journal of Epidemiology. 2007:104-8. exclusion reason - background. [pmid: 17426040].
1192 Rees RS, Reilley AF, Nanney LB, Lynch JB. Sacral pressure sores: Treatment with island gluteus maximus musculocutaneous flaps. Southern Medical Journal. 1985:1147-51. exclusion reason - not relevant. [pmid: 3901280].
1193 Rees RS, Robson MC, Smiell JM, Perry BH. Becaplermin gel in the treatment of pressure ulcers: A randomized double-blind placebo-controlled study. Wound Repair and Regeneration. 1998:A478. exclusion reason - not relevant. [pmid: 10417749].
1194 Rees RS, Robson MC, Smiell JM, Perry BH. A randomized, double-blind, placebo-controlled study of becaplermin (recombinant human platelet-derived growth factor-bb) gel in the treatment of pressure ulcers. Wound Repair and Regeneration. 1998:A246. exclusion reason - no original data.
1195 Reeves I, Plourde M, Authier S, Doddridge C. combined effect of acticoat and vac on wound healing. Perspective infirmiere: Revue Officielle de l’Ordre des Infirmieres et Infirmiers du Quebec. 2005:10-5. exclusion reason - not relevant. [pmid: 15962530].
1196 Regan MA, Teasell RW, Wolfe DL, Keast D, Mortenson WB, Aubut JAL. A systematic review of therapeutic interventions for pressure ulcers after spinal cord injury. Archives of Physical Medicine and Rehabilitation. 2009:213-231. exclusion reason - Systematic Review, not directly used. [pmid: 19236976].
1197 Reger SI, Negami S, Reyes ET, Navarro R, Parikh N, McDevitt CA. [610] use of direct current stimulation in pressure sore healing. Journal of Rehabilitation Research and Development. 1991:478. exclusion reason - not relevant.
1198 Reichert B, Brenner P, Berger A. management of para-pelvic decubitus ulcers. Zentralblatt fur Chirurgie. 1996:83-4. exclusion reason - not relevant. [pmid: 8967256].
1199 Reis B. doubts about modern treatment methods but: Moist wound treatment is cheaper. Pflege Zeitschrift. 1999:365-6. exclusion reason - not relevant. [pmid: 10514739].
1200 Reis J, Amarante J, Costa-Ferreira A, Silva A, Malheiro E. Surgical treatment of pressure sores. European Journal of Plastic Surgery. 1999:318-321. exclusion reason - background.
1201 Relander M. conservative and surgical management of decubitus ulcer. Duodecim. 1996:1492-5. exclusion reason - not relevant. [pmid: 10596137].
1202 Relander M, Palmer B. Recurrence of surgically treated pressure sores. Scandinavian Journal of Plastic & Reconstructive Surgery & Hand Surgery. 1988:89-92. exclusion reason - not relevant. [pmid: 3387926].
1203 Remington L. Wound care... Not an isolated problem. Remington Report. 2006:5-5. exclusion reason - background.
1204 Remon JP. The magistral prescription on the basis of hypochlorite in the treatment of bedsores. Farmaceutisch Tijdschrift voor Belgie. 1995:27-28. exclusion reason - not relevant.
1205 Rendo M, Veneziani C, Zappulla S. prevention and treatment of decubitus ulcers: An experience. Professioni Infermieristiche. 1999:48-53. exclusion reason - not relevant. [pmid: 10455813].
1206 Rennert R, Golinko M, Yan A, Flattau A, Tomic-Canic M, Brem H. Developing and evaluating outcomes of an evidence-based protocol for the treatment of osteomyelitis in stage iv pressure ulcers: A literature and wound electronic medical record database review. Ostomy Wound Management. 2009:42-53. exclusion reason - not relevant. [pmid: 19359709].
1207 Resch CS, Kerner E, Robson MC, Heggers JP, Scherer M, Boertman JA, Schileru R. Pressure sore volume measurement. A technique to document and record wound healing. Journal of the American Geriatrics Society. 1988:444-6. exclusion reason - background. [pmid: 3361046].
1208 Ribinik P, Yvon C, Barrois B, Colin D, Megnigbeto A. decubitus ulcers and dressings. Nursing practices. Soins; La Revue de Reference Infirmiere. 1997:44-7. exclusion reason - not relevant. [pmid: 9239098].
1209 Ricci E. treatment of skin lesions with katogel. Minerva Chirurgica. 1996:369-75. exclusion reason - not relevant. [pmid: 9072749].
1210 Ricci E, Bosio D, Nano M. Topical treatment of chronic pressure ulcers with ustiosan. Giornale Italiano di Dermatologia e Venereologia. 2003:513-517. exclusion reason - not relevant.
1211 Rice TT. Metronidazole use in malodorous skin lesions. Rehabilitation Nursing. 1992:244-5. 255. exclusion reason - wrong population. [pmid: 1448604].
1212 Richards J, Lowery K, Atkinson B. Installing electrically operated beds. Nursing Times. 2003:71. exclusion reason - background. [pmid: 12715566].
1213 Riebelova V. The tensor fasciae latae musculocutaneous flap in operations for trochanteric decubitus ulcers. Acta Chirurgiae Plasticae. 1985:17-25. exclusion reason - not relevant. [pmid: 2581409].
1214 Rieger U, Scheufler O, Schmid D, Zweifel-Schlatter M, Kalbermatten D, Pierer G. six treatment principles of the basle pressure sore concept. Handchirurgie, Mikrochirurgie, Plastische Chirurgie. 2007:206-14. exclusion reason - not relevant. [pmid: 17602385].
1215 Rieger UM, Pierer G. Decubitus - six fundamental treatment principles. Haut. 2011:13-16. exclusion reason - background.
1216 Riggs R, Banks V, Bale S, Harding K. Comparison of an absorbent semi-permeable polyurethane dressing (spyrosorb/mitraflex) and a hydrocolloid dressing (granuflex e) for the treatment of moderately exuding pressure sores in hospitalised patients. 3rd European Conference on Advances in Wound Management. 1993. exclusion reason - no original data.
1217 Rigotti G, Bortolani A, Cristofoli C, Gibelli PL, Marchi A, Furlan S. Repair of loss of cutaneous tissue in the vertebral area. Rivista Italiana di Chirurgia Plastica. 1988:277-281. exclusion reason - not relevant.
1218 Riihelainen A. care of pressure sores. Sairaanhoitaja (Helsinki). 1991:42-4. exclusion reason - not relevant. [pmid: 1888910].
1219 Rimareix F, Lortat-Jacob A. Surgical treatment of paraplegic patent’s pressures sores. Retrospective study of 90 cases. Annales de Chirurgie Plastique et Esthetique. 2000:589-596. exclusion reason - not relevant. [pmid: 11147118].
1220 Rindflesch AB, Miller NE. The thoracic suspension orthosis - a seating option for patients with pressure ulcers. Journal of Spinal Cord Medicine. 2002:306-309. exclusion reason - not relevant. [pmid: 12482174].
1221 Rioufol MO. care and prevention actions. 1/6. Prevention of decubitus ulcers. Soins; La Revue de Reference Infirmiere. 2001:51-2. exclusion reason - not relevant. [pmid: 12008500].
1222 Rioufol MO. 5/6--prevention and treatment of effects of prolonged bedrest. Soins; La Revue de Reference Infirmiere. 2001:55-6. exclusion reason - not relevant. [pmid: 12012690].
1223 Roales-Welsch S, Antaszek M, Hense W, Pfeiffer M, Freyenhagen E, Engel P. study on quality assurance in the prevention and therapy of decubitus ulcer by measuring the overlay pressure with test subjects on different prophylaxis systems. Pflege. 2000:297-305. exclusion reason - not relevant. [pmid: 11194333].
1224 Roberts L, Mello B. Improving outcomes for pressure ulcer patients: Tying together financial and clinical quality for success. Remington Report. 2005:35-36. exclusion reason - background.
1225 Robinson BJ. The use of a hydrofibre dressing in wound management. Journal of Wound Care. 2000:32-4. exclusion reason - no original data. [pmid: 10827666].
1226 Robres MDB, Ros GL, Melero Garcia MA. Starch paste as a treatment for pressure ulcers. [spanish]. Enfermeria Clinica. 1994:195-198. exclusion reason - not relevant.
1227 Robson MC, Barbul A. Guidelines for the best care of chronic wounds. Wound Repair & Regeneration. 2006:647-648. exclusion reason - background. [pmid: 17199830].
1228 Robson MC, Maggi SP, Smith PD, Wassermann RJ, Mosiello GC, Hill DP, Cooper DM. Ease of wound closure as an endpoint of treatment efficacy. Wound Repair & Regeneration. 1999:90-96. exclusion reason - wrong outcome. [pmid: 10231510].
1229 Robson MC, Mannari RJ, Smith PD, Payne WG. Maintenance of wound bacterial balance. American Journal of Surgery. 1999:399-402. exclusion reason - wrong intervention. [pmid: 10612536].
1230 Rodier-Bruant C, Keller P, Herman D, Stricher R, Geiger D, Manunta A, Wilk A. the use of sorbsan in the treatment of the donor site of skin transplantations. Minerva Chirurgica. 1992:995-9. exclusion reason - not relevant. [pmid: 1436580].
1231 Rodriguez PalmaM, Malia Gazquez R, Barba Chacon A. immobilization and localization of pressure ulcers in aged patients under home care. Revista de Enfermeria. 2000:515-8. exclusion reason - background. [pmid: 10983158].
1232 Rodriguez Rocha C. chronic ulcers. A protocol of care and treatment. Revista de Enfermeria. 1993:65-9. exclusion reason - not relevant. [pmid: 8321990].
1233 Roeckl-Wiedmann I, Bennett M, Kranke P. Systematic review of hyperbaric oxygen in the management of chronic wounds. British Journal of Surgery. 2005:24-32. exclusion reason - wrong population. [pmid: 15635604].
1234 Roghmann MC, Siddiqui A, Plaisance K, Standiford H. Mrsa colonization and the risk of mrsa bacteraemia in hospitalized patients with chronic ulcers. Journal of Hospital Infection. 2001:98-103. exclusion reason - background. [pmid: 11170772].
1235 Rogissart F, Malka G, Guyenne C. Gluteal decubitus ulcers: Our therapeutic approach over the last 10 years, base on a series of 32 cases. Annales de Chirurgie Plastique et Esthetique. 1997:247-252. exclusion reason - not relevant. [pmid: 9768162].
1236 Roldan ValenzuelaA, Jaen Ferrer P, Ferrer Cano F, Torra i Bou JE. decubitus ulcers in the sacrum. Evaluation of a specific hydrocolloid hydro-regulatory dressing. Revista de Enfermeria. 1999:223-30. exclusion reason - not relevant. [pmid: 10437569].
1237 Romanelli M, Dimi V, Bertone MS, Mazzatenta C, Martini P. Efficacy and tolerability of “fitostimoline(registered trademark) antibiotico” soaked gauzes in the topical treatment of cutaneous sores, ulcers and burns, complicated with bacterial contamination. An open-label, controlled, randomised, multicentre, parallel group. Gazzetta Medica Italiana Archivio per le Scienze Mediche. 2008:251-260. exclusion reason - not relevant.
1238 Romanelli M, Dini V, Barbanera S, Bertone MS. Evaluation of the efficacy and tolerability of a solution containing propyl betaine and polihexanide for wound irrigation. Skin Pharmacology & Physiology. 2010:41-4. exclusion reason - wrong population. [pmid: 20829661].
1239 Romanelli M, Magliaro A, Mastronicola D, Siani S. Systemic antimicrobial therapies for pressure ulcers. Ostomy Wound Management. 2003:25-9. exclusion reason - no original data. [pmid: 12883162].
1240 Rooman RP. Ketanserin promotes wound healing: Clinical and preclinical results. Progress in Clinical & Biological Research. 1991:115-28. exclusion reason - wrong population. [pmid: 1862126].
1241 Roth RS, Lowery JC, Hamill JB. Assessing persistent pain and its relation to affective distress, depressive symptoms, and pain catastrophizing in patients with chronic wounds: A pilot study. American Journal of Physical Medicine & Rehabilitation. 2004:827-34. exclusion reason - wrong intervention. [pmid: 15502735].
1242 Rothenaicher G. possibilities of v.A.C. Therapy in outpatient surgical practices. Zentralblatt fur Chirurgie. 2006:S182-4. exclusion reason - not relevant. [pmid: 16575678].
1243 Rousseau P. Management of pressure sores. Postgraduate Medicine. 1988:51-2. exclusion reason - background. [pmid: 3357870].
1244 Routkovsky NC, Meaume S, Goldfarb JM, Le PC, Preauchat A. Randomized comparative study of two hydrocolloid dressings in the treatment of decubitus ulcers. Revue de Geriatrie. 1996:213-218. exclusion reason - wrong outcome.
1245 Routman A, Van Manen W, Haddad R. Cefsulodin treatment for serious pseudomonas aeruginosa infections. Journal of International Medical Research. 1986:242-253. exclusion reason - wrong intervention. [pmid: 3770290].
1246 Rubayi S, Ambe MK, Garland DE, Capen D. Heterotopic ossification as a complication of the staged total thigh muscles flap in spinal cord injury patients. Annals of Plastic Surgery. 1992:41-6. exclusion reason - not relevant. [pmid: 1497295].
1247 Rubayi S, Burnett CC. The efficacy of single-stage surgical management of multiple pressure sores in spinal cord-injured patients. Annals of Plastic Surgery. 1999:533-9. exclusion reason - not relevant. [pmid: 10340863].
1248 Rubayi S, Cousins S, Valentine WA. Myocutaneous flaps. Surgical treatment of severe pressure ulcers. AORN Journal. 1990:40-7. 50. 52. 5. exclusion reason - no original data. [pmid: 2195991].
1249 Rubayi S, Doyle BS. The gluteus maximus muscle-splitting myocutaneous flap for treatment of sacral and coccygeal pressure ulcers. Plastic & Reconstructive Surgery. 1995:1366-71. exclusion reason - not relevant. [pmid: 7480235].
1250 Rubayi S, Kiyono Y. Flap surgery to cover olecranon pressure ulcers in spinal cord injury patients. Plastic & Reconstructive Surgery. 2001:1473-81. exclusion reason - not relevant. [pmid: 11335821].
1251 Rubayi S, Pompan D, Garland D. Proximal femoral resection and myocutaneous flap for treatment of pressure ulcers in spinal injury patients. Annals of Plastic Surgery. 1991:132-8. exclusion reason - not relevant. [pmid: 1952736].
1252 Rubin JA, Whetzel TP, Stevenson TR. The posterior thigh fasciocutaneous flap: Vascular anatomy and clinical application. Plastic & Reconstructive Surgery. 1995:1228-39. exclusion reason - not relevant. [pmid: 7761510].
1253 Rumeau P, Senet P, Lefranc G, Didailler C, Meaume S. supports to aid in prevention and care. Soins; La Revue de Reference Infirmiere. 2001:22-3. exclusion reason - not relevant. [pmid: 12008428].
1254 Russell L The sheepskin myth Nursing Times 20004exclusion reason - background. 11963708
1255 Russell L. Malnutrition and pressure ulcers: Nutritional assesment tools. British Journal of Nursing (BJN). 2000:194-196. exclusion reason - wrong population.
1256 Russell L. Overview of research to investigate pressure-relieving surfaces. British Journal of Nursing. 2001:1421-6. exclusion reason - background. [pmid: 11865248].
1257 Russell L. What is the evidence for specific pressure-reducing mattresses?. British Journal of Nursing. 2002:S5. exclusion reason - no original data. [pmid: 12476147].
1258 Russell L, Reynolds TM, Carr J, Evans A, Holmes M. Randomised controlled trial of two pressure-relieving systems. Journal of Wound Care. 2000:52-5. exclusion reason - duplicate. [pmid: 11933280].
1259 Russell LJ, Reynolds TM, Park C, Rithalia S, Gonsalkorale M, Birch J, Torgerson D, Iglesias C. P-S Group. Randomized clinical trial comparing 2 support surfaces: Results of the prevention of pressure ulcers study. Advances in Skin & Wound Care. 2003:317-27. exclusion reason - wrong outcome. [pmid: 14652518].
1260 Russell T, Bsn AL, Lohman JA. A medical center’s experience with managing specialty bed usage. Journal of Wound, Ostomy, & Continence Nursing. 2001:274-8. exclusion reason - background. [pmid: 11707759].
1261 Russell T, Logsdon A. Pressure ulcers and lateral rotation beds: A case study. Journal of Wound, Ostomy, & Continence Nursing. 2003:143-5. exclusion reason - not relevant.
1262 Ryan DW. The fluidised bed i: Basic principles, bacteriology and wound care. Intensive Care World. 1990:92-6. exclusion reason - unable to find. [pmid: 10148102].
1263 Ryan DW. Cost effectiveness of specialised beds. Care of the Critically Ill. 1994:10+12-13. exclusion reason - wrong outcome.
1264 Ryan DW. The fluidised bed. Intensive Care Medicine. 1995:270-6. exclusion reason - no original data. [pmid: 7790620].
1265 Ryan JM. Occupational therapists: A frontline approach to better managing pressure ulcers. Remington Report. 2008:42. exclusion reason - background.
1266 Rycroft-Malone J, Duff L. Developing clinical guidelines: Issues and challenges. Journal of Tissue Viability. 2000:144-9. 152. 3. exclusion reason - background. [pmid: 11949302].
1267 Rycroft-Malone J, Duff L. Pressure ulcer guidelines. Nursing Standard. 2000:31. exclusion reason - background. [pmid: 11974175].
1268 Ryden MB, Snyder M, Gross CR, Savik K, Pearson V, Krichbaum K, Mueller C. Value-added outcomes: The use of advanced practice nurses in long-term care facilities. Gerontologist. 2000:654-62. exclusion reason - wrong intervention. [pmid: 11131082].
1269 Rygiel R. Death from pressure ulcer. American Journal of Nursing. 2009:13. exclusion reason - not relevant. [pmid: 19411881].
1270 Sabharwal S, Woods P, Spungen AM, Bauman WA, Collins JF. Use of adjunctive therapies for pressure ulcer treatment in sci. Journal of Spinal Cord Medicine. 2009:474. exclusion reason - wrong population.
1271 Sabree M. Death from pressure ulcer. American Journal of Nursing. 2009:13. author reply 14. exclusion reason - no original data. [pmid: 19411882].
1272 Safaie N, Maghamipour N. Management of deep bed sore with closed irrigation in cardiac surgery: Experience with the use of normal saline solution. Research Journal of Medical Sciences. 2009:133-136. exclusion reason - not relevant.
1273 Saggini R, Figus A, Troccola A, Cocco V, Saggini A, Scuderi N. Extracorporeal shock wave therapy for management of chronic ulcers in the lower extremities. Ultrasound in Medicine & Biology. 2008:1261-71. exclusion reason - wrong outcome. [pmid: 18394777].
1274 Sahni T, Singh P, John MJ. Hyperbaric oxygen therapy: Current trends and applications. Journal of the Association of Physicians of India. 2003:280-4. exclusion reason - background. [pmid: 12839352].
1275 Saint-Cyr M, Uflacker A. Pedicled anterolateral thigh flap for complex trochanteric pressure sore reconstruction. Plastic & Reconstructive Surgery. 2012:397e-399e. exclusion reason - not relevant. [pmid: 22286486].
1276 Saji M, Taguchi S, Hayama N, Ohzono E, Kobayashi Y, Uchiyama K, Kanekawa T, Ohkuni H. effect of gentian violet on the elimination of methicillin-resistant staphylococcus aureus (mrsa) existing in the decubitus region. Nippon Ronen Igakkai Zasshi - Japanese Journal of Geriatrics. 1993:795-801. exclusion reason - not relevant. [pmid: 8230793].
1277 Saji M, Taguchi S, Uchiyama K, Osono E, Hayama N, Ohkuni H. Efficacy of gentian violet in the eradication of methicillin-resistant staphylococcus aureus from skin lesions. Journal of Hospital Infection. 1995:225-8. exclusion reason - wrong outcome. [pmid: 8586792].
1278 Salas CamposL, Pastor Amoros T, Martin Campos R, Martinez de la Chica A, De Haro Barrios A. therapeutic uses for asian yellow-flowered crowfoot, genus ranunculus: The case of blastoestimulina. Revista de Enfermeria. 2005:59-62. exclusion reason - background. [pmid: 15768959].
1279 Salawu A, Middleton C, Gilbertson A, Kodavali K, Neumann V. Stump ulcers and continued prosthetic limb use. Prosthetics & Orthotics International. 2006:279-85. exclusion reason - not relevant. [pmid: 17162518].
1280 Salcido R. Anabolic steroids and wound healing. Advances in Wound Care. 1999:391-391. exclusion reason - no original data.
1281 Salcido R. Anabolic steroids for pressure ulcers revisited. Advances in Skin & Wound Care. 2005:344-6. exclusion reason - no original data. [pmid: 16160455].
1282 Salcido SR. 2007 national patient safety goals: Pressure ulcers. Advances in Skin & Wound Care. 2007:630. 632. exclusion reason - background. [pmid: 18091109].
1283 Salles N, Jenn J. Effect of nutritional support in prevention and treatment of pressure ulcers. Nutrition Clinique et Metabolisme. 2012. exclusion reason - background.
1284 Salzberg CA. Continuing the dialogue on healing. Proceedings of the national pressure ulcer advisory panel, fifth national conference, “monitoring pressure ulcer healing: An alternative to reverse staging”. Advances in Wound Care. 1997:8-8. exclusion reason - background.
1285 Salzberg CA, Cooper-Vastola SA, Perez F, Viehbeck MG, Byrne DW. The effects of non-thermal pulsed electromagnetic energy on wound healing of pressure ulcers in spinal cord-injured patients: A randomized, double-blind study. Ostomy Wound Management. 1995:42-4. 46. 48 passim. exclusion reason - background. [pmid: 7546114].
1286 San MiguelL, Torra i Bou JE, Verdu Soriano J. Economics of pressure-ulcer care: Review of the literature on modern versus traditional dressings. Journal of Wound Care. 2007:5-9. exclusion reason - Systematic Review, not directly used. [pmid: 17334139].
1287 Sanada H. evaluation and management of pressure ulcers in the elderly. Nippon Ronen Igakkai Zasshi - Japanese Journal of Geriatrics. 2006:137-46. exclusion reason - not relevant. [pmid: 16683635].
1288 Sanada H. updated pressure ulcer management. Nippon Ronen Igakkai Zasshi - Japanese Journal of Geriatrics. 2007:425-8. exclusion reason - not relevant. [pmid: 17827794].
1289 Sanada H, Nakagami G, Mizokami Y, Minami Y, Yamamoto A, Oe M, Kaitani T, Iizaka S. Evaluating the effect of the new incentive system for high-risk pressure ulcer patients on wound healing and cost-effectiveness: A cohort study. International Journal of Nursing Studies. 2010:279-86. exclusion reason - not relevant. [pmid: 19748617].
1290 Santangelo A, Testai M, Ossino MC, Barbagallo P, Crisafulli C, Muscara G, Tomarchio M, Maugeri D. Management and treatment of decubital ulcers of an elderly population in the assisted sanitary residence of futura-viagrande (catania, sicily, italy). Archives of Gerontology & Geriatrics. 2009:332-4. exclusion reason - wrong intervention. [pmid: 18456351].
1291 Santangelo M. Alleviating bedsores can be done. Today’s Caregiver. 2009:26-27. exclusion reason - background.
1292 Santos VL. Selected abstracts from the 17th biennial congress of the wcet in slovenia: Wound care. World Council of Enterostomal Therapists Journal. 2010:38-40. exclusion reason - background.
1293 Santos VL, Rastinehad D. Wcet: Advancing clinical practice and research-wound abstracts. World Council of Enterostomal Therapists Journal. 2007:34-37. exclusion reason - background.
1294 Sapountzis S, Park HJ, Kim JH, Chantes A, Beak RM, Heo CY. The ‘reading man flap’ for pressure sore reconstruction. Indian Journal of Plastic Surgery. 2011:448-52. exclusion reason - not relevant. [pmid: 22279278].
1295 Sarabia Lavin R, Rojo Santos E. pressure ulcers - management of pressure injuries. Enfermeria Clinica. 2010:136-8. exclusion reason - not relevant. [pmid: 20298952].
1296 Sari AA, Flemming K, Cullum NA, Wollina U. Therapeutic ultrasound for pressure ulcers. Cochrane Database of Systematic Reviews. 2009. exclusion reason - duplicate.
1297 Satoh K, Aoyama R, Yoshikawa A, Iwanami M, Fukuya Y. Reconstruction of pressure sores of the buttocks using fasciocutaneous flaps. Japanese Journal of Plastic and Reconstructive Surgery. 1989:371-377. exclusion reason - not relevant.
1298 Saydak SJ. A pilot test of two methods for the treatment of pressure ulcers. Journal of Enterostomal Therapy. 1990:139-42. exclusion reason - not relevant. [pmid: 2347993].
1299 Scavron C. Clinical investigation to determine an effective protocol for managing pressure on skin and soft tissue. Ostomy Wound Management. 1989:70-9. exclusion reason - wrong population. [pmid: 2730758].
1300 Schaefer C. The treatment of wounds with collagen-containing ointments. Zeitschrift fur Allgemeinmedizin. 1990:665. exclusion reason - no original data.
1301 Schaitel C. Why use a hydrogel dressing?. Advances in Wound Care. 1995:12. exclusion reason - background.
1302 Schaum KD. A new medicare part b wound care policy. Advances in Skin & Wound Care. 2001:238-40. exclusion reason - background. [pmid: 11905971].
1303 Schaum KD. Medicare part b negative pressure wound therapy pump policy. A partner for medicare part a pps. Home Healthcare Nurse. 2002:57-8. exclusion reason - background. [pmid: 11839966].
1304 Schaum KD. New acute care inpatient hospital payment system affects wound care. Advances in Skin & Wound Care. 2008:458-60. exclusion reason - no original data. [pmid: 18836323].
1305 Scheffel S, Panfil E-M. mattresses and co. For prevention of decubitus ulcer. What measures are effective. Pflege Zeitschrift. 2011:162-3. exclusion reason - not relevant. [pmid: 21462468].
1306 Scherer LA, Shiver S, et al. The vacuum assisted closure device: A method of securing skin grafts and improving graft survival. Archives of Surgery. 2002:930-934. exclusion reason - wrong population. [pmid: 12146992].
1307 Schessel ES, Ger R. The management of pressure sores by constant-tension approximation. British Journal of Plastic Surgery. 2001:439-46. exclusion reason - not relevant. [pmid: 11428778].
1308 Scheufler O, Farhadi J, Kovach SJ, Kukies S, Pierer G, Levin LS, Erdmann D. Anatomical basis and clinical application of the infragluteal perforator flap. Plastic & Reconstructive Surgery. 2006:1389-400. exclusion reason - not relevant. [pmid: 17051110].
1309 Schiffman J, Golinko MS, Yan A, Flattau A, Tomic-Canic M, Brem H. Operative debridement of pressure ulcers. World Journal of Surgery. 2009:1396-402. exclusion reason - not relevant. [pmid: 19424752].
1310 Schindler S, Motta GJ. Study project: The use of a topical circulatory stimulant for the treatment of pressure ulcers. Ostomy Wound Management. 1991:50-2. exclusion reason - not relevant. [pmid: 1998544].
1311 Schluer A-B, Cignacco E, Halfens RJ. pressure ulcer prevention and therapy: Results of a descriptive study. Pflege Zeitschrift. 2008:158-61. exclusion reason - not relevant. [pmid: 18450264].
1312 Schmid P, Cox D, Bilbe G, McMaster G, Morrison C, Stahelin H, Luscher N, Seiler W. Tgf-beta s and tgf-beta type ii receptor in human epidermis: Differential expression in acute and chronic skin wounds. Journal of Pathology. 1993:191-7. exclusion reason - background. [pmid: 8277368].
1313 Schmidt AB, Fromberg G, Ruidisch MH. Applications of the pedicled vastus lateralis flap for patients with complicated pressure sores. Spinal Cord. 1997:437-42. exclusion reason - not relevant. [pmid: 9232748].
1314 Schmidtling RE, Gordon SI, Davenport BB. Treating pressure ulcers with a myocutaneous flap. Nursing. 1992:56-9. exclusion reason - not relevant. [pmid: 1407784].
1315 Schmuckler J. Acoustic pressure wound therapy to facilitate granulation tissue in sacral pressure ulcers in patients with compromised mobility: A case series. Ostomy Wound Management. 2008:50-3. exclusion reason - not relevant. [pmid: 18716342].
1316 Schneider SM, Veyres P, Pivot X, Soummer AM, Jambou P, Filippi J, van Obberghen E, Hébuterne X. Malnutrition is an independent factor associated with nosocomial infections. Br J Nutr. 2004:105-111. exclusion reason - wrong population. [pmid: 15230993].
1317 Schoeller T, Shafighi M, Huemer GM, Wechselberger G, Piza-Katzer H. coverage of pressure sores with free flaps. Chirurg. 2003:671-6. exclusion reason - not relevant. [pmid: 12883796].
1318 Schols JMGA. dietary supplements are useful in the prevention and treatment of pressure sores. Nederlands Tijdschrift voor Geneeskunde. 2007:1014. exclusion reason - not relevant. [pmid: 17508686].
1319 Schols JMGA. Protein leakage from pressure ulcers: Clinically relevant?. Nutrition. 2010:859-60. exclusion reason - not relevant. [pmid: 20605697].
1320 Schols JMGA, Heyman H, Meijer EP. Nutritional support in the treatment and prevention of pressure ulcers: An overview of studies with an arginine enriched oral nutritional supplement. Journal of Tissue Viability. 2009:72-9. exclusion reason - no original data. [pmid: 19427218].
1321 Schonfeld M, Moll I, Maier K, Jung EG. keratinocytes from cell culture for therapy of skin defects. Review and personal results. Hautarzt. 1993:281-9. exclusion reason - not relevant. [pmid: 8320114].
1322 Schroder-Van Den, Nieuwendijk Dl, DJ-VDEMA. The effect of a pressure ulcer specific-versus a protein enriched-sip feed on pressure ulcer healing. 2nd World Union of Wound Healing Societies Meeting. 2004. exclusion reason - no original data.
1323 Schuz W, Haas HG, Klemm K. closure of soft tissue defects in bone infections using free and pedicled muscle flaps. Unfallchirurgie. 1987:163-73. exclusion reason - not relevant. [pmid: 3660502].
1324 Scopel F, Mazzon G, Zanettin P, Filippi F, Cattoni C, Pinato G. The use of cadexomer iodine in the treatment of decubitus ulcers. A preliminary note. Giornale Italiano di Ricerche Cliniche e Terapeutiche. 1991:37-44. exclusion reason - not relevant.
1325 Seaborne D, Quirion-DeGirardi C, Rousseau M, Rivest M, Lambert J. The treatment of pressure sores using pulsed electromagnetic energy (peme). Physiotherapy Canada. 1996:131-137. exclusion reason - wrong outcome.
1326 Seal DV, Middleton K. Healing of cavity wounds with sugar. Lancet. 1991:571-2. exclusion reason - no original data. [pmid: 1678823].
1327 Seaman S. Evaluation & management of lower extremity ulcers. Adherence to prescribed therapy can save limbs. Advance for Nurse Practitioners. 2002:32-6. 39. 42. 44 passim. exclusion reason - not relevant. [pmid: 12418335].
1328 Seaman S, Herbster S, Muglia J, Murray M, Rick C. Simplifying modern wound management for nonprofessional caregivers. Ostomy Wound Management. 2000:18-27. exclusion reason - wrong outcome. [pmid: 11189544].
1329 Sebern M. Home-team strategies for treating pressure sores. Nursing. 1987:50-3. exclusion reason - no original data. [pmid: 3645405].
1330 Secretariat MA. Management of chronic pressure ulcers - evidence-based analysis (structured abstract). Health Technology Assessment Database. 2011. exclusion reason - not relevant.
1331 Sedigh M, Polykandriotis E, Jost M, Kees MG, Kees F, Horch RE. Penetration of moxifloxacin into wound tissue and wound exudate obtained during topical negative pressure therapy. Clinical Microbiology and Infection. 2011:S196-S197. exclusion reason - wrong outcome.
1332 Segovia GomezT, Bermejo Martinez M, Molina Silva R, Rueda Lopez J, Torra i Bou JE. skin care and pressure ulcer. Hyperoxygenated fatty acids in the prevention of pressure ulcers and treatment of stage i lesions. Revista de Enfermeria. 2001:18-22. exclusion reason - not relevant. [pmid: 12150123].
1333 Segovia GomezT, Verdu Soriano J, Nolasco Bonmati A, Rueda Lopez J. The effectiveness of a hyperoxygenated fatty acid compound in preventing pressure ulcers. EWMA Journal. 2005:27-31. exclusion reason - not relevant.
1334 Seiler WO. home treatment of decubitus. Deutsche Medizinische Wochenschrift. 1989:1137. exclusion reason - not relevant. [pmid: 2743879].
1335 Seiler WO. prevention of decubitus ulcers and their treatment. Krankenpflege Journal. 1989:15-20. exclusion reason - not relevant. [pmid: 2601292].
1336 Seiler WO, Stahelin HB. Pressure sores in geriatrics - pathogenesis, prophylaxis and therapy. Therapeutische Umschau. 1991:329-340. exclusion reason - not relevant. [pmid: 1871688].
1337 Seiler WO, Stahelin HB. therapy of decubitus ulcers. 3. Krankenpflege - Soins Infirmiers. 1994:53-9. exclusion reason - not relevant. [pmid: 8015266].
1338 Seiler WO, Stahelin HB. a little known element of modern ulcer therapy: Moist therapy of chronic skin ulcers. Krankenpflege - Soins Infirmiers. 1998:35-8. exclusion reason - not relevant. [pmid: 9748959].
1339 Seiler WO, Stahelin HB. malnutrition prevents healing of decubitus ulcers. Krankenpflege Journal. 1998:333-41. exclusion reason - not relevant. [pmid: 9807378].
1340 Seiler WO, Stahelin HB. search for factors preventing wound healing. A motivating therapy concept in chronic decubitus ulcers. Krankenpflege Journal. 1999:317-23. exclusion reason - not relevant. [pmid: 10542559].
1341 Seki M, Takahashi H, Chino N. treatment of pressure sores accompanied by infection in outpatients with spinal cord injury. Gan to Kagaku Ryoho. Japanese Journal of Cancer & Chemotherapy. 2000:756-9. exclusion reason - not relevant. [pmid: 11190341].
1342 Semo AH. Relationship-based care: A model for wocn and woca practice. 41st annual wound, ostomy and continence nurses annual conference. st. Louis, missouri. june 6–10, 2009. Wound, ostomy, continence nurse...Wound, ostomy, continence associate. Journal of Wound, Ostomy & Continence Nursing. 2009:S25-S25. exclusion reason - background.
1343 Senet P, Meaume S. Local and general treatment of pressure sores in the elderly. Presse Medicale. 1999:1840-1845. exclusion reason - not relevant. [pmid: 10584120].
1344 Senet P, Meaume S. Decubitus ulcers. Revue du Praticien. 2000:1965-1969. exclusion reason - not relevant. [pmid: 11151341].
1345 Serena T, Wolcott R, DiSalvo M, Hurley D. Bilayered living cell-based treatment for pressure ulcers:Reuslts of a prospective, randomized, multi-center, open-label clinical trial. The Symposium on Advanced Wounds Care and the Wound Healing Society. 2010. exclusion reason - unable to find.
1346 Severens JL, Habraken JM, Duivenvoorden S, Frederiks CMA. The cost of illness of pressure ulcers in the netherlands. Advances in Skin & Wound Care. 2002:72-7. exclusion reason - background. [pmid: 11984050].
1347 Seyhan T, Ertas NM, Bahar T, Borman H. Simplified and versatile use of gluteal perforator flaps for pressure sores. Annals of Plastic Surgery. 2008:673-8. exclusion reason - not relevant. [pmid: 18520206].
1348 Sha L. Clinical observation on w-s analogous mankind frequency spectrum apparatus for treatment of bed sore. [chinese]. Shanxi Journal of Nursing. 1995:80-1. exclusion reason - not relevant.
1349 Shahin ESM, Dassen T, Halfens RJG. Incidence, prevention and treatment of pressure ulcers in intensive care patients: A longitudinal study. International Journal of Nursing Studies. 2009:413-21. exclusion reason - wrong outcome. [pmid: 18394626].
1350 Sham E, Choi W-T, Flood SJ. Lateral supramalleolar flap in reconstruction of pressure ulcers in patients with spinal cord injury. ANZ Journal of Surgery. 2008:167-71. exclusion reason - not relevant. [pmid: 18269481].
1351 Shamimi NouriK, Heshmat R, Karimian R, Nasli E, Larijani B, Novitsky YA, Farhadi M, Gharibdoust F. Intravenous semelil (angipars(trademark)) as a novel therapy for pressure ulcers: A randomized clinical trial. Daru. 2008:49-53. exclusion reason - wrong intervention.
1352 Shannon ML, Miller B. Evaluation of hydrocolloid dressings on healing of pressure ulcers in spinal cord injury patients. Decubitus. 1988:42-6. exclusion reason - not relevant. [pmid: 3254702].
1353 Shapiro P. An investigation into the prevention and management of pressure ulcers in ventilator assisted patients using an alternating mattress replacement with advanced features. 2008. exclusion reason - no original data.
1354 Sharp A. Pilot study to compare the incidence of pressure ulceration on two therapeutic support surfaces in elderly care. 17th Conference of the European Wound Management Association. 2007. exclusion reason - wrong population.
1355 Sharp C, Burr G, Broadbent M, Cummins M, Casey H, Merriman A. Pressure ulcer prevention and care: A survey of current practice. Journal of Quality in Clinical Practice. 2000:150-7. exclusion reason - background. [pmid: 11207953].
1356 Sheffet A, Cytryn AS, Louria DB. Applying electric and electromagnetic energy as adjuvant treatment for pressure ulcers: A critical review. Ostomy Wound Management. 2000:28-33. 36. 40. 42. 4. exclusion reason - background. [pmid: 10745854].
1357 Shekhterman T, Targonski A, Mulhall ML. Evaluation and treatment of pressure ulcers. Combined Sections Meeting of the Specialty Sections of the American Physical Therapy Association. San Diego, California. 2006. exclusion reason - unable to find.
1358 Sherman RA. Maggot therapy for treating diabetic foot ulcers unresponsive to conventional therapy. Diabetes Care. 2003:446-451. exclusion reason - wrong population. [pmid: 12547878].
1359 Shigeyama M. preparation of a gel-forming ointment base applicable to the recovery stage of bedsore and clinical evaluation of a treatment method with different ointment bases suitable to each stage of bedsore. Yakugaku Zasshi - Journal of the Pharmaceutical Society of Japan. 2004:55-67. exclusion reason - not relevant. [pmid: 14978948].
1360 Shigeyama M, Oogaya T, Yoneyama T, Futamura M, Murakawa T, Shibata H, Takeuchi H, Kawashima Y. preparation of a gel-forming ointment base applicable to the recovery stage of bedsore and clinical evaluation of a treatment method with different ointment bases suitable to each stage of bedsore. Yakugaku Zasshi - Journal of the Pharmaceutical Society of Japan. 2001:441-50. exclusion reason - not relevant. [pmid: 11433778].
1361 Shimada S, Ogawa T, Fukuya Y. The method of keeping complete rest for postoperative patients of pressure sore. Japanese Journal of Plastic and Reconstructive Surgery. 2004:1234-1236. exclusion reason - not relevant.
1362 Shimamoto Y, Shimamoto H, Fujihata H, Nakamura H, Matsuura Y. Topical application of sugar and povidone-iodine in the management of decubitus ulcers in aged patients. Hiroshima Journal of Medical Sciences. 1986:167-9. exclusion reason - not relevant. [pmid: 3771275].
1363 Shindo K. Clinical report on effects of skin barrier containing sodium carboxymethyl cellulose on decubitus. Japanese Pharmacology and Therapeutics. 1990:277-288. exclusion reason - not relevant.
1364 Shioda K, Nisijima K, Kobayashi T, Kato S. Iodoform poisoning: An unrecognized cause of consciousness disturbance. General Hospital Psychiatry. 2004:83-4. exclusion reason - not relevant. [pmid: 14757308].
1365 Shipkov C, Hadjiev B, Stefanova P, Mojallal A, Uchikov A. The posterior thigh flap for ischial pressure sores. Journal of Reconstructive Microsurgery. 2011:141-2. exclusion reason - no original data. [pmid: 20945278].
1366 Shipperley T. Guidelines for pressure sore prevention and management. Journal of Wound Care. 1998:309-11. exclusion reason - background. [pmid: 9697467].
1367 Shipperley T. Guidelines for pressure ulcer prevention and management. Nursing Times. 2000:11-2. exclusion reason - background. [pmid: 10827728].
1368 Shojaei H, Sokhangoei Y, Soroush MR. Low level laser therapy in the treatment of pressure ulcers in spinal cord handicapped veterans living in tehran. Iranian Journal of Medical Sciences. 2008:44-48. exclusion reason - wrong population.
1369 Sholar AD, Wong LK, Culpepper JW, Sargent LA. The specialized wound care center: A 7-year experience at a tertiary care hospital. Annals of Plastic Surgery. 2007:279-84. exclusion reason - wrong intervention. [pmid: 17471132].
1370 Shutler S, Stock J, Bale S, Harding KG, Squires D, Wilson I, et al. A multi-centre comparison of a hydrocellular adhesive dressing (allevyn adhesive) and a hydrocolloid dressing (granuflex) in the management of stage 2 and 3 pressure sores. Proceedings of the 5th European Conference on Advances in Wound Management. 1995. exclusion reason - no original data.
1371 Sibbald RG, Coutts P, Woo KY. Reduction of bacterial burden and pain in chronic wounds using a new polyhexamethylene biguanide antimicrobial foam dressing-clinical trial results. Advances in Skin & Wound Care. 2011:78-84. exclusion reason - wrong outcome. [pmid: 21242737].
1372 Sibbald RG, Woo KY, Ayello EA. Healing chronic wounds: Dim before dime can help... Debridement, infection/inflammation, moisture balance, edge effect. Ostomy Wound Management. 2009:12-12. exclusion reason - not relevant.
1373 Siddiqui A, Wiedrich T, Lewis VL Jr. Tensor fascia lata v-y retroposition myocutaneous flap: Clinical experience. Annals of Plastic Surgery. 1993:313-7. exclusion reason - not relevant. [pmid: 8239429].
1374 Siddiqui F, Steinberg J. Essential treatment tips for decubitus ulcers. Podiatry Today. 2011:44. exclusion reason - background.
1375 Sideranko S, Quinn A, Burns K, Froman RD. Effects of position and mattress overlay on sacral and heel pressures in a clinical population. Research in Nursing & Health. Wiley Subscription Services, Inc., A Wiley Company. 1992:245-251. [pmid: 1496149]. exclusion reason - wrong outcome.
1376 Siegel TJ. Death from pressure ulcer. American Journal of Nursing. 2009:13-4. author reply 14. exclusion reason - not relevant. [pmid: 19411880].
1377 Silvetti AN, Hagen JC, Gaffud J, Sankoorikal J, Neerukonda S, Pettke E. Topical use of d - glucose polysaccaharide (dgp) and other nutrients as an effective method to treat and prevent pressure ulcers in the elderly. San Antonio, TX. exclusion reason - no original data.
1378 Singh R, Rohilla RK, Siwach R, Verma V, Kaur K. Surgery for pressure ulcers improves general health and quality of life in patients with spinal cord injury. Journal of Spinal Cord Medicine. 2010:396-400. exclusion reason - not relevant. [pmid: 21061899].
1379 Singh R, Verma V. Does surgery for pressure ulcers alter rehabilitation outcome?. Journal of Spinal Cord Medicine. 2009:459. exclusion reason - not relevant.
1380 Sinha SN, Amarasena I. Does phenytoin have a role in the treatment of pressure ulcers?. Wound Practice & Research. 2008:37-41. exclusion reason - not relevant.
1381 Sipponen A, Jokinen JJ, Lohi J. Resin salve from the norwegian spruce tree: A ‘novel’ method for the treatment of chronic wounds. Journal of Wound Care. 2007:72-4. exclusion reason - not relevant. [pmid: 17319621].
1382 Sipponen A, Jokinene JJLJ, Sipponen P. Efficiency of resin salve from norway spruce in treatment of pressure ulcers and chronic surgical and traumatic wounds. EWMA Journal. 41. exclusion reason - not relevant.
1383 Skipper A. Challenges in nutrition, pressure ulcers, and wound healing. Nutrition in Clinical Practice. 2010:13-5. exclusion reason - background. [pmid: 20130153].
1384 Skorkowska-Telichowska K, Kulma A, Zk M, Czuj T, Szopa J. The effects of newly developed linen dressings on decubitus ulcers. Journal of Palliative Medicine. 2012:146-148. exclusion reason - no original data. [pmid: 22313461].
1385 Smith DM. Pressure ulcers in the nursing home. Annals of Internal Medicine. 1995:433-42. exclusion reason - Systematic Review, not directly used. [pmid: 7639444].
1386 Smith DM, Snow DE, Rees E, Zischkau AM, Hanson JD, Wolcott RD, Sun Y, White J, Kumar S, Dowd SE. Evaluation of the bacterial diversity of pressure ulcers using btefap pyrosequencing. BMC Medical Genomics. 2010. exclusion reason - background. [pmid: 20854691].
1387 Smith N. The benefits of vac therapy in the management of pressure ulcers. British Journal of Nursing. 2004:1359-65. exclusion reason - no original data. [pmid: 15687905].
1388 Smith RA, Powell JF. Pressure sores. Prevention and treatment. Current Therapeutics. 1986:49-62. exclusion reason - no original data.
1389 Smith-Temple J, Johnson JY. Hospital extra. Clinical procedures. Decubitus care.. Adapted with permission from nurses’ guide to clinical procedures. 2nd edition. smith-temple jean msn, rn, johnson joyce young phd, ccrn, editors. copyright 1994 by j.B. Lippincott company. phildelaphia. American Journal of Nursing. 1997:16D-e. exclusion reason - background.
1390 Smith-Temple J, Johnson JY. Hospital extra. Clinical procedures. Pressure ulcer management.. Adapted with permission from nurses’ guide to clinical procedures. 3rd edition. smith-temple jean msn, rn, johnson joyce young phd, ccrn, editors. copyright 1998 by lippincott-raven publishers. philadelphia, pa. American Journal of Nursing. 1998:16D. exclusion reason - background.
1391 Smoot EC. Beware of the low-pressure bed substitute. [18]. Plastic and Reconstructive Surgery. 2000:1908. exclusion reason - background. [pmid: 10809139].
1392 Smy J. Making the beds better. Nursing Times. 2004:24-5. exclusion reason - background. [pmid: 15630966].
1393 Snyder RJ. Wound management. Nutrition and its role in wound healing. Podiatry Management. 2006:175-176. exclusion reason - background.
1394 Soares MO, Dumville JC, Ashby RL, Iglesias C, Bojke L, Adderley U, McGinnis E, Stubbs N, Torgerson DJ, Claxton K, Cullum N. Negative pressure wound therapy for severe pressure ulcers: Evidence synthesis and the value of further research. Wound Repair and Regeneration. 2011:A52. exclusion reason - no original data.
1395 Sobotka L, Meguid MM. Healing of wounds and pressure ulcers. Nutrition. 2010:856-7. exclusion reason - background. [pmid: 20598854].
1396 Sociedad Espanola de, Q., I. Sociedad Espanola de Medicina and C. Asociacion Espanola de. treatment guide for skin and soft tissue infections. Spanish chemotherapy society, spanish internal medicine society, spanish association of surgeons. Revista Espanola de Quimioterapia. 2006:378-94. exclusion reason - background. [pmid: 17235409].
1397 Soldevilla Agreda J, Martinez Cuervo F. society and chronic wounds. Thoughts to stop invisibility. Revista de Enfermeria. 2005:35-8. exclusion reason - background. [pmid: 15768956].
1398 Soldevilla Agreda JJ. research on chronic wounds. Revista de Enfermeria. 2007:4-6. exclusion reason - background. [pmid: 17380629].
1399 Soldevilla Agreda JJ, Je, Posnett J, Verdu Soriano J, San Miguel L, Mayan Santos M. The burden of pressure ulcers in spain. Wounds: A Compendium of Clinical Research & Practice. 2007:201-206. exclusion reason - background.
1400 Solomon M, Davis P, Tran NV, Rock M. Use of bioabsorbable bone graft in osteomyelitis associated with ischial pressure sores. Plastic & Reconstructive Surgery. 2010:102e-4e. exclusion reason - wrong population. [pmid: 20679810].
1401 Soloway DN. Civil claims relating to pressure ulcers: A claimants’ lawyer’s perspective. Ostomy Wound Management. 1998:20-4. 26. exclusion reason - background. [pmid: 9526418].
1402 Song KY. effects of immobility: Pressure sores and their management. Taehan Kanho - Korean Nurse. 1991:32-40. exclusion reason - not relevant. [pmid: 1921267].
1403 Sopata M. Advances in treatment of pressure ulcers and chronic wounds. Onkologia Polska. 2008:153-156. exclusion reason - no original data.
1404 Sopata M, Luczak J. The new dressing aquacel -- advances in the treatment of heavily exuding pressure sores. [polish]. Przeglad Flebologiczny. 2003:139-142. exclusion reason - not relevant.
1405 Sopata M, Luczak J, Ciupinska M. Effect of bacteriological status on pressure ulcer healing in patients with advanced cancer. Journal of Wound Care. 2002:107-10. exclusion reason - not relevant. [pmid: 11933727].
1406 Soppi E, TJ. Novel carital specialty mattress in the management of pressure sores. 2nd World Union of Wound Healing Societies Meeting. 2004. exclusion reason - no original data.
1407 Sorensen JL, Jorgensen B, Gottrup F. Surgical treatment of pressure ulcers. American Journal of Surgery. 2004:42-51. exclusion reason - background. [pmid: 15223502].
1408 Sorensen JL, Lassen MK, Alsbjorn BF, Gottrup F. pressure sores. Background and therapeutic strategy. Ugeskrift for Laeger. 1997:275-9. exclusion reason - background. [pmid: 9054068].
1409 Sorrentino EA, Mayrovitz HN. Microcirculation: An open area for nursing research. Critical Care Nursing Quarterly. 1991:1-7. exclusion reason - background. [pmid: 1933540].
1410 Spadafora A, Durand AS, De los Rios E, Vinas JM. Rocking shoes for beds: Prevention and treatment of pressure sores. Prensa Medica Argentina. 1985:324-328. exclusion reason - not relevant.
1411 Spahn JG. Develop a seamless individualized pressure ulcer care plan: Recognize-understand-solve. Home Health Care Management & Practice. 2007:285-293. exclusion reason - background.
1412 Spahn JG. Rethinking treatment for pressure sores. Advance for Physical Therapy & Rehab Medicine. 2010:55-55. exclusion reason - background.
1413 Sparholt SH. Cost-effectiveness of wound management protocols debated. British Journal of Nursing. 2001:216-7. author reply 216–7. exclusion reason - background. [pmid: 12170644].
1414 Spauwen PHM, Robinson PH, De Bruijn HP, Mulder D. Surgical treatment of pressure sore in paraplegic patients: An evaluation. Netherlands Journal of Surgery. 1989:68-70. exclusion reason - not relevant. [pmid: 2747967].
1415 Specht JP, Bergquist S, Frantz RA. Adoption of a research-based practice for treatment of pressure ulcers. Nursing Clinics of North America. 1995:553-63. exclusion reason - background. [pmid: 7567579].
1416 Speed CAC. Therapeutic ultrasound in soft tissue lesions. Rheumatology (Oxford). 2001:1331-1336. exclusion reason - background. [pmid: 11752501].
1417 Spetalnick BM, Powers JS. Decubitus ulcer treatment with the water flotation mattress. Journal of the Tennessee Medical Association. 1989:471-2. exclusion reason - wrong outcome. [pmid: 2796333].
1418 Spillo NM Managing stage iv pressure ulcers in the home Ostomy Wound Management 20096exclusion reason - no original data. 19673057
1419 Splete H. International pressure ulcer guidelines released in draft. Caring for the Ages. 2009:2p. exclusion reason - background.
1420 Spoelhof GD, Ide K. Pressure ulcers in nursing home patients. American Family Physician. 1993:1207-15. exclusion reason - background. [pmid: 8465716].
1421 Sposato G, Ziccardi P, Di Caprio G, Scioli M, Palma T, Scuderi N. Gluteus myocutaneous flap repairs ischial pressure sores. Rivista Italiana di Chirurgia Plastica. 2001:99-102. exclusion reason - not relevant.
1422 Sprigle S. Prescribing pressure ulcer treatment. Rehab Management. 2000:72-7. exclusion reason - no original data. [pmid: 11702387].
1423 Spungen AM. Vacuum assisted therapy for pressure ulcers in patients with spinal cord injury. exclusion reason - no original data.
1424 Spungen AM. Healing rate of chronic stage 3 and 4 pressure ulcers. 52nd Annual Conference of American Paraplegia Society. exclusion reason - Systematic Review, not directly used.
1425 Spungen AM, Koehler KM, Modeste-Duncan R, Rasul M, Cytryn AS, Bauman WA. 9 clinical cases of nonhealing pressure ulcers in patients with spinal cord injury treated with an anabolic agent: A therapeutic trial. Advances in Skin & Wound Care. 2001:139-44. exclusion reason - not relevant. [pmid: 11905979].
1426 Spurgin S, Clinch K. Journal of wound care nursing. A new dressing for pressure sores. Nursing Times. 1991:82. 84. exclusion reason - wrong outcome. [pmid: 1886821].
1427 Srivastava A, Gupta A, Taly AB, Murali T. Surgical management of pressure ulcers during inpatient neurologic rehabilitation: Outcomes for patients with spinal cord disease. Journal of Spinal Cord Medicine. 2009:125-31. exclusion reason - not relevant. [pmid: 19569459].
1428 St Clair M. Descriptive study of the use of a specialty bed in the united kingdom. Decubitus. 1992:28-30. 32. 36 passim. exclusion reason - no original data. [pmid: 1558690].
1429 Staas WE Jr, Cioschi HM. Pressure sores--a multifaceted approach to prevention and treatment. Western Journal of Medicine. 1991:539-44. exclusion reason - background. [pmid: 1830985].
1430 Stacey M, Falanga V, Marston W, Moffat C, Phillips T, Sibbald RG, Vanscheidt W, Lindholm C. Compression therapy in the treatment of venous leg ulcers. Nursing Times. 2002:39-43. exclusion reason - wrong population. [pmid: 12244668].
1431 Staiano J, Richard B, Graham K. Pressure sore of the helical rim: A new problem, a novel treatment. Plastic & Reconstructive Surgery. 2004:1655-7. exclusion reason - background. [pmid: 15509972].
1432 Stair JM, Petty PM. Clinical uses of the tensor fascia lata myocutaneous flap. Journal of the Arkansas Medical Society. 1985:475-7. exclusion reason - no original data. [pmid: 3156119].
1433 Stamate T, Budurca AR. The treatment of the sacral pressure sores in patients with spinal lesions. Acta Neurochirurgica - Supplement. 2005:183-7. exclusion reason - not relevant. [pmid: 15986752].
1434 Stapleton M. Preventing pressure sores--an evaluation of three products. Geriatric nursing (London, England). 1986:23-5. exclusion reason - wrong population. [pmid: 3635484].
1435 Starritt T, Ewing E. Implementing good practice in the prevention and management of pressure sores. British Journal of Theatre Nursing. 1999:60-3. exclusion reason - background. [pmid: 10232135].
1436 Stechmiller JK, Cowan L, Whitney JD, Phillips L, Aslam R, Barbul A, Gottrup F, Gould L, Robson MC, Rodeheaver G, Thomas D, Stotts N. Guidelines for the prevention of pressure ulcers. Wound Repair & Regeneration. 2008:151-168. exclusion reason - background. [pmid: 18318801].
1437 Steele K, Irwin G, Dowds N. Cadexomer iodine in the management of venous leg ulcers in general practice. Practitioner. 1986:63-68. exclusion reason - wrong population. [pmid: 3513150].
1438 Steenfos HH, Agren MS. A fibre-free alginate dressing in the treatment of split thickness skin graft donor sites. Journal of the European Academy of Dermatology and Venereology. 1998:252-256. exclusion reason - wrong population. [pmid: 9883438].
1439 Stenberg M. Air support therapy. Journal of ET Nursing. 1993:132-3. exclusion reason - not relevant. [pmid: 8347760].
1440 Stephen-Haynes J. Achieving effective outcomes: Monitoring the effectiveness of the softform premier active[™] mattress. British Journal of Community Nursing. 2010:S48-54. exclusion reason - no original data. [pmid: 20852536].
1441 Stephen-Haynes J. Managing exudate and the key requirements of absorbent dressings. British Journal of Cardiac Nursing. 2011:S44-9. exclusion reason - not relevant.
1442 Stephen-Haynes J, Callaghan R. Clinical outcomes using a low friction and shear garment in the care home setting. Wounds UK. 2011:76-84. exclusion reason - wrong population.
1443 Stevenson TR, Pollock RA, Rohrich RJ, VanderKolk CA. The gluteus maximus musculocutaneous island flap: Refinements in design and application. Plastic & Reconstructive Surgery. 1987:761-8. exclusion reason - not relevant. [pmid: 3575521].
1444 Stockarova D, Pilnacek J, Rubin J. Gluteus maximus musculocutaneous island flaps and their use in sacral decubitus ulcers. Acta Chirurgiae Plasticae. 1985:176-84. exclusion reason - not relevant. [pmid: 4060966].
1445 Stockarova D, Pilnacek J, Rubin J. treatment of sacral decubiti using musculocutaneous flaps. Rozhledy V Chirurgii. 1986:85-92. exclusion reason - not relevant. [pmid: 3961603].
1446 Stone A. Pilot study of pressure ulcer mitigation using a unique pressure-redistributing support surface. exclusion reason - Scientific Information Packets, not directly used.
1447 Stone JM, Wolfe VA, Nino-Murcia M, Perkash I. Colostomy as treatment for complications of spinal cord injury. Archives of Physical Medicine & Rehabilitation. 1990:514-8. exclusion reason - not relevant. [pmid: 2350223].
1448 Stone PJ, Prigozen M, Hofeldt, et al. Bolster versus negative pressure wound therapy for securing split-thickness skin grafts in trauma patients. Wounds UK. 2004. exclusion reason - wrong population.
1449 Stoneberg C, Pitcock N, Myton C. Pressure sores in the homebound: One solution. American Journal of Nursing. 1986:426-8. exclusion reason - wrong population. [pmid: 3633697].
1450 Stranadko EP, Tolstykh PI, Kuleshov IY. Antibacterial photodynamic therapy for treating non-healing purulent wounds and trophic ulcers. Photodiagnosis and Photodynamic Therapy. 2010:S18. exclusion reason - no original data.
1451 Stratton RJ, Ek A-C, Engfer M, Moore Z, Rigby P, Wolfe R, Elia M. Enteral nutritional support in prevention and treatment of pressure ulcers: A systematic review and meta-analysis. Ageing Research Reviews. 2005:422-50. exclusion reason - Systematic Review, not directly used. [pmid: 16081325].
1452 Strauss MJ, Gong J, Gary BD, Kalsbeek WD, Spear S. The cost of home air-fluidized therapy for pressure sores. A randomized controlled trial. Journal of Family Practice. 1991:52-9. exclusion reason - duplicate. [pmid: 2056290].
1453 Suissa D, Danino A, Nikolis A. Negative-pressure therapy versus standard wound care: A meta-analysis of randomized trials. Plastic & Reconstructive Surgery. 2011:498e-503e. exclusion reason - background. [pmid: 22030509].
1454 Suit H, Spiro IJ. Soft tissue sarcomas: Radiation as a therapeutic option. Ann Acad Med Singapore. 1996:855-861. exclusion reason - wrong population. [pmid: 9055016].
1455 Sullivan N, Snyder DL, Tipton K, Uhl S, Schoelles KM. Negative pressure wound therapy devices. Technology Assessment Report. Rockville, Maryland: AHRQ. 2009:494. exclusion reason - Systematic Review, not directly used.
1456 Summer WR, Curry P, Haponik EF, Nelson S, Elston R. Continuous mechanical turning of intensive care unit patients shortens length of stay in some diagnostic-related groups. Journal of Critical Care. 1989:45-53. exclusion reason - wrong population.
1457 Summers JB, Kaminski JM. Management of pressure ulcers. JAMA. 2003:2210. author reply 2210–1. exclusion reason - no original data. [pmid: 12734127].
1458 Sung YH, Park KH. Factors affecting the healing of pressure ulcers in a korean acute care hospital. Journal of Wound, Ostomy, & Continence Nursing. 2011:38-45. exclusion reason - background. [pmid: 21178788].
1459 Surratt SC. Help for managing pressure ulcers. Nursing Management. 2000:6-6. exclusion reason - no original data.
1460 Suzuki S. Conservative treatment using various dressings. Japanese Journal of Plastic and Reconstructive Surgery. 2003:471-475. exclusion reason - not relevant.
1461 Suzuki T, Yamashita R, Tanaka M, Yamada N, Uchinuma E, Kuroyanagi Y. Development of new hydrocolloid-type wound dressing containing silver sulfadiazine - multi-centre’s clinical reports. Japanese Pharmacology and Therapeutics. 2000:621-633. exclusion reason - not relevant.
1462 Szabo E, Bujdoso J. Calendula officinalis in wound treatment. [hungarian]. Nover. 1994:20-22. exclusion reason - not relevant.
1463 Szor JK, Bourguignon C. Description of pressure ulcer pain at rest and at dressing change. Journal of Wound, Ostomy, & Continence Nursing. 1999:115-20. exclusion reason - wrong intervention. [pmid: 10711120].
1464 Tachi M, Hirabayashi S. Adjuvant therapy for pressure ulcer management. Japanese Journal of Plastic and Reconstructive Surgery. 2003:477-483. exclusion reason - wrong population.
1465 Tachi M, Hirabayashi S, Yonehara Y, Uchida G, Tohyama T, Ishii H. Topical negative pressure using a drainage pouch without foam dressing for the treatment of undermined pressure ulcers. Annals of Plastic Surgery. 2004:338-42. exclusion reason - not relevant. [pmid: 15385767].
1466 Tachibana S. Clinical evaluation of ulcer dressing for burns, pressure sores, donor sites of skin grafts and similar applications. Japanese Journal of Plastic and Reconstructive Surgery. 1990:321-326. exclusion reason - not relevant.
1467 Tada H, Hatoko M, Tanaka A, Kuwahara M, Mashiba K, Yurugi S. Experiences of the reconstruction of sacral pressure sores with the parasacral perforator-based island flap. European Journal of Plastic Surgery. 2002:17-20. exclusion reason - not relevant.
1468 Takahashi C, Nemoto H, Shibagaki Y. Management of pressure ulcers using design. World Council of Enterostomal Therapists Journal. 2010:40. exclusion reason - wrong intervention.
1469 Takahashi PY, Cha SS, Kiemele LJ. Six-month mortality risks in long-term care residents with chronic ulcers. International Wound Journal. 2008:625-31. exclusion reason - wrong intervention. [pmid: 19134063].
1470 Takahashi PY, Kiemele LJ, Chandra A, Cha SS, Targonski PV. A retrospective cohort study of factors that affect healing in long-term care residents with chronic wounds. Ostomy Wound Management. 2009:32-7. exclusion reason - wrong intervention. [pmid: 19174587].
1471 Takahashi PY, Kiemele LJ, Jones JP. Wound care for elderly patients: Advances and clinical applications for practicing physicians. Mayo Clinic Proceedings. 2004:260-7. exclusion reason - wrong population. [pmid: 14959923].
1472 Takala J, Varmavuo S, Soppi E. Prevention of pressure sores in acute respiratory failure: A randomised controlled trial. Clin Intensive Care. 1996:228-235. exclusion reason - wrong outcome.
1473 Takeuchi A, Yamamoto Y, Minakawa H, Kokubu I, Sugihara T, Yoshida T. The use of a rectus abdominis myocutaneous flap for repair of defects of the inguinal and ischial regions. Japanese Journal of Plastic and Reconstructive Surgery. 1996:21-25. exclusion reason - not relevant.
1474 Takeuchi K. treatment of decubitus and leg ulcer in small cohort hospital without plastic surgeon--a view point of community cooperation and home-based care. Gan to Kagaku Ryoho. Japanese Journal of Cancer & Chemotherapy. 2009:63-5. exclusion reason - not relevant. [pmid: 20443404].
1475 Taniguchi S, Urakawa S. A follow-up study of recurred decubites ulcer cases. Japanese Journal of Plastic and Reconstructive Surgery. 1990:547-554. exclusion reason - not relevant.
1476 Tarantola P, Lombardi G, Inzoli MR, Malgeri C, Magnolfi G. The effect of local application of hyaluronic acid associated with lasertherapy in the treatment of decubitus ulcers. An open control clinical study. Giornale di Gerontologia. 1990:151-155. exclusion reason - not relevant.
1477 Tarvainen. Cadexomer iodine (iodosorb) compared with dextranomer (debrisan) in the treatment of chronic leg ulcers. Acta Chir Scand Suppl. 1988:57-59. exclusion reason - wrong population. [pmid: 2459870].
1478 Tate P. A holistic approach to pressure area care. Nursing Times. 1998:69-72. exclusion reason - no original data. [pmid: 9625971].
1479 Tavakoli K, Rutkowski S, Cope C, Hassall M, Barnett R, Richards M, Vandervord J. Recurrence rates of ischial sores in para- and tetraplegics treated with hamstring flaps: An 8-year study. British Journal of Plastic Surgery. 1999:476-9. exclusion reason - not relevant. [pmid: 10673925].
1480 Taylor A. Managing pressure ulcers: The need for pain assessment. Community Nurse. 2000:45-6. exclusion reason - no original data. [pmid: 12778508].
1481 Taylor BB. Duoderm wafers: A report on product evaluation. New Zealand Nursing Journal. 1985:10-1. exclusion reason - no original data. [pmid: 3858747].
1482 Taylor TV, Rimmer S, Day B, Butcher J, Dymock IW. Ascorbic acid supplementation in the treatment of pressure-sores. Lancet. 1974:544-546. exclusion reason - background. [pmid: 4140267].
1483 Tazawa K, Kasagi T, Takemori S, Arai H, Yamamoto K, Fujimaki M. Clinical evaluation of a new hydrocolloid dressing in pressure sores. Therapeutic Research. 1990:231-245. exclusion reason - not relevant.
1484 Tebbe B, Orfanos CE. Therapy of leg ulcers and decubitus ulcers with a xerodressing: Modern wound dressing with anti-bacterial activity. H+G Zeitschrift fur Hautkrankheiten. 1996:697-702. exclusion reason - not relevant.
1485 Teichs T, Purfield J. Keeping current: Electrical stimulation can augment standard pressure ulcer management. Advance for Physical Therapy & Rehab MedicineAdv Phys Ther Rehab Med. 2010:28. exclusion reason - wrong intervention.
1486 Tellioglu AT, Bilen BT, Ulusoy G, Akan M, Celebioglu S, Kocer U, Baran C. Ideal treatment modality for trochanteric pressure sores. European Journal of Plastic Surgery. 1998:184-185. exclusion reason - not relevant.
1487 Tellioglu AT, Tekdemir I, Akyuz M, Arifoglu K, Bilen BT, Ulusoy G, Sensoz O. Ischial pressure sores treated with a sensate gracilis myocutaneous flap. European Journal of Plastic Surgery. 2000:132-134. exclusion reason - not relevant.
1488 Teng BT, Tam EW, Benzie IF, Siu PM. Protective effect of caspase inhibition on compression-induced muscle damage. Journal of Physiology. 2011:3349-69. exclusion reason - wrong population. [pmid: 21540338].
1489 Teno J, Gozalo P, Mitchell S, Kuo S, Fulton A, Mor V. Does percutaneous gastrostomy tubes prevent or heal decubitus ulcers in advanced cognitive impairment?. Journal of Pain and Symptom Management. 2012:335. exclusion reason - not relevant.
1490 Teno JM, Gozalo P, Mitchell SL, Kuo S, Fulton AT, Mor V. Feeding tubes and the prevention or healing of pressure ulcers. Archives of Internal Medicine. 2012:697-701. exclusion reason - not relevant. [pmid: 22782196].
1491 Teot L. the “surgical moment” in the care of chronic wounds. Soins; La Revue de Reference Infirmiere. 2000:9-11. exclusion reason - not relevant. [pmid: 11040819].
1492 Teot L. decubitus ulcers. Revue de L’Infirmiere. 2003:55-8. exclusion reason - not relevant. [pmid: 12677911].
1493 Teot L. decubitus ulcers in paraplegics. Soins; La Revue de Reference Infirmiere. 2005:20-1. exclusion reason - not relevant. [pmid: 15997483].
1494 Ter Riet G. Correction: Randomised clinical trial of ultrasound treatment for pressure ulcers (british medical journal (22nd april) (1040–1041)). British Medical Journal. 1995:1300. exclusion reason - no original data.
1495 ter Riet G, Kessels AG, Knipschild P. Problems in the conduct of a randomised clinical trial. Journal of Wound Care. 1998:259-62. exclusion reason - background. [pmid: 9677998].
1496 ter Riet G, Kessels AGH, Knipschild P. Vitamin c and ultrasound in the treatment of pressure ulcers. PhD Thesis. 1994. exclusion reason - not relevant.
1497 Terashi H, Sakakibara S, Noguchi M, Matsumoto K, Sugimoto M, Sakurai S, Shibaoka Y, Tahara S. Sugical treatment and perioperative management for pressure ulcers on ischial region. Wound Repair and Regeneration. 2012:A3. exclusion reason - wrong outcome.
1498 Theilla M, Schwartz B, Zimra Y, Shapiro H, Anbar R, Rabizadeh E, Cohen J, Singer P. Enteral n-3 fatty acids and micronutrients enhance percentage of positive neutrophil and lymphocyte adhesion molecules: A potential mediator of pressure ulcer healing in critically ill patients. British Journal of Nutrition. 2011:1-6. exclusion reason - wrong outcome.
1499 Thomas DR, Goode PS, Tarquine PH, Allman RM. Hospital-acquired pressure ulcers and risk of death. Journal of the American Geriatrics Society. 1996:1435-40. exclusion reason - wrong outcome. [pmid: 8951312].
1500 Thomas DR, Rodeheaver GT, Bartolucci AA, Franz RA, Sussman C, Ferrell BA, Cuddigan J, Stotts NA, Maklebust J. Pressure ulcer scale for healing: Derivation and validation of the push tool. The push task force. Advances in Wound Care. 1997:96-101. exclusion reason - background. [pmid: 9362591].
1501 Thomas R. Acoustic pressure wound therapy in the treatment of stage ii pressure ulcers. Ostomy Wound Management. 2008:56-8. exclusion reason - not relevant. [pmid: 19037138].
1502 Thomas S. Alginate dressings in surgery and wound management: Part 2. Journal of Wound Care. 2000:115-9. exclusion reason - Systematic Review, not directly used. [pmid: 11933292].
1503 Thompson P, Anderson J, Langemo D, Hanson D, Hunter S. Support surfaces: Definitions and utilization for patient care. Advances in Skin & Wound Care. 2008:264-266. exclusion reason - background. [pmid: 18525248].
1504 Thornhill-Joynes M, Gonzales F, Stewart CA. Osteomyelitis associated with pressure ulcers. Archives of Physical Medicine and Rehabilitation. 1986:314-318. exclusion reason - wrong outcome. [pmid: 3707316].
1505 Tintle TE, Jeter KF. Early experience with a calcium alginate dressing. Ostomy Wound Management. 1990:74-81. exclusion reason - wrong outcome. [pmid: 2363804].
1506 Tizian C, Brenner P. Coverage of sacral pressure sores by myocutaneous gluteus maximums island flap. Handchirurgie Mikrochirurgie Plastische Chirurgie. 1985:156-160. exclusion reason - not relevant. [pmid: 3891544].
1507 Toba K, Sudoh N, Nagano K, Eto M, Mizuno Y, Nakagawa H, Kawabata Y, Yamami N, Hara M, Fukushima Y, Ouchi Y. randomized prospective trial of gentian violet with dibutyryl camp and povidone-iodine with sugar as treatment for pressure sores infected with methicillin-resistant staphylococcus aureus in elderly patients. Nippon Ronen Igakkai Zasshi - Japanese Journal of Geriatrics. 1997:577-82. exclusion reason - not relevant. [pmid: 9388378].
1508 Toriyabe S. A film-dressing therapy for pressure ulcers at npuap stages lll/lv. 2nd World Union of Wound Healing Societies Meeting. 2004. exclusion reason - no original data.
1509 Torra i Bou JE. treatment of pressure ulcers at home. Multicenter study of a dressing made of a combination of carboxymethyl-cellulose and calcium alginate with hydro-regulatory activity. Revista de Enfermeria. 1995:23-30. exclusion reason - not relevant. [pmid: 8539517].
1510 Torra i Bou JE, Rueda Lopez J, Camanes G, Herrero Narvaez E, Blanco Blanco J, Martinez-Esparza EH, Aneas Alcantara J, Verdu Soriano J. heel pressure ulcers. Comparative study between heel protective bandage and hydrocellular dressing with special form for the heel. Revista de enfermeria (Barcelona, Spain). 2002:50-6. exclusion reason - not relevant.
1511 Torres de Castro OG, Galindo Carlos A, Torra i Bou JE. pure calcium-sodium alginate dressing. Multicenter evaluation of chronic cutaneous lesions. Revista de Enfermeria. 1997:23-30. exclusion reason - not relevant. [pmid: 9385189].
1512 Tymec AC, Pieper B, Vollman K. A comparison of two pressure-relieving devices on the prevention of heel pressure ulcers. Advances in Skin & Wound Care. 1997:39. exclusion reason - wrong population. [pmid: 9204803].
1513 Tzeng Y-S, Yu C-C, Chou T-D, Chen T-M, Chen S-G. Proximal pedicled anterolateral thigh flap for reconstruction of trochanteric defect. Annals of Plastic Surgery. 2008:79-82. exclusion reason - not relevant. [pmid: 18580155].
1514 U.S. Food and Drug Administration. Medical devices; general and plastic surgery devices; classification of non-powered suction apparatus device intended for negative pressure wound therapy. Final rule. Federal Register. 2010/11/26 ed. 2010:70112-4. [pmid: 21090144]. exclusion reason - background.
1515 Ubbink DT, Vermeulen H, Legemate DA. Comment on: Negative pressure wound therapy: A systematic review of effectiveness and safety p. Vikatmaa, v. Juutilainen, p. Kuukasjarvi, a. Malmivaara, eur j vasc endovasc surg 2008; 36(4):438–48. European Journal of Vascular & Endovascular Surgery. 2009:740-1. author reply 741–2. exclusion reason - Systematic Review, not directly used. [pmid: 19328731].
1516 Ubbink DT, Westerbos SJ, Nelson EA, Vermeulen H. A systematic review of topical negative pressure therapy for acute and chronic wounds. British Journal of Surgery. 2008:685-92. exclusion reason - Systematic Review, not directly used. [pmid: 18446777].
1517 Ueda Y, Mizumoto S, Nakagawa Y, Fukui A, Tamai S. Clinical study on the distal vastus lateralis musculocutaneous island flap - a method of elevating this musculocutaneous flap and the clinical results obtained. Japanese Journal of Plastic and Reconstructive Surgery. 1999:543-550. exclusion reason - not relevant.
1518 Ullah N, Alam I. Nutritional care of patients with pressure ulcers: Some evidence based guidelines. Pakistan Journal of Medical Sciences. 2012:196-200. exclusion reason - no original data.
1519 Ulusoy MG, Akan AM, Esoz O, Ozdemir R. Bilateral, extended v-y advancement flap. Annals of Plastic Surgery. 2001:5-8. exclusion reason - not relevant. [pmid: 11192035].
1520 Upton Z, Wallace HJ, Shooter GK, van Lonkhuyzen DR, Yeoh-Ellerton S, Rayment EA, Fleming JM, Broszczak D, Queen D, Sibbald RG, Leavesley DI, Stacey MC. Human pilot studies reveal the potential of a vitronectin: Growth factor complex as a treatment for chronic wounds. International Wound Journal. 2011:522-32. exclusion reason - wrong population. [pmid: 21914133].
1521 USPSTF. U.S. Preventive services task force procedures manual. United States PreventiveServices Task Force. 2008. Section 4: Evidence Report Development. exclusion reason - background.
1522 Valenzuela AR, Perucho NS. the effectiveness of a 0.1% polyhexanide gel. Revista de Enfermeria. 2008:7-12. exclusion reason - not relevant. [pmid: 18564781].
1523 van Anholt RD, Sobotka L, Meijer EP, Heyman H, Groen HW, Topinkova E, van Leen M, Schols JMGA. Specific nutritional support accelerates pressure ulcer healing and reduces wound care intensity in non-malnourished patients. Nutrition. 2010:867-72. exclusion reason - duplicate. [pmid: 20598855].
1524 Van Den BoogaardM, De Laat E, Spauwen P, Schoonhoven L. The effectiveness of topical negative pressure in the treatment of pressure ulcers: A literature review. European Journal of Plastic Surgery. 2008:1-7. exclusion reason - Systematic Review, not directly used.
1525 Van den Plas DL, Lambrecht A, Jacobs D, Liekens J, Van Hoey M. Treatment of recalcitrant wounds of diverse etiology with a new hydoactive gel. Wounds: A Compendium of Clinical Research & Practice. 2009:243-248. exclusion reason - not relevant.
1526 van Leen M. Springer-Verlag. Randomised study on the efficacy of collagenase - containing ointment versus hydrocolloid dressing in wound repair after surgical/enzymatic debridement of necrotic tissue. The Clinical Relevance of Debridement. New York. 1999:71-78. exclusion reason - not relevant.
1527 van Leen M, Hovius S, Neyens J, Halfens R, Schols J. Pressure relief, cold foam or static air? A single center, prospective, controlled randomized clinical trial in a dutch nursing home. Journal of Tissue Viability. 2011:30-4. exclusion reason - wrong intervention. [pmid: 20510611].
1528 Van Leen MWF. Collagenase therapy in decubitus ulcers. TGO - Tijdschrift voor Therapie Geneesmiddel en Onderzoek. 1994:2-7. exclusion reason - not relevant.
1529 Van Rijswijk L, Gray M. Evidence, research, and clinical practice: A patient-centered framework for progress in wound care. Journal of Wound, Ostomy, and Continence Nursing. 2012:1-10. exclusion reason - Scientific Information Packets, not directly used. [pmid: 22124460].
1530 van Twisk R, Borghouts JM. surgical treatment of decubitus ulcers in the area of the ischium, sacrum and trochanter major. Handchirurgie, Mikrochirurgie, Plastische Chirurgie. 1987:277-80. exclusion reason - not relevant. [pmid: 3666597].
1531 Vangilder C, Macfarlane GD, Meyer S. Results of nine international pressure ulcer prevalence surveys: 1989 to 2005. Ostomy Wound Management. 2008:40-54. exclusion reason - background. [pmid: 18382042].
1532 Vannini MA, Carpanelli F, Puglisi C, Biraghi M. Clinical and iconographical assessment of cadexomer iodine efficacy in the treatment of decubitus wounds. Gazzetta Medica Italiana Archivio per le Scienze Mediche. 1993:25-30. exclusion reason - not relevant.
1533 Varea S, Oro C, Bronchales J, Sapena MJ, Poveda C, Maranchon F, Fornes J, Oro JM. occlusive dressings in the management of decubitus ulcers. Revista de Enfermeria. 1988:39-42. exclusion reason - not relevant. [pmid: 3231977].
1534 Vega A. A review of the efficacy of zinc, selenium, and vitamin c in the treatment of pressure ulcers. Topics in Clinical Nutrition. 2011:115-125. exclusion reason - Systematic Review, not directly used.
1535 Veit N, Bailey BL, Swoager L. Clinical evaluation of dermagran spray and ointment in the treatment of pressure ulcers in spinal cord injury. Sci Nursing. 1993:135-6. exclusion reason - not relevant. [pmid: 7863307].
1536 Venezia L, Velardo F, Tisci RA, Baldassarre G, Forino V, Aloia V, Biraghi M. Efficacy and tolerability of cadexomer iodine ointment in the treatment of decubitus ulcers. Results of an open study performed in elderly patients. Gazzetta Medica Italiana Archivio per le Scienze Mediche. 1990:213-219. exclusion reason - not relevant.
1537 Venkataramakrishnan V, Mohan D, Krishna A, Chowdhary S. The longest pedicle for a gastrocnemius flap!. Annals of Plastic Surgery. 1997:106-8. exclusion reason - not relevant. [pmid: 9229107].
1538 Verdote-Robertson R, Munchua MM, Reddon JR. The use of low intensity laser therapy (lilt) for the treatment of open wounds in psychogeriatric patients: A pilot study. Physical & Occupational Therapy in Geriatrics. 2000:1-19. exclusion reason - wrong population.
1539 Verdu SorianoJ, Nolasco Bonmati A, Lopez Casanova P, Torra i Bou J-E. auriga-04 study on the use of a range of allevyn hydro-cellular dressings in the treatment of bed sores and leg ulcers by primary health care professionals. Revista de Enfermeria. 2006:43-9. exclusion reason - not relevant. [pmid: 16724499].
1540 Viau F, Mangenot D, Boval C, Perron J. Crystallized sugar for the treatment of wounds, pressure sores and leg ulcers. Semaine des Hopitaux. 1986:2431-2435. exclusion reason - not relevant.
1541 Vig S, Dowsett C, Berg L, Caravaggi C, Rome P, Birke-Sorensen H, Bruhin A, Chariker M, Depoorter M, Dunn R, Duteille F, Ferreira F, Francos Martinez JM, Grudzien G, Hudson D, Ichioka S, Ingemansson R, Jeffery S, Krug E, Lee C, Malmsjo M, Runkel N, Martin R, Smith J. Evidence-based recommendations for the use of negative pressure wound therapy in chronic wounds: Steps towards an international consensus. Journal of tissue viability. 2011:S1-S18. exclusion reason - Systematic Review, not directly used. [pmid: 22119531].
1542 Vigil-Escalera Quintanal LJ. Treatment of heel pressure sores. Clinical performance of a new adhesive dressing. [spanish]. Metas de Enfermería. 2003:19-26. exclusion reason - not relevant.
1543 Vikatmaa P, Juutilainen V, Kuukasjarvi P, Malmivaara A. Negative pressure wound therapy: A systematic review on effectiveness and safety. European Journal of Vascular & Endovascular Surgery. 2008:438-48. exclusion reason - Systematic Review, not directly used. [pmid: 18675559].
1544 Vink L, Blok CS, Scheper RJ, Van Montfrans C, De Boer EM, Gibbs S. Retrospective analysis of patients with ulcers of (arterio-)venous, traumatic or decubitus origin treated with autologous skin substitute. Wound Repair and Regeneration. 2011:A96. exclusion reason - wrong population.
1545 Vlastou C. Alternatives in soft tissue reconstruction of the ankle and foot. Acta Orthopaedica Scandinavica. Supplementum. 1995:27-30. exclusion reason - not relevant. [pmid: 7604725].
1546 Vodovnik L, Stefanovska A, Turk R. [611] therapeutic intervention for healing pressure sores with electrical stimulation on persons with spinal discontinuities. Journal of Rehabilitation Research and Development. 1991:479. exclusion reason - wrong intervention.
1547 Vogelpohl T. Description and critique of the guidelines for pressure ulcers. Decubitus. 1991:32-4. exclusion reason - background. [pmid: 2036166].
1548 Voigt DW, Paul CN. The use of acticoat as silver impregnated telfa dressings in a regional burn and wound care center: The clinicians view. Wounds: A Compendium of Clinical Research & Practice. 2001:11-22. exclusion reason - wrong population.
1549 Voigt H, Kleeberg UR, Naquin R. Pathogenesis, prevention, and therapy for decubitus in cancer patients. Medizinische Klinik. 1987:191-195. exclusion reason - not relevant. [pmid: 3587161].
1550 Volker HU. Decubitus ulcers. Pressure relief is of the essence. MMW-Fortschritte der Medizin. 1999:30-33. exclusion reason - background. [pmid: 10795164].
1551 Vu T, Harris A, Duncan G, Sussman G. Cost-effectiveness of multidisciplinary wound care in nursing homes: A pseudo-randomized pragmatic cluster trial. Family Practice. 2007:372-9. exclusion reason - not relevant. [pmid: 17602174].
1552 Vuerstaek JDD, Vainas T, Wuite J, Nelemans P, Neumann MHA, Veraart JCJM. State-of-the-art treatment of chronic leg ulcers: A randomized controlled trial comparing vacuum-assisted closure (v.A.C.) with modern wound dressings. Journal of Vascular Surgery. 2006:1029-1037. exclusion reason - wrong population. [pmid: 17000077].
1553 Vyhlidal SK, Moxness D, Bosak KS, Van Meter FG, Bergstrom N. Mattress replacement or foam overlay? A prospective study on the incidence of pressure ulcers. Applied Nursing Research. 1997:111-120. exclusion reason - wrong population. [pmid: 9274063].
1554 Wahrburg U. Nutrition and decubital ulcers. Tägliche Praxis. 2004:381. exclusion reason - not relevant.
1555 Walding M. Wound care. Skin treatment. Nursing Times. 1994:78-82. exclusion reason - no original data. [pmid: 8127765].
1556 Walker A. The cost-effectiveness of home health: A case presentation. Geriatric Nursing. 1996:37-40. exclusion reason - not relevant. [pmid: 8707142].
1557 Walker P. Management of pressure ulcers. Oncology (Williston Park). 2001:1499-508. 1511. discussion 1511, 1515–6. exclusion reason - background. [pmid: 11758876].
1558 Wallenstein SM, Carasa N, Kapil-Pair EPCM, Zoller J, Hollier L, Brem H. Defining the rate of healing of pressure ulcers (poster presentation). EPUAP. Budapest, Hungary. 2002. exclusion reason - not relevant.
1559 Wallin A-M, Bostrom L, Ulfvarson J, Ottosson C. Negative pressure wound therapy - a descriptive study. Ostomy Wound Management. 2011:22-9. exclusion reason - wrong outcome. [pmid: 21701045].
1560 Walsh NS, Blanck AW, Barrett KL. Pressure ulcer management in the acute care setting: A response to regulatory mandates. Journal of Wound, Ostomy, & Continence Nursing. 2009:385-8. exclusion reason - wrong intervention. [pmid: 19609158].
1561 Wang C-H, Chen S-Y, Fu J-P, Dai N-T, Chen S-L, Chen T-M, Chen S-G. Reconstruction of trochanteric pressure sores with pedicled anterolateral thigh myocutaneous flaps. Journal of Plastic, Reconstructive & Aesthetic Surgery: JPRAS. 2011:671-6. exclusion reason - not relevant. [pmid: 20884307].
1562 Wang Z, Ren J, Song J. Clinical and experimental study on the use of chuangling solution to treat the ulcer. [chinese]. Shanxi Nursing Journal. 1997:200-203. exclusion reason - not relevant.
1563 Warbanow K, Krause-Bergmann A, Brenner P, Reichert B, Berger A. myocutaneous flap as reliable defect coverage in high grade pelvic decubitus ulcers. Classification, therapeutic concept and presentation of personal patient sample of 16 years. Langenbecks Archiv fur Chirurgie. 1997:359-66. exclusion reason - not relevant. [pmid: 9498209].
1564 Ward C. The value of systematic evaluation in determining the effectiveness and practical utility of a pressure-redistributing support surface. Journal of Tissue Viability. 2010:22-7. exclusion reason - wrong intervention. [pmid: 20106665].
1565 Warnet S, Bandelier L. prevention and management of decubitus ulcers. Revue de L’Infirmiere. 2007:24-5. exclusion reason - not relevant. [pmid: 17566501].
1566 Warren S, Neto M, Hermans MHE. Better pressure relief and a reduction of the environmental impact of mattress technology. exclusion reason - Scientific Information Packets, not directly used.
1567 Warren S, Neto M, Hermans MHE. A reduction in the environmental impact of mattress production. exclusion reason - Scientific Information Packets, not directly used.
1568 Warren S, Neto M, Hermans MHE. Reduction of average and peak pressures with a hybrid gel/smt support surface: Pressure mapping results in volunteers. exclusion reason - Scientific Information Packets, not directly used.
1569 Waterlow J. Wound care. Recording risk factors. Nursing Times. 1995:64-6. exclusion reason - no original data. [pmid: 7716024].
1570 Waterlow J. From costly treatment to cost-effective prevention: Using waterlow. British Journal of Community Nursing. 2005:S25-6. S28. S30. exclusion reason - not relevant. [pmid: 16245392].
1571 Watier E, Chevrier S, Georgieu N, Pardo A, Schuck S, Pailheret JP. Our experience with ischial pressure sores in a series of 34 patients. European Journal of Plastic Surgery. 2000:32-35. exclusion reason - background.
1572 Watkoskey C. Pressure ulcers: Collaboration in wound care. Is there a reasonable approach?. Ostomy Wound Management. 1997:6. exclusion reason - no original data. [pmid: 9282042].
1573 Watret L. Not easily used by all. Nursing Times. 1994:25. exclusion reason - no original data. [pmid: 8058508].
1574 Watson R. Sore point. Geriatric Nursing & Home Care. 1989:26-7. exclusion reason - no original data. [pmid: 2721956].
1575 Watson R. Pressure sores: A rational approach to treatment. Nursing Standard. 1989:22-5. exclusion reason - not relevant. [pmid: 2503730].
1576 Watson R. The benefits of excellence. A cost-effective treatment programme for pressure sores. Professional Nurse. 1990:356-62. exclusion reason - not relevant. [pmid: 2111550].
1577 Webb M. Selection of a cost-effective debriding alternative to a pharmaceutical enzymatic agent at one county long-term care facility. 41st annual wound, ostomy and continence nurses annual conference. st. Louis, missouri. june 6–10, 2009. Journal of Wound, Ostomy & Continence Nursing. 2009:S17-8. exclusion reason - not relevant.
1578 Webster RM. Pressure ulcers. [5]. Journal of the American Medical Directors Association. 2002:210-211. exclusion reason - background.
1579 Wechselberger G, Schoeller T, Otto A. Principles in the operative treatment of pressure sores. Archives of Surgery. 1998:465. exclusion reason - background. [pmid: 9565131].
1580 Wechselberger G, Schoeller T, Schwabegger A, Ninkovic M, Papp C, Anderl H. plastic surgery treatment of extensive decubitus ulcers of the pelvic area. Chirurg. 1996:1147-51. exclusion reason - not relevant. [pmid: 9035951].
1581 Weeks SK. Save our skin (sos). Rehabilitation Nursing. 1996:267-8. exclusion reason - no original data. [pmid: 8868759].
1582 Weheida SM, Nagubib HH, El-Banna HM, Marzouk S. Comparing the effects of two dressing techniques on healing of low grade pressure ulcers. Journal of the Medical Research Institute. 1991:259-78. exclusion reason - wrong population.
1583 Weiler PG, Franzi C, Kecskes D. Pressure sores in nursing home patients. Aging-Clinical & Experimental Research. 1990:267-75. exclusion reason - background. [pmid: 2094365].
1584 Welber A. The pressure is on!. Med-Surg Matters. 2005:3-4. exclusion reason - background.
1585 Wells JA, Karr D. Interface pressure, wound healing, and satisfaction in the evaluation of a non-powered fluid mattress. Ostomy Wound Management. 1998:38-42. 44. 6. 48 passim. exclusion reason - wrong population. [pmid: 9526420].
1586 Welton JM. Implications of medicare reimbursement changes related to inpatient nursing care quality. Journal of Nursing Administration. 2008:325-30. exclusion reason - not relevant. [pmid: 18690122].
1587 Werdin F, Tennenhaus M, Schaller H-E, Rennekampff H-O. Evidence-based management strategies for treatment of chronic wounds. Eplasty [Electronic Resource]. 2009:e19. exclusion reason - background. [pmid: 19578487].
1588 Werner GT, Gadomski M, Wehle F. Immersion into co2-water in the treatment of chronic ulcers with delayed healing. Zeitschrift fur Physikalische Medizin Balneologie Med Klimatologie. 1990:52-56. exclusion reason - not relevant.
1589 West BJ, Brockman SJ, Scott A. Action research and standards of care. The prevention and treatment of pressure sores in elderly patients. Health Bulletin. 1991:356-61. exclusion reason - background. [pmid: 1765486].
1590 Westerhof W, Jansen FC, de Wit FS, Cormane RH. Controlled double-blind trial of fibrinolysin-desoxyribonuclease (elase) solution in patients with chronic leg ulcers who are treated before autologous skin grafting. Journal of the American Academy of Dermatology. 1987:32-39. exclusion reason - wrong population. [pmid: 2956297].
1591 Weum S, De Weerd L. The butterfly design as an alternative to the “double-a” bilateral flaps for the treatment of large sacral defects. Plastic and Reconstructive Surgery. 2008:1513-1514. exclusion reason - no original data. [pmid: 18349687].
1592 White-Chu EF, Flock P, Struck B, Aronson L. Pressure ulcers in long-term care. Clinics in Geriatric Medicine. 2011:241-58. exclusion reason - background. [pmid: 21641509].
1593 Whitehead SJ, Trueman P. To what extent can pressure relieving surfaces help reduce the costs of pressure ulcers?. Nursing Times. 2010:10-2. exclusion reason - not relevant. [pmid: 20836473].
1594 Whitney J, Higa L, Savadalena G, Mich M. Effect of radiant heat treatment on pressure ulcer healing: Preliminary findings. 31st Annual Wound, Ostomy and Continence Conference. 1999. exclusion reason - not relevant.
1595 Whitney J, Phillips L, Aslam R, Barbul A, Gottrup F, Gould L, Robson MC, Rodeheaver G, Thomas D, Stotts N. Guidelines for the treatment of pressure ulcers. Wound Repair & Regeneration. 2006:663-79. exclusion reason - background. [pmid: 17199832].
1596 Whittemore R. Pressure-reduction support surfaces: A review of the literature. Journal of Wound, Ostomy, & Continence Nursing. 1998:6-25. exclusion reason - Systematic Review, not directly used. [pmid: 9481284].
1597 WHO. Uv raditation. World Health Organization. 2012. exclusion reason - background.
1598 Wiechula R, Paillaud E, Herbaud S, Caillet P, Lejonc JL, Campillo B, Bories PN, Hutchinson JJ, McGuckin M. The use of moist wound-healing dressings in the management of split-thickness skin graft donor sites: A systematic review relations between undernutrition and nosocomial infections in elderly patients occlusive dressings: A microbiologic and clinical review. International Journal of Nursing Practice. 2003:S9-17. exclusion reason - wrong population. [pmid: 12694482].
1599 Wikipedia. Laser. Wikipedia: Wikipedia. 2012. exclusion reason - background.
1600 Wild T, Stremitzer S, Budzanowski A, Hoelzenbein T, Ludwig C, Ohrenberger G. Definition of efficiency in vacuum therapy--a randomised controlled trial comparing with v. A.C. Therapy. International Wound Journal. 2008:641-7. exclusion reason - no original data. [pmid: 19134065].
1601 Wilk A. decubitus ulcer. Revue du Praticien. 1994:1769-75. exclusion reason - background. [pmid: 7939261].
1602 Wilk A, Rodier C, Beau C, Stricher F, Lesage F, Lecocq J, Wilhelm B, Bougrelle J. sacral bedsore: An evaluation of 10 years’ treatment with the gluteus maximus muscle. Annales de Chirurgie Plastique et Esthetique. 1991:132-137. exclusion reason - not relevant. [pmid: 1718202].
1603 Wilm S, Geisler D. Care for patients with decubitus by general practitioners in germany. Zeitschrift fur Allgemeinmedizin. 1999:257-264. exclusion reason - background.
1604 Wilson D. Silver polymeric membrane dressings promote healing of multiple small stalled pressure ulcers. 39th annual wound, ostomy and continence nurses annual conference. Journal of Wound, Ostomy & Continence Nursing. 2007:S13-S13. exclusion reason - wrong population.
1605 Wilson G, Logan H. The role of education, technique and equipment in pressure area care. British Journal of Nursing. 2005:990-4. exclusion reason - background. [pmid: 16237357].
1606 Wind S, Happ E, Kerstein MD. Pressure ulcers: Collaboration in wound care Is there a reasonable approach?. Ostomy Wound Management. 1997:40-4. 46. 48–50 passim. exclusion reason - background. [pmid: 9205397].
1607 Winter E, Muller JE, Bilow H, Eggstein A, Hontzsch D, Weller S. indications, technique and results of muscle flaps in decubitus ulcers of the pelvic region in paraplegic patients. Aktuelle Traumatologie. 1994:222-7. exclusion reason - not relevant. [pmid: 7801819].
1608 Wiseman LA. Sugar as an aid to wound healing and the treatment of ulcers in leprosy. Leprosy Review. 1989:67-8. exclusion reason - not relevant. [pmid: 2634986].
1609 Wisniewska-Wrona M, Kucharska M, Niekraszewicz A, Kardas I, Ciechaniska D, Bodek KH. chitosan-alginate biocomposites in the form of films used in bedsores treatment. Polimery W Medycynie. 2010:57-64. exclusion reason - not relevant. [pmid: 20649090].
1610 Witkowski JA, Parish LC. Topical metronidazole gel. The bacteriology of decubitus ulcers. International Journal of Dermatology. 1991:660-1. exclusion reason - wrong intervention. [pmid: 1938084].
1611 Witkowski JA, Parish LC. The decubitus ulcer: Skin failure and destructive behavior. International Journal of Dermatology. 2000:894-6. exclusion reason - background. [pmid: 11168655].
1612 Witkowski W, Baranski M, Broma A, Olszowska-Golec M. the operative management of sacral pressure sores with a bilateral modificated myocutaneous v-y plasty. Polski Merkuriusz Lekarski. 2005:192-5. exclusion reason - not relevant. [pmid: 17877129].
1613 Witkowski W, Jawien A, Witkiewicz W, Zon B. Initial multi-centre observations upon the effect of a new topical negative pressure device upon patient and clinician experience and the treatment of wounds. International Wound Journal. 2009:167-74. exclusion reason - wrong population. [pmid: 19432667].
1614 Wollina U. lower leg ulcers and decubitus ulcer. Optimal wound management improves relative quality of life. MMW Fortschritte der Medizin. 1999:50-2. 54. exclusion reason - background. [pmid: 10904642].
1615 Wong C-H, Tan B-K, Song C. The perforator-sparing buttock rotation flap for coverage of pressure sores. Plastic & Reconstructive Surgery. 2007:1259-66. exclusion reason - not relevant. [pmid: 17496599].
1616 Wong TC, Ip FK. Comparison of gluteal fasciocutaneous rotational flaps and myocutaneous flaps for the treatment of sacral sores. International Orthopaedics. 2006:64-7. exclusion reason - not relevant. [pmid: 16333656].
1617 Wong V. Skin blood flow response to 2-hour repositioning in long-term care residents: A pilot study. Journal of Wound, Ostomy, & Continence Nursing. 2011:529-37. exclusion reason - wrong population. [pmid: 21860333].
1618 Wong VK, Stotts NA, Hopf HW, Froelicher ES, Dowling GA. How heel oxygenation changes under pressure. Wound Repair and Regeneration. 2007:786-794. exclusion reason - background. [pmid: 18028125].
1619 Woo KY, Sibbald RG. Topical treatment of pain in pressure ulcers: A systematic review. 41st annual wound, ostomy and continence nurses annual conference. st. Louis, missouri. june 6–10, 2009. Journal of Wound, Ostomy & Continence Nursing. 2009:S58-S58. exclusion reason - Systematic Review, not directly used.
1620 Woo KY, Sibbald RG, Ayello EA. Wound edge effect. Ostomy Wound Management. 2009:21-22. exclusion reason - background.
1621 Wood JM, Jacobson WF, Schallreuter KU, Evans P, Jacobson M, Suffer R, Newman J, White C. Pulsed low-intensity direct current (plidc) is effective in healing chronic decubitus ulcers in stages ii and iii. Abstract 136. Journal of Investigative Dermatology. 1992:574. exclusion reason - not relevant.
1622 Woolsey RM, McGarry JD. The cause, prevention, and treatment of pressure sores. Neurologic Clinics. 1991:797-808. exclusion reason - background. [pmid: 1921959].
1623 Worsley M. Comparing efficacies... Treatment of leg ulcers and pressure sores. Nursing Standard. 1991:5-6. exclusion reason - no original data.
1624 Wright RD, O’Brien C. Technological advances in wound care. DNA Reporter. 1999:18-20. exclusion reason - no original data.
1625 Wu FX. repair of bedsores and ulcers with gluteus maximus musculocutaneous flap. Chung-Hua Cheng Hsing Shao Shang Wai Ko Tsa Chih - Chinese Journal of Plastic Surgery & Burns. 1992:293-4. 330. exclusion reason - not relevant. [pmid: 1304963].
1626 Wu JX. axial skin flap and musculocutaneous flap in the treatment of bedsores--report of 8 cases. Chung-Hua Cheng Hsing Shao Shang Wai Ko Tsa Chih - Chinese Journal of Plastic Surgery & Burns. 1988:112-3. 158. exclusion reason - not relevant. [pmid: 3151451].
1627 Wyndaele JJ. Medical honey for chronic pressure ulcers in sci individuals. Spinal Cord. 2012:87. exclusion reason - no original data.
1628 Xie X, McGregor M, Dendukuri N. The clinical effectiveness of negative pressure wound therapy: A systematic review. Journal of Wound Care. 2010:490-5. exclusion reason - background. [pmid: 21135797].
1629 Xin SF. guangzhou yuchuangjia in the treatment of bedsore. Chung-Hua Hu Li Tsa Chih Chinese Journal of Nursing. 1993:714-6. exclusion reason - not relevant. [pmid: 8156610].
1630 Xu XW, Qing Y, Li ZY, Cen Y. Treatment of sacrococcygeal decubitus ulcers by two period operations of myocutaneous flap transposition: Reports of 19 cases. Journal of Clinical Rehabilitative Tissue Engineering Research. 2008:364-367. exclusion reason - not relevant.
1631 Xu Y, Hai H, Liang Z, Feng S, Wang C. Pedicled fasciocutaneous flap of multi-island design for large sacral defects. Clinical Orthopaedics & Related Research. 2009:2135-41. exclusion reason - not relevant. [pmid: 19048353].
1632 Xu Y, Liang Z, Feng S. an effect of multi-island flap with shallow branch of gluteus upper artery on repair of sacrum soft tissue defect. Chung-Kuo Hsiu Fu Chung Chien Wai Ko Tsa Chih/Chinese Journal of Reparative & Reconstructive Surgery. 2007:850-3. exclusion reason - not relevant. [pmid: 17882883].
1633 Yamamoto Y, Oyama A, Tsutsumida A, Murazumi M, Honda K, Sugihara T. Reconstructive surgery with the fasciocutaneous flap for the treatment of pressure sores. Japanese Journal of Plastic and Reconstructive Surgery. 1998:1113-1119. exclusion reason - not relevant.
1634 Yamashita R, Kuroyanagi Y, Nakakita N, Uchinuma E, Shioya N. Allogeneic cultured dermal substitute composed of spongy collagen containing fibroblasts: Preliminary clinical trials. Wounds: A Compendium of Clinical Research & Practice. 1999:34-44. exclusion reason - not relevant.
1635 Yamashita R, Uchinuma E, Kuroyanagi Y. Treatment of skin ulcers and pressure sores using allogeneic cultured dermal substitute composed of fibroblasts combined within spongy collagen matrix. Japanese Journal of Plastic and Reconstructive Surgery. 1998:917-923. exclusion reason - not relevant. [pmid: 10450570].
1636 Yan C-L, Liu Q-J, Yang P, Fu A-J, Zhu J, Wang H-H. clinical research on bedsores treated with fire needle therapy. Zhongguo Zhenjiu. 2010:819-21. exclusion reason - not relevant. [pmid: 21058478].
1637 Yanai A, Kosaka Y, Teraoka A, Papp C. Several types of gluteus maximus musculocutaneous flaps for closure of sacral decubitus ulcer - refinements in design. European Journal of Plastic Surgery. 1991:157-163. exclusion reason - not relevant.
1638 Yang C-H, Kuo Y-R, Jeng S-F, Lin P-Y. An ideal method for pressure sore reconstruction: A freestyle perforator-based flap. Annals of Plastic Surgery. 2011:179-84. exclusion reason - not relevant. [pmid: 21200313].
1639 Yelken B, Ay A. Comparison of hydropolymer dressing and hydrocolloid dressing in management of pressure ulcers. 19th Annual Congress of the European Society of Intensive Care Medicine. Barcelona (Spain). Springer. 2006. exclusion reason - no original data.
1640 Zelenkova H. Enzymatic debridement in dermatology. Cesko-Slovenska Dermatologie. 2000:18-21. exclusion reason - not relevant.
1641 Zeleznik J. Review: Specially designed products to prevent or heal pressure ulcers are more effective than standard mattresses. Commentary on cullum n, deeks j, sheldon ta, song f, fletcher aw. Beds, mattresses and cushions for pressure sore prevention and treatment Cochrane review, latest version 26 may 1999. The cochrane library. Oxford. Update software ACP Journal Club. 2000:59-59. exclusion reason - not relevant.
1642 Zeppetella G, Paul J, Ribeiro MDC. Analgesic efficacy of morphine applied topically to painful ulcers. Journal of Pain and Symptom Management. 2003:555-558. exclusion reason - wrong population. [pmid: 12782436].
1643 Zhang J. Clinical effects f moist burn adhesive plaster on bed sore. Chinese Journal of Clinical Rehabilitation. 2003:345. exclusion reason - not relevant.
1644 Zhang QH, Sun ZR, Yue JH, Ren X, Qiu LB, Lv XL, Du W. Traditional chinese medicine for pressure ulcer: A meta-analysis. International Wound Journal. 2012. [pmid: 22512889]. exclusion reason - background.
1645 Zhao J. Application of iodophor for nursing care of patients with pressure sore. [chinese]. Chinese Nursing Research. 2009:1090-1090. exclusion reason - not relevant.
1646 Zhou DP, Lu LQ, Mao XL. insulin and hyperosmotic glucose solution external used for treating pressure sore. Bulletin of Hunan Medical University. 2001:475-6. exclusion reason - not relevant. [pmid: 12536508].
1647 Zhou G, Qiao Q, Chen GY, Ling YC, Swift R. Clinical experience and surgical anatomy of 32 free anterolateral thigh flap transplantations. British Journal of Plastic Surgery. 1991:91-6. exclusion reason - not relevant. [pmid: 2018912].
1648 Zhou Sh JXY. Observation of the effects of physical therapy in the treatment of decubitus ulcer. Stroke and Nervous Diseases. 1996:156-7. exclusion reason - unable to find.
1649 Ziegler UE, Schmidt K, Keller HP, Thiede A. treatment of chronic wounds with an alginate dressing containing calcium zinc and manganese. Fortschritte der Medizin. Originalien: Erganzungsband ... der MMW, Fortschritte der Medizin. 2003:19-26. exclusion reason - not relevant. [pmid: 15117065].
1650 Zogovska E, Novevski L, Agai L, Mircevski V, Peev I, Dzokic G. Our experience in treatment of pressure ulcers by using local cutaneous flaps. Makedonska Akademija na Naukite i Umetnostite Oddelenie Za Bioloshki i Meditsinski Nauki Prilozi. 2008:199-210. exclusion reason - not relevant. [pmid: 18709010].
1651 Zolghadrasli AA. Ciclosporin for pressure ulcers. Journal of Wound Care. 2008:208. exclusion reason - no original data. [pmid: 18546994].
1652 Zuccarelli GC, Berna D, Tammaro AE. Collagenase in the treatment of decubitus ulcers in elderly high-risk patients. Giornale di Gerontologia. 1990:237-241. exclusion reason - not relevant.
1653 Zuloff-Shani A, Kachel E, Frenkel O, Orenstein A, Shinar E, Danon D. Macrophage suspensions prepared from a blood unit for treatment of refractory human ulcers. Transfusion & Apheresis Science. 2004:163-7. exclusion reason - wrong population. [pmid: 15062757].
1654 Zur Nieden HC, Pullen R, Fusgen I. Treatment of decubital ulcers in geriatric patients with ornithine- oxoglutarate - a randomized, double-blind pilot study. European Journal of Geriatrics. 1999:144-147. exclusion reason - not relevant.