# Stages of Pressure Ulcers

Table C-1 Stages of pressure ulcer equivalency

NPUAP Stage | Description | Yarkony-Kirk | Description | Shea | Description | DeLisa, Mikulic | Description | Torrance | Description
I | Intact skin with non-blanchable redness of a localized area usually over a bony prominence. Darkly pigmented skin may not have visible blanching; its color may differ from the surrounding area. | I | Red area:; a. Present longer that 30 minutes, but less than 24 hours; b. Present longer than 24 hours | NA | No Equivalent | I | Pressure sore is an acute inflammatory response involving the epidermis An irregular, ill-defined area if soft-tissue erythema accompanies by in duration and heat persists for more than 24 hours. The epidermis remains intact, and the ulcer is reversible. | I | Persistent erythema of the skin
II | Partial thickness loss of dermis presenting as a shallow open ulcer with a red pink wound bed, without slough. May also present as an intact or open/ruptured serum-filled blister | II | Epidermis and/or dermis ulcerated with no subcutaneous fat observed | I | Limited to epidermis exposing dermis | II | Pressure sore is a break in or blistering of the epidermis surrounded by erythema and in duration. Potentially, it also is reversible. | II | Blister formation or superficial subcutaneous ulcer
III | Full thickness tissue loss. Subcutaneous fat may be visible but bone, tendon or muscles are not exposed. Slough may be present but does not obscure the depth of tissue loss. May include undermining and tunneling. | III | Subcutaneous fat observed, no muscle observed | II, III | Full-thickness of dermis to junction of subcutaneous fat Fat obliterated, limited by deep fascia undermining of skin | III | Pressure ulcer is an inflammatory fibroblastic response extending through the dermis to the junction with subcutaneous fat. Clinically presents as an irregular, shallow ulcer that has subcutaneous fat at its base and is surrounded by erythema, induration, and heat. | III | Deep subcutaneous ulcer-ulceration progress through the dermis
IV | Full thickness tissue loss with exposed bone, tendon or muscle. Slough or eschar may be present on some parts of the wound bed. Often include undermining and tunneling. | IV–V | Muscle/fascia observed, but no bone observed Bone observed, but no involvement of joint space | IV | Bone at the base of ulceration | IV – muscle | Pressure ulcer extents through the full thickness of skin into the deep fascia and/or muscle. Its draining, necrotic base is often foul-smelling, and under-mining of the surface tissues may be excessive. | IV
IV | Full thickness tissue loss with exposed bone, tendon or muscle. Slough or eschar may be present on some parts of the wound bed. Often include undermining and tunneling. | IV–V | Muscle/fascia observed, but no bone observed Bone observed, but no involvement of joint space | IV | Bone at the base of ulceration | V – exposed bone | Pressure ulcer penetrates the underlying bone, causing osteomyelitis. It has no anatomic limit and is surrounded by erythema and induration. Clinically, it presents as an extensive ulcer with exposed bone, joint, muscle, and/or fascia at its base. | IV
| | VI | Involvement of joint space | V | Closed large cavity through a small sinus | | | V
Suspected Deep Tissue Injury | Purple or maroon localized area of discolored intact skin or blood-filled blister due to damage of underlying soft tissue from pressure and/or shear. The area may be preceded by tissue found to be painful, firm, mushy, boggy, warmer or cooler as compared to adjacent tissue.
Unstageable | Full thickness tissue loss in which the base of the ulcer is covered by slough (yellow, tan, gray, green, or brown) and/or eschar (tan, brown, or black) in the wound bed.