# Inclusion Criteria by PICOTS and Key Question

Table B-1 Pressure ulcer treatment inclusion criteria by PICOTS and Key Question

| Inclusion Criteria | Exclusion Criteria
Populations | Adults aged 18 years and older being treated for existing decubitus ulcers. Subgroups include: sex, race/ethnicity, socioeconomic status, and diverse specific medical comorbidities (e.g., diabetes, end-stage renal disease, dementia), and patients with specific known risk factors for pressure ulcers (e.g., nutritional status, incontinence, peripheral vascular disease, mobility limitations, functional ability). | Wrong population. Children, adolescents, and patients with non pressure-related ulcers, including but not limited to venous ulcers and diabetic foot ulcers, because treatment considerations for these patients may differ significantly from those for pressure ulcers.
Interventions | Treatment for pressure ulcers including but not limited to: support surfaces, nutritional supplementation, wound debridement and cleansing, wound dressings, biologic agents, and surgical repair. Adjunctive therapies including ultrasound, electrical stimulation, vacuum-assisted closure, and hyperbaric oxygen therapy.; - For efficacy and effectiveness assessments, all studies of interventions for treatment of pressure ulcers meeting the requirements of the PICOTS and Key Questions were included. | Wrong intervention. Studies of interventions without comparators were excluded but included in KQ2 to evaluate harms.
Comparisons | Usual care, placebo, no treatment, different treatment interventions | Studies with no comparator (included for harms only)
Outcomes | Clinical outcomes:; - Complete wound healing; - wound surface area reduction; - pain; - prevention of sepsis,; - prevention of osteomyelitis,; - recurrence rate and harms of treatment care settings, (including but not limited to nurse/patient staffing ratio, staff education and training in wound care, the use of wound care teams, and home caregiver support and training) | Non-clinical outcomes, cost, comfort, and nursing time.
Settings | Patient-care settings, such as home, nursing facility, or hospitals. | Hospice care facilities.
Timing | No minimum follow up time was required. | Studies published prior to 1985.
Study designs | Randomized and non randomized trials, retrospective and prospective cohort studies, case-control studies, and multicenter intervention series with a population of 100 patients or more. | Single case reports, intervention series with sample sizes less than 100 patients conducted at single sites, articles with no original data; review articles, letter, and editorials. Systematic reviews used for background only.
Treatment Key Questions
Population Interventions Comparators Outcomes Timing Settings | KQ1:1. In adults with pressure ulcers, what is the comparative effectiveness of treatment strategies for improved health outcomes including but not limited to: complete wound healing, healing time, reduced wound surface area, pain, and prevention of serious complications of infection?; - For efficacy and effectiveness assessments, all studies of interventions for treatment of pressure ulcers meeting the requirements of the PICOTS and Key Questions were included.; - No minimum followup time was required. | Wrong population. Wrong interventions. Studies without a comparator or studies that reported outcomes only as an adverse event were excluded, but used in the assessment of harms. Wrong outcomes. Hospice care facilities.
Population/patient, ulcer characteristics | 1a. Does the comparative effectiveness of treatment strategies differ according to features of the pressure ulcers, such as anatomic site or severity at baseline? | None.
Population/ patient, characteristics | 1b. Does the comparative effectiveness of treatment strategies differ according to patient characteristics, including but not limited to: age; race/ethnicity; body weight; specific medical comorbidities; and known risk factors for pressure ulcers, such as functional ability, nutritional status, or incontinence? | Wrong population.
Settings | 1c. Does the comparative effectiveness of treatment strategies differ according to patient care settings such as home, nursing facility, or hospital, or according to features of patient care settings, including but not limited to nurse/patient staffing ratio, staff education and training in wound care, the use of wound care teams, and home caregiver support and training? | Hospice care facilities.
Harms Key Questions
Population Interventions Comparators Outcomes Timing Settings | KQ 2. What are the harms of treatments for pressure ulcers? | Wrong population. Wrong intervention. Hospice care facilities.
Population/Patient, ulcer characteristics | 2a. Do the harms of treatment strategies differ according to features of the pressure ulcers, such as anatomic site or severity at baseline? | Wrong population.
Population/ patient, characteristics | 2b. Do the harms of treatment strategies differ according to patient characteristics, including: age, race/ethnicity; body weight; specific medical comorbidities; and knows risk factors for pressure ulcers, such as functional ability, nutritional status, or incontinence? | Wrong population.
Settings | 2c. Do the harms of treatment strategies differ according to patient care settings such as home, nursing facility, or hospital, or according to features of patient care settings, including but not limited to nurse/patient staffing ratio, staff education and training in wound care, the use of wound care teams, and home caregiver support and training? | Hospice care facilities.