# Exact Search Strategy

The following databases have been searched for relevant information:

Search strategies are presented for the original searches. An updated search was conducted on June 5^th^, 2012.

## Medline

Searched: Ovid MEDLINE(R) and Ovid OLDMEDLINE(R) 1946 to August Week 5 2011

Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations September 12, 2011

Date Searched: September 14, 2011

Updated Searches: June 5^th^, 2012 and October 17^th^, 2012

1 | Pressure Ulcer/dh, dt, nu, rt, rh, su, th, ae, co, in, mo, po, to | 4917
2 | pressure ulcer/ and (treatment or healing or management or therapy).hw. | 1818
3 | ((pressure ulcer$ or pressure sore$ or bed sore$ or bedsore$ or decubitus ulcer$) adj5 (treat$ or heal$ or manag$ or therap$)).ti,ab. | 2244
4 | 1 or 2 or 3 | 6047
5 | limit 4 to yr=“1985 -Current” | 4876
6 | remove duplicates from 5 | 4668

## EMBASE

Searched: Embase (Elsevier)

Date Searched: September 14, 2011

Updated Search: June 5^th^, 2012

6 | ((‘pressure ulcer?’ OR ‘pressure sore?’ OR ‘bed sore?’ OR bedsore? OR decubitus) NEAR/5 (treat* OR heal* OR manag* OR therap* OR surger*)):ab,ti AND [embase]/lim OR (‘decubitus’/mj AND (‘radiotherapy’:de OR ‘drug therapy’:de OR ‘therapy’:de OR ‘magnetotherapy’:de OR ‘treatment outcome’:de OR ‘palliative therapy’:de OR ‘treatment failure’:de OR ‘treatment response’:de OR ‘wound healing impairment’:de OR ‘healing’:de OR ‘ulcer healing’:de OR ‘wound healing’:de OR ‘wound care’:de OR ‘wound healing promoting agent’:de OR ‘vacuum assisted closure’:de OR ‘surgery’:de OR ‘ultrasound therapy’:de OR ‘diet therapy’:de OR ‘malnutrition’:de OR ‘debridement’:de OR ‘wound dressing’:de) AND [embase]/lim) AND (1985:py OR 1986:py OR 1987:py OR 1988:py OR 1989:py OR 1990:py OR 1991:py OR 1992:py OR 1993:py OR 1994:py OR 1995:py OR 1996:py OR 1997:py OR 1998:py OR 1999:py OR 2000:py OR 2001:py OR 2002:py OR 2003:py OR 2004:py OR 2005:py OR 2006:py OR 2007:py OR 2008:py OR 2009:py OR 2010:py OR 2011:py) | 1,739
5 | ((‘pressure ulcer?’ OR ‘pressure sore?’ OR ‘bed sore?’ OR bedsore? OR decubitus) NEAR/5 (treat* OR heal* OR manag* OR therap* OR surger*)):ab,ti AND [embase]/lim OR (‘decubitus’/mj AND (‘radiotherapy’:de OR ‘drug therapy’:de OR ‘therapy’:de OR ‘magnetotherapy’:de OR ‘treatment outcome’:de OR ‘palliative therapy’:de OR ‘treatment failure’:de OR ‘treatment response’:de OR ‘wound healing impairment’:de OR ‘healing’:de OR ‘ulcer healing’:de OR ‘wound healing’:de OR ‘wound care’:de OR ‘wound healing promoting agent’:de OR ‘vacuum assisted closure’:de OR ‘surgery’:de OR ‘ultrasound therapy’:de OR ‘diet therapy’:de OR ‘malnutrition’:de OR ‘debridement’:de OR ‘wound dressing’:de) AND [embase]/lim) | 2,263
4 | ‘decubitus’/mj AND (‘radiotherapy’:de OR ‘drug therapy’:de OR ‘therapy’:de OR ‘magnetotherapy’:de OR ‘treatment outcome’:de OR ‘palliative therapy’:de OR ‘treatment failure’:de OR ‘treatment response’:de OR ‘wound healing impairment’:de OR ‘healing’:de OR ‘ulcer healing’:de OR ‘wound healing’:de OR ‘wound care’:de OR ‘wound healing promoting agent’:de OR ‘vacuum assisted closure’:de OR ‘surgery’:de OR ‘ultrasound therapy’:de OR ‘diet therapy’:de OR ‘malnutrition’:de OR ‘debridement’:de OR ‘wound dressing’:de) AND [embase]/lim | 1,528
3 | ((‘pressure ulcer?’ OR ‘pressure sore?’ OR ‘bed sore?’ OR bedsore? OR decubitus) NEAR/5 (treat* OR heal* OR manag* OR therap* OR surger*)):ab,ti AND [embase]/lim | 1,439
2 | ‘radiotherapy’:de OR ‘drug therapy’:de OR ‘therapy’:de OR ‘magnetotherapy’:de OR ‘treatment outcome’:de OR ‘palliative therapy’:de OR ‘treatment failure’:de OR ‘treatment response’:de OR ‘wound healing impairment’:de OR ‘healing’:de OR ‘ulcer healing’:de OR ‘wound healing’:de OR ‘wound care’:de OR ‘wound healing promoting agent’:de OR ‘vacuum assisted closure’:de OR ‘surgery’:de OR ‘ultrasound therapy’:de OR ‘diet therapy’:de OR ‘malnutrition’:de OR ‘debridement’:de OR ‘wound dressing’:de AND [embase]/lim | 2,565,030
1 | ‘decubitus’/mj AND [embase]/lim | 3,001

## CINAHL

Searched: EBSCOHost CINAHL Plus with Full Text

Date Searched: September 14, 2011

Updated Search: June 5^th^, 2012

S6 | S1 or S2 or S5 | Limiters - Published Date from: 19850101–20111231 Search modes - Boolean/Phrase | 1197
S5 | S3 or S4 | Limiters - Search Only Pre-CINAHL Search modes - Boolean/Phrase | 22
S4 | (AB “pressure ulcer*” or AB “pressure sore*” or AB “bed sore*” or AB “bedsore*” or AB “decubitus ulcer*”) and (AB “treat*” or AB “heal*” or AB “manag*” or AB “therapy” or AB “therapies”) | Limiters - Exclude MEDLINE records Search modes - Boolean/Phrase | 658
S3 | (TI “pressure ulcer*” or TI “pressure sore*” or TI “bed sore*” or TI “bedsore*” or TI “decubitus ulcer*”) and (TI “treat*” or TI “heal*” or TI “manag*” or TI “therapy” or TI “therapies”) | Limiters - Exclude MEDLINE records Search modes - Boolean/Phrase | 449
S2 | (MM “Pressure Ulcer”) and (MW “treatment” or MW “healing” or MW “management” or MW “therapy” or MW “therapeutic”) | Limiters - Exclude MEDLINE records Search modes - Boolean/Phrase
S1 | (MH “Pressure Ulcer/CO/DH/DT/MO/NU/RT/RH/SU/TH”) | Limiters - Exclude MEDLINE records Search modes - Boolean/Phrase | 1013

## EBM Reviews

Searched:

EBM Reviews - Cochrane Database of Systematic Reviews 2005 to August 2011,

EBM Reviews - Database of Abstracts of Reviews of Effects 3rd Quarter 2011,

EBM Reviews - Cochrane Central Register of Controlled Trials 3rd Quarter 2011,

EBM Reviews - Health Technology Assessment 3rd Quarter 2011,

EBM Reviews - NHS Economic Evaluation Database 3rd Quarter 2011

Date Searched: September 14, 2011

Updated Search: June 5^th^, 2012

1 | Pressure Ulcer/dh, dt, nu, rt, rh, su, th, ae, co, in, mo, po, to | 262
2 | Pressure ulcer/ and (treatment or healing or management or therapy).hw. | 184
3 | ((pressure ulcer$ or pressure sore$ or bed sore$ or bedsore$ or decubitus ulcer$) adj5 (treat$ or heal$ or manag$ or therap$)).ti,ab. | 363
4 | 1 or 2 or 3 | 501
5 | limit 4 to yr=“1985 -Current” | 470
6 | remove duplicates from 5 | 466

## ClinicalTrials.gov

Searched 09/15/2011

Update Search 06/05/2012

( ( NOT ( “Recruiting” OR “Not yet recruiting” OR “Available” ) ) [OVERALL-STATUS] AND pressure ulcer* OR decubitus ulcer* OR pressure sore* OR bedsore* OR bed sore* [DISEASE] ) [ALL-FIELDS]

Results = 184

## Current Controlled Trials

Searched 09/15/2011

Update Search 06/05/2012

Search box: pressure ulcer*, decubitus ulcer*, pressure sore*, bedsore*, bed sore*

Selected all registries with the exception of Nih’s ClinicalTrials.gov

Results = 8, which were then edited to treatment trials

## ClinicalStudyResults.org

Searched 09/15/2011

Update Search 06/04/2012

Studies Indications or Disease: two searches:

#1: Ulcers, Pressure

#2: Ulcers, Diabetic and Decubitus (bedsores)

Results: neither search returned any results

## WHO ICTRP

Searched 09/15/2011

Update Search 06/05/2012

Search terms:

Condition search box, two separate searches: decubitus ulcers, pressure ulcers

Recruitment status: ALL

Results = 79, which were then edited to treatment trials

Notes: search interface gave inconsistent and unexpected results, based on documentation.

## ProQuest CSA Conference Papers Index

Searched: ProQuest CSA Conference Papers Index

Date Searched: 9/19/2011

Updated Search: 06/05/2012

Search Query #9 KW=(pressure ulcer* or pressure sore* or bed sore* or bedsore* or decubitus ulcer*) and KW=(treat* or heal* or surger* or surgical* or diet* or nutrition* or manag* or therap* or pressure or mattress* or cushion* or surface* or gel* or bandage* or dressing* or foam* or maggot* or debrid* or silver or saline or vibration* or cream*) and not Q1=(screening or prevention or risk assessment or classification or diabetes mellitus or training or quality of life or animal studies) ([underlined: Copy Query])

241 Published Works results found in Conference Papers Index

Date Range: 1985 to 2012

## ProQuest Dissertations & Theses

Searched 09/16/2011

Search terms:

(decubitus ulcer* or pressure ulcer* or pressure sore* or bedsore* or bed sore*) AND (treat* or therap* or manag* or heal*)

## Details of the Search Process

A research Librarian, developed a list of databases to be searched and tested database specific search strategies in collaboration with the research team. Additional references were found by hand-searching the bibliographies of review articles and included studies; letters to the editor and commentaries; and Technical Expert Panel input.

All citations were imported into Thomson Reuters’ EndNote X3 (citation management) and then Distiller Systematic Review Software (screening of abstracts and full text, kappa calculation, data extraction, exclusion reports, and table construction).

## Search Strategy Development Notes

A combination of controlled vocabulary and keywords were employed in the search strategies, with age, study methodology, and date (2002-) limits applied. No language limit was used. Details of the search strategies are given in Appendix A.

## List of Databases Searched

Table A-1 Databases searched

Name | Date Searched | Platform Provider
Bibliographic Database Search
Medline | 1947-02/28/2011; Update Search 06/05/2012 | OvidSP
Embase | 1976-04/11/2011; Update Search 06/05/2012 | Elsevier
Cochrane Library/EBM Reviews: Cochrane Central Register of Controlled Trials (CCRCT) | 1991-04/11/2011; Update Search 06/05/2012 | OvidSP
Cochrane Library/EBM Reviews: Cochrane Database of Systematic Reviews (CDSR) | 2005-04/11/2011; Update Search 06/05/2012 | OvidSP
Cochrane Library/EBM Reviews: Database of Abstracts of Reviews of Effects (DARE) | 1991-04/11/2011; Update Search 06/05/2012 | OvidSP
Citation Database Search
Scopus | 1960-04/11/2011; Update Search 06/05/2012 | Elsevier
Subject Specific Database Search
PsycINFO | 1806-04/12/2011; Update Search 06/05/2012 | OvidSP

## Grey Literature (Unpublished Literature) Strategy

In addition to searching bibliographic, citation, and subject-specific databases, additional materials were sought by searching for regulatory information, clinical trial registries, and conference proceedings. Including the following databases and websites:

Table A-2 Grey literature searched

Name | Date Searched | Platform Provider
Clinical Trial Registries
Clinicaltrials.gov | Original Search 03/02/2011 Update Search 06/05/2012 | US National Institutes of Health
Regulatory Agencies
Drug Approval Package | Original Search 03/02/2011 Update Search 05/052012 | US Federal Drug Administration
European Public Assessment Reports | Original Search 03/02/2011 Update Search 04/06/2012 | European Medicines Agency
Summary Basis of Decision (SBD): Drugs | Original Search 03/02/2011 Update Search 06/05/2012 | Health Canada
Conference Proceedings
Scopus | 1960-April 11, 2011; Update Search 06/05/2012 | Elsevier

## Scientific Information Packets (SIPs)

The Effective Health Care Program Scientific Resource Center requested information about published and unpublished Phase II and above clinical studies, post-marketing studies, and observational studies from pharmaceutical companies. The SIP request deadline had not yet passed when this draft report was written, the final report will be updated with all relevant information derived from SIP submissions.

## Hyperbaric Oxygenation Search Strategy

1 | Pressure Ulcer/dh, dt, nu, rt, rh, su, th, ae, co, in, mo, po, to | 4899
2 | pressure ulcer/ and (treatment or healing or management or therapy).hw. | 1892
3 | ((pressure ulcer$ or pressure sore$ or bed sore$ or bedsore$ or decubitus ulcer$) adj5 (treat$ or heal$ or manag$ or therap$)).ti,ab. | 2266
4 | 1 or 2 or 3 | 6087
5 | limit 4 to yr=“1985 -Current” | 4963
6 | remove duplicates from 5 | 4920
7 | hyperbaric$.ti,ab,hw. | 13131
8 | Hyperbaric Oxygenation/ | 9635
9 | 7 or 8 | 13131
10 | 6 and 9 | 24