# Abbreviations and Acronyms

AF: Air-fluidized
AHCPR: Agency for Health Care Policy and Research
AHRQ: Agency for Healthcare Research and Quality
ANOVA: Analysis of variance
AP: Alternating pressure
BCT: Balsam peru castor oil trypsin
bFGF: Basic fibroblast growth factor
CDC: Center for Disease Control and Prevention
CERs: Comparative Effectiveness Reviews
CHIP: Children’s Health Insurance Program
CI: Confidence interval
CLP: Constant low pressure
CO_2_: Carbon dioxide
DP: Dextranomer paste
EMT: Electromagnetic therapy
EPC: Evidence-based Practice Center
ET: Electrotherapy
EPUAP: European Pressure Ulcer Advisory Panel
GM-CSF: Granulocyte-macrophage colony-stimulating factor
HBV: Hepatitis B virus
HCV: Hepatitis C virus
ICU: Intensive care unit
LAL: Low-air-loss beds
MVP: Moisture vapor permeable
NPUAP: United States National Pressure Ulcer Advisory Panel
NPWT: Negative pressure wound therapy
NR: Not reported
NS: Not significant
OKG: Ornithine Alpha-Ketoglutarate
PDGF: Platelet -Derived Growth Factor
PICOTS: Populations, Interventions, Comparators, Outcomes, Timing, and Setting
PSST: Pressure Sore Status Tool
PU: Pressure ulcer
PUSH: Pressure Ulcer Scale for Healing
RR: Relative risk
SCI: Spinal cord injury
SIP: Scientific information packet
SR: Systematic review
NPWT: Topical negative pressure
TENS: Transcutaneous Electric Nerve Stimulation
TEP: Technical Expert Panel
TGF-beta: Transforming growth factor beta
US: Ultrasound
USPSTF: United States Preventative Services Task Force
UVC: Ultraviolet C
WHO: World Health Organization