# Abbreviations

Acronym/Abbreviation | Definition
AHRQ | Agency for Healthcare Research and Quality
BMI | Body Mass Index
BMS | Bare Metal Stent
CABG | Coronary Artery Bypass Grafting
CAD | Coronary Artery Disease
CCS | Canadian Cardiovascular Society
CER | Comparative Effectiveness Review
DES | Drug-Eluting Stent
EF | Ejection Fraction
EPC | Evidence-based Practice Center
HTN | Hypertension
LAD | Left Anterior Descending Artery
LCX | Left Circumflex Artery
LIMA | Left Internal Mammary Artery
LV | Left Ventricle
LVEF | Left Ventricular Ejection Fraction
MeSH | Medical Subject Headings
MI | Myocardial Infarction
MIDCAB | Minimally Invasive Direct Coronary Artery Bypass
MVD | Multi-vessl Disease
NYHA | New York Heart Association
PCI | Percutaneous Coronary Intervention
PVD | Peripheral Vascular Disease
RCA | Right Circumflex Artery
RCT | Randomized Controlled Trial
SCHIP | State Children's Health Insurance Program
SRC | Scientific Resource Center
SVD | Single-Vessel Disease
TIA | Transient Ischemic Attack
TMI | Transmyocardial Revascularization
UK | United Kingdom
US | United States of America