# Summary and Discussion

The comparative effectiveness of PCI and CABG for patients with the middle spectrum of coronary artery disease who are eligible for both procedures has been assessed in 23 randomized trials that enrolled 9,963 patients, as well as in several large clinical registries. These published studies provide a robust body of evidence regarding the overall outcomes of these alternative coronary revascularization procedures (Figure 25). Despite this solid evidence for overall comparative effectiveness, there is much less evidence regarding the potential for variations in clinical outcomes according to patient-specific and provider-specific characteristics. Most clinical trials have not reported outcomes in key subgroups. Outcomes in the most intensively studied subgroup, patients with diabetes, have been reported by only seven of the 23 trials; outcomes according to other key coronary risk factors have been reported less frequently. Nevertheless, some conclusions can be drawn on the basis of the published trial and registry results.

## Outcomes Overall

Procedural survival was high for both PCI and for CABG in the randomized trials and did not differ significantly (PCI-CABG procedural survival difference of 0.1 percent). Procedural survival in the trials was higher than that in large contemporaneous registries, probably due to patient eligibility criteria for the trials, and the participation of higher quality centers for coronary revascularization. Nevertheless, procedural survival for PCI is significantly greater than for CABG in clinical registries. In randomized trials the freedom from procedural stroke was significantly higher with PCI (Figure 8).

Long-term survival was not substantially different between PCI and CABG up to five years after the initial procedure in the randomized trials. Summary survival differences indicated higher survival in CABG-assigned patients over PCI-assigned patients between six months and five years of less than one percent in absolute terms at each time point (Figure 11, Appendix C Figures 3–6). This conclusion differs somewhat from that of the meta-analysis reported by Hoffman and associates, who found a statistically significant survival advantage for CABG of 1.9 percent at five years based on the results of seven trials. Our analysis is based on a larger number of trials (12 with five years follow-up), and a greater representation of trials in which PCI was performed using stents. Five-year survival in our analysis of the “balloon-era” trials was significantly higher after CABG, whereas survival in the “stent-era” trials was not different between the procedures (Appendix C, Figure 17). Another difference is that our analysis included the AWESOME trial, which was excluded by Hoffman and associates, but our findings were unchanged in a sensitivity analysis that excluded the AWESOME trial. Thus, the most likely explanation for this difference between our results and those of Hoffman and associates is simply that our analysis was based on a more extensive data set with a greater number of more recent trials that used coronary stents routinely. Our analyses show that overall survival over one to five years was generally quite similar in PCI- and CABG-treated patients who were eligible for randomization to either procedure.

Overall freedom from angina and from repeat revascularization procedures strongly favored CABG over PCI (Figures 16 and 17). This difference may be the result of more complete anatomic revascularization with CABG than with PCI, or to restenosis after PCI or both. The advantage of CABG in freedom from angina diminished between one and five years of follow-up, but the difference of 5 percent at five years was nevertheless significant (p<0.0001). The difference between CABG and PCI in the need for repeat revascularization diminished from balloon-era trials to stent-era trials (Figure 18), but remained quite significant even in the most recent trials in which bare metal stents were used routinely for PCI.

## Outcomes in Subgroups

The average outcomes reported by clinical trials and large registries may vary according to patient and provider characteristics. Our review suggests that while the overall outcome differences between PCI and CABG may widen or narrow somewhat in various patient subgroups, there was little evidence for neutralization or frank reversal of comparative effectiveness according to these factors. This conclusion is based more on an absence of evidence rather than on strong evidence that efficacy is unchanged according to patient characteristics, since statistical power was low in subgroup analyses and outcomes in subgroups have been reported sparsely, if reported at all.

The subgroup evidence is strongest for patients with diabetes and patients with more extensive coronary disease. There has been much debate about the finding of the BARI trial that CABG reduced mortality much more than PCI among patients with diabetes than in patients without diabetes. Our overview of all randomized trials (Figures 20 and 21) shows that the overall survival advantage of CABG over PCI in patients with diabetes was not statistically significant, averaging 0.8 percent in absolute terms at five years. The totality of the evidence from clinical trials suggests that the initial BARI finding may have been accentuated by the play of chance within the subgroup of patients with diabetes.

It has been shown previously that the survival advantage for coronary revascularization compared with medical therapy varies directly with the number of diseased vessels, which suggests that the comparative efficacy of PCI and CABG may also vary according to the number of diseased vessels. Trials enrolling patients with single-vessel proximal LAD disease had qualitatively similar results as trials enrolling patients with multi-vessel disease (Figure 12). Only a few trials specifically reported outcomes by number of diseased vessels—these suggest that CABG reduces mortality compared with PCI to a greater extent in patients with three-vessel disease than in patients with two-vessel disease. While this finding is not definitive, it is consistent with analyses from large clinical registries that show significant variation in comparative survival after PCI and CABG depending on the extent of coronary artery disease.

While most of the other patient characteristics such as age, gender, or presence of non-coronary vascular disease reduce long-term survival, they appear to decrease survival to a similar extent in patients treated with PCI or CABG. There is no strong basis, therefore, to alter the general conclusions about the relative effectiveness of PCI and CABG in these subgroups. Again, this conclusion must be tempered by the low statistical power of all subgroup analyses and the very spotty reporting by trials on these subgroups.

There was considerable evidence that the level of provider experience with CABG and PCI affects clinical outcomes. Procedural survival of both CABG and PCI decreased significantly in low volume hospitals and with low volume operators. While none of these studies was randomized, these findings are consistent with a large body of literature demonstrating a relationship between the volume of patients treated and patient outcomes for a wide variety of procedures. ^219^ The effect on procedural outcomes of PCI and CABG may be only modest, however, at least among sufficiently experienced centers and operators. Nevertheless, the persistence of this phenomenon even as the risk of PCI has been reduced by the availability of coronary stents and adjunctive therapy suggests that patients should be aware of the experience and outcomes of the specific center in which they will undergo coronary revascularization.

## Generalizability of Randomized Trials of PCI Versus CABG

While randomized trials are accepted as the most definitive method to compare therapies, it is important to acknowledge the limitations in generalizing trial results to less selected patients and providers. The patients enrolled in the randomized trials of PCI versus CABG were selected to represent the “middle ground” in the spectrum of coronary artery disease, in that neither patients with very extensive coronary atherosclerosis (who generally receive CABG) nor patients with very limited coronary atherosclerosis (who generally undergo PCI) were enrolled (Tables 5 and 6). In addition, few patients enrolled in the trials were elderly, or had a left ventricular ejection fraction below 40 percent, or had heart failure. The findings from the randomized trials, and our synthesis of these results, do not necessarily apply to populations of patients who were not well represented in clinical trials.

Some insight into the comparative use and outcomes of PCI and CABG is provided by several large clinical registries, including the regional databases from Alberta, Canada, ^147^ New York State, ^188^ Northern New England, ^201^ and Scotland, ^206^ and the databases of the large referral centers at Duke ^156,^ ^159^ and the Cleveland Clinic. ^153^ These registries document striking differences in the extent of coronary artery disease between patients selected for PCI and those selected for CABG. In the Duke series, for instance, 60 percent of PCI patients had single-vessel disease and nine percent had triple-vessel disease, whereas 58 percent of CABG patients had triple-vessel disease and nine percent had single-vessel disease. ^159^ The Cleveland Clinic Registry used a multivariable propensity score to quantify the probability a patient would undergo PCI rather than CABG, and reported the most significant predictors (p<0.0001) to be ejection fraction (PCI/CABG odds ratio 1.22 favoring PCI for every 10 percent increase), presence of a total coronary occlusion (PCI/CABG odds ratio 0.26), left main disease (PCI/CABG odds ratio 0.06), proximal left anterior descending disease (PCI/CABG odds ratio 0.45) and peripheral vascular disease (PCI/CABG odds ratio 0.38 favoring CABG). In the Cleveland data, the median propensity score of 0.52 (interquartile range 0.20 to 0.79) among the PCI patients was considerably higher than the median score of 0.03 (interquartile range 0.01 to 0.11) for CABG patients. These data from large registries show that in common clinical practice the typical patient undergoing PCI is quite distinct from the typical patient undergoing CABG, and suggest that few patients would be eligible for randomization because few would be considered to be a reasonable candidate for either PCI or CABG.

These large clinical databases have also compared survival of patients who have undergone PCI with that of patients who had CABG. ^147,^ ^153,^ ^156,^ ^159,^ ^188,^ ^201,^ ^206^ Since patients were not randomized, the registries used a variety of statistical methods to adjust for the observed and recorded differences between the two patient groups. In the overall patient populations in these registries, the CABG/PCI hazard ratio ranged from 0.43 ^153^ to 0.86, ^201^ which differs substantially from the PCI/CABG odds ratio we found in our overview of randomized trials in patients with multi-vessel disease (PCI/CABG odds ratio for survival of 0.95 at five years of follow-up).

We believe that the difference in comparative efficacy of PCI and CABG reported by randomized trials and that reported by the registries is largely due to the differences in the patient populations, especially in their extent of coronary disease. Patients in the randomized trials all met specific entry criteria and could reasonably receive either PCI or CABG, whereas patients in the registries were relatively unselected and were typically eligible either for PCI or CABG, but not for both. The registry studies that compared PCI and CABG in different subgroups of coronary anatomy found very similar survival in the patients in the “middle ground” of the spectrum of coronary disease and, by contrast, much better survival with CABG than with PCI among patients with extensive coronary disease. In the Northern New England Registry, for instance, the adjusted CABG/PCI hazard ratio was 0.98 for double-vessel disease (p=0.77) and 0.60 for triple-vessel disease (p<0.01). In the Duke Databank, ^156,^ ^159^ there was a significant inverse relationship between the extent of coronary disease and the CABG/PCI hazard ratio, with most of the survival advantage from CABG derived from patients with most severe coronary disease. Similar results were reported from the Alberta and Cleveland Registries and, to a lesser extent, from the New York State Registry. ^188^ We interpret these data as showing relatively little difference between PCI and CABG in survival among patients who would meet entry criteria for randomized trials, but a larger difference in patients with more extensive disease who were selected for CABG in the registries from the mid-1990s to 2001.

## Evolving Revascularization Methods

The evidence we have summarized derives primarily from randomized trials conducted in the “balloon era” of 1987 to 1993, and the “bare-metal stent-era” of 1997 to 2001. There are very few trial data that compare the most recent drug-eluting stent technology with contemporary CABG. While several randomized trials are ongoing, results will not be available for several years, especially for long-term outcomes. While some have argued that older PCI vs. CABG trials are now “obsolete,” the evidence does not support the contention that survival and freedom from myocardial infarction have changed as a result of the most recent revascularization methods. Specifically, quantitative overviews have reported no difference in survival and freedom from myocardial infarction between patients randomized to either bare-metal stents or to balloon angioplasty, ^8^ or between patients randomized to either drug-eluting stents or bare-metal stents. ^9^ Nor is there any higher incidence of survival or freedom from MI between patients randomized to minimally invasive or off-pump CABG compared with standard CABG techniques. ^229,^ ^230^ The technical improvements in coronary revascularization clearly do reduce the need for repeat procedures (PCI) and shorten perioperative recovery time (CABG), but these improvements should not be extrapolated to imply that hard events (death and myocardial infarction) have been reduced as well.

Background medical therapy for coronary disease has dramatically improved since the mid-1980s with the introduction of new drugs and the completion of large clinical trials that demonstrate reduced cardiac events. Medical therapy is recommended for all patients after PCI and CABG, so the comparative efficacy of these two procedures should not change drastically as a result of better medical therapy. Nevertheless, to the extent that the overall risk of patients with coronary disease has been reduced by improved medical therapy, any risk differences between PCI and CABG are also likely to be reduced. More importantly, the efficacy of coronary revascularization in increasing survival and freedom from myocardial infarction compared with medical therapy may also have been reduced over the past 20 years. While a comparison of PCI or CABG with medical therapy is beyond the scope of this report, we note that several clinical trials (e.g., BARI-2D, COURAGE) are ongoing and will compare contemporary aggressive medical therapy with revascularization plus medical therapy.

## Future Research

This comprehensive review of the comparative effectiveness of PCI and CABG has identified numerous gaps in evidence that would be suitable for future research. The paucity of published analyses of PCI and CABG outcomes according to patient characteristics strongly suggests the value of a collaborative pooling of individual patient-level data from the randomized trials to a) enhance statistical power to identify subgroup effects, and b) reduce publication bias by including data from all trials. The stent trialists collaboration has pooled one-year outcomes of four trials (ARTS, ERACI-II, MASS-II, and SOS), and provided useful short-term analysis in key subgroups. ^17^ The planned extension of this collaborative pooling to include five year follow-up data will be very informative.

A more extensive collaborative study to pool individual patient data from both balloon-era and stent-era trials would provide additional advantages. First, the number of patients and outcome events would be greatly increased, thereby improving statistical power even further in patient subgroups. Second, more direct assessments of the impact of stents upon the comparative effectiveness of PCI and CABG would be feasible, as well as assessment of whether relative efficacy changes over extended follow-up.

Further clinical trials are also needed to assess whether the availability of drug-coated stents have affected the comparative efficacy of PCI and CABG. Such trials are particularly warranted, as pooled studies suggest that survival and freedom from myocardial infarction are not different between bare metal stents and drug-coated stents over medium-term follow-up. Recent safety concerns about drug-coated stents emphasize the need for extended follow-up and trials large enough to detect clinically meaningful differences in outcomes. Several trials are currently underway to compare CABG with PCI using drug-coated stents (Appendix C Table 13).

While there is extensive literature examining the effect of hospital volume and physician volume on the outcomes of PCI and CABG, our review indicates several major gaps that should be addressed in further research. The new, minimally invasive approaches to CABG have not been examined in much detail with respect to procedure volume and outcome, and it cannot be assumed that the relationships defined for standard CABG will apply to minimally invasive CABG. In particular, the volume thresholds for minimally invasive CABG are likely to be different, given the difference in technique. A broader issue in all volume-outcome research is that procedural mortality is not the only important measure of outcome. Procedural myocardial infarction, graft patency, relief of angina, and long-term outcomes are also pertinent to decision making and should be explored in relation to volume levels. Finally, process measures have been increasingly used to measure quality of care when there is a strong evidence base linking process to outcome. Research to establish evidence-based process measures for coronary revascularization might provide better metrics for quality of care for PCI and CABG procedures. However, these measures may be more cumbersome to collect, such that volume measures may still be valuable if the relationship between process, volume, and outcome were better defined.