# Results

Our searches for RCTs comparing the effectiveness of PCI and CABG yielded 1695 potentially relevant articles of which 204 articles merited full-text review (Figure 1). A total of 113 articles reporting on 23 unique populations met our inclusion criteria. Appendix B provides the citations of articles excluded after the full text review with the reason for exclusion.

Figure 1. Search results for RCTs

Our searches for registries yielded 94 potentially relevant articles on ten registries that met our inclusion criteria. In the sections that follow, we first present an overview of the included RCTs and observational studies and then present the evidence relevant to each of the key questions.

## General Description of Included Studies

### Description of the Randomized Controlled Trials

We identified 23 RCTs that enrolled a total of 9,963 patients (5019 who received PCI and 4944 who received CABG) (Table 3). We also identified a collaborative pooling of patient data from four of the included RCTs. ^17^

Table 3 Brief overview of the randomized controlled trials

AMIST—Angioplasty versus Minimally Invasive Surgery Trial.
A small UK trial of 100 patients with single-vessel proximal LAD disease conducted 1999-2001.
Reeves BC, Angelini GD, Bryan AJ, et al. A multi-centre randomised controlled trial of minimally invasive direct coronary bypass grafting versus percutaneous transluminal coronary angioplasty with stenting for proximal stenosis of the left anterior descending coronary artery. Health Technol Assess. 2004 Apr;8(16):1–43.
ARTS—Arterial Revascularization Therapies Study.
A large European trial of 1205 patients with MVD that used bare metal stents. One of four trials that participated in the pooling project of stent trials.
Serruys PW, Unger F, Sousa JE, et al. Comparison of coronary-artery bypass surgery and stenting for the treatment of multivessel disease. N Engl J Med. 2001 Apr 12;344(15):1117–24.
AWESOME—Angina with Extremely Serious Operative Mortality Evaluation.
A medium-sized American Department of Veterans Affairs trial in 454 patients with medically refractory angina, high procedural risk, and single or multi-vessel disease.
Morrison DA, Sethi G, Sacks J, et al. Percutaneous coronary intervention versus coronary artery bypass graft surgery for patients with medically refractory myocardial ischemia and risk factors for adverse outcomes with bypass: a multicenter, randomized trial. Investigators of the Department of Veterans Affairs Cooperative Study #385, the Angina With Extremely Serious Operative Mortality Evaluation (AWESOME). J Am Coll Cardiol. 2001 Jul;38(1):143–9.
BARI—Bypass Angioplasty Revascularization Investigation.
Large American-Canadian trial of 1829 patients that used balloon angioplasty and reported extensively on outcomes in patient subgroups. Extended follow-up to ten years has been reported.
The Bypass Angioplasty Revascularization Investigation (BARI) Investigators. Comparison of coronary bypass surgery with angioplasty in patients with multivessel disease. N Engl J Med. 1996 Jul 25;335(4):217–25.
CABRI—Coronary Angioplasty versus Bypass Revascularization Investigation.
Large European trial of 1054 patients with MVD that used balloon angioplasty and had limited follow-up.
CABRI Trial Participants. First-year results of CABRI (Coronary Angioplasty versus Bypass Revascularisation Investigation). Lancet. 1995 Nov 4;346(8984):1179–84.
EAST—Emory Angioplasty Surgery Trial.
A medium-sized, single-center American trial of 392 patients with MVD that used balloon angioplasty and reported extended follow-up to eight years.
King SB, 3rd, Lembo NJ, Weintraub WS, et al. A randomized trial comparing coronary angioplasty with coronary bypass surgery. Emory Angioplasty versus Surgery Trial (EAST). N Engl J Med. 1994 Oct 20;331(16):1044–50.
ERACI-I—Argentine Randomized Trial of PTCA versus CABG in Multi-vessel Disease.
A small Argentine trial of 127 patients with MVD that used balloon angioplasty and had limited follow-up.
Rodriguez A, Boullon F, Perez-Balino N, et al. Argentine randomized trial of percutaneous transluminal coronary angioplasty versus coronary artery bypass surgery in multivessel disease (ERACI): in-hospital results and 1-year follow-up. ERACI Group. J Am Coll Cardiol. 1993;22(4):1060–7.
ERACI-II—Second Argentine Randomized Trial of PTCA versus CABG in Multi-vessel Disease.
A medium-sized trial of 450 patients with MVD conducted by the same Argentine group that organized ERACI-I. The trial used bare metal stents and was one of four trials that participated in the primary data pooling project
Rodriguez A, Bernardi V, Navia J, et al. Argentine Randomized Study: Coronary Angioplasty with Stenting versus Coronary Bypass Surgery in patients with Multiple-Vessel Disease (ERACI II): 30-day and one-year follow-up results. ERACI II Investigators. Journal of the American College of Cardiology. 2001 Jan;37(1):51–8.
GABI—German Angioplasty Bypass Surgery Investigation.
A medium-sized German trial of 359 patients with MVD that used balloon angioplasty and has reported the longest follow-up of any PCI-CABG trial (13 years).
Hamm CW, Reimers J, Ischinger T, et al. A randomized study of coronary angioplasty compared with bypass surgery in patients with symptomatic multivessel coronary disease. German Angioplasty Bypass Surgery Investigation (GABI). N Engl J Med. 1994 Oct 20;331(16):1037–43.
Groningen
A small, single-center Dutch study of 100 patients with single-vessel proximal LAD disease randomized to either stent implantation or minimally invasive bypass surgery.
Drenth DJ, Veeger NJGM, Winter JB, et al. A prospective randomized trial comparing stenting with off-pump coronary surgery for high-grade stenosis in the proximal left anterior descending coronary artery: three-year follow-up. J Am Coll Cardiol. 2002 Dec 4;40(11):1955–60.
Lausanne
A small, single-center Swiss trial (134 patients) with single-vessel proximal LAD disease that used balloon angioplasty.
Goy JJ, Eeckhout E, Burnand B, et al. Coronary angioplasty versus left internal mammary artery grafting for isolated proximal left anterior descending artery stenosis. Lancet. 1994;343(8911):1449–53.
Leipzig
A small, single-center German study of 220 patients with single-vessel proximal LAD disease that compared bare-metal stents with minimally invasive CABG.
Diegeler A, Thiele H, Falk V, et al. Comparison of stenting with minimally invasive bypass surgery for stenosis of the left anterior descending coronary artery. N Engl J Med. 2002 Aug 22;347(8):561–6.
MASS-I—Medicine, Angioplasty, or Surgery Study.
A small, single-center Brazilian trial that used three treatment options for patients with single-vessel proximal LAD disease (only outcomes in patients assigned to PCI or CABG were used in this report)
Hueb WA, Bellotti G, de Oliveira SA, et al. The Medicine, Angioplasty or Surgery Study (MASS): a prospective, randomized trial of medical therapy, balloon angioplasty or bypass surgery for single proximal left anterior descending artery stenoses. J Am Coll Cardiol. 1995;26(7):1600–5.
MASS-II—Second Medicine, Angioplasty, or Surgery Study.
A medium-sized Brazilian trial of 408 patients with MVD conducted by the same investigators as the MASS-I trial. This study used bare-metal stents and was one of four trials that contributed to the primary data pooling project for stent trials.
Hueb W, Soares PR, Gersh BJ, et al. The medicine, angioplasty, or surgery study (MASS-II): a randomized, controlled clinical trial of three therapeutic strategies for multivessel coronary artery disease: one-year results. J Am Coll Cardiol. 2004 May 19;43(10):1743–51.
Myoprotect I
A small, single-center German trial of 44 high risk patients with left main or left main equivalent disease randomized to PCI supported by retroinfusion of the anterior cardiac vein or to bypass surgery.
Pohl T, Giehrl W, Reichart B, et al. Retroinfusion-supported stenting in high-risk patients for percutaneous intervention and bypass surgery: results of the prospective randomized myoprotect I study. Catheter Cardiovasc Interv. 2004;62(3):323–30.
Octostent
A medium-sized Dutch trial of 280 patients with single- or MVD comparing coronary stents with off-pump bypass surgery
Eefting F, Nathoe H, van Dijk D, et al. Randomized comparison between stenting and off-pump bypass surgery in patients referred for angioplasty. Circulation. 2003 Dec 9;108(23):2870–6.
Poland
A small, single-center Polish trial of 100 patients with single-vessel proximal LAD disease comparing coronary stenting with minimally invasive direct coronary bypass grafting.
Cisowski M, Drzewiecki J, Drzewiecka-Gerber A, et al. Primary stenting versus MIDCAB: preliminary report-comparision of two methods of revascularization in single left anterior descending coronary artery stenosis. Ann Thorac Surg. 2002;74(4):S1334–9.
RITA—Randomized Intervention Treatment of Angina.
A large UK trial of 1011 patients with single-or MVD comparing balloon angioplasty with bypass surgery.
Henderson RA, Pocock SJ, Sharp SJ, et al. Long-term results of RITA-1 trial: clinical and cost comparisons of coronary angioplasty and coronary-artery bypass grafting. Randomised Intervention Treatment of Angina. Lancet. 1998 Oct 31;352(9138):1419–25.
Seoul-Hong
A small, single-center Korean trial of 189 patients with proximal LAD disease comparing treatment with DES to MIDCAB.
Hong SJ, Lim D-S, Seo HS, et al. Percutaneous coronary intervention with drug-eluting stent implantation vs. minimally invasive direct coronary artery bypass (MIDCAB) in patients with left anterior descending coronary artery stenosis. Catheter Cardiovasc Interv. 2005 Jan;64(1):75–81.
Seoul-Kim
A small, single-center Korean trial of 100 patients with proximal LAD disease comparing treatment with BMS to MIDCAB.
Kim JW, Lim DS, Sun K, et al. Stenting or MIDCAB using ministernotomy for revascularization of proximal left anterior descending artery? Int J Cardiol. 2005 Mar 30;99(3):437–41.
SIMA—Stenting versus Internal Mammary Artery study.
A small European trial of 123 patients with isolated proximal LAD disease comparing coronary stenting to MIDCAB.
Goy JJ, Kaufmann U, Goy-Eggenberger D, et al. A prospective randomized trial comparing stenting to internal mammary artery grafting for proximal, isolated de novo left anterior coronary artery stenosis: The SIMA trial. Mayo Clin Proc. 2000;75(11):1116–23.
SoS—Stent or Surgery.
A large European-Canadian trial of 988 patients with MVD comparing coronary stenting with CABG. One of four trials that contributed to the individual data pooling project for stent trials.
SoS Investigators. Coronary artery bypass surgery versus percutaneous coronary intervention with stent implantation in patients with multivessel coronary artery disease (the Stent or Surgery trial): a randomised controlled trial. Lancet. 2002 Sep 28;360(9338):965–70.
Toulouse
A small, single-center French study of 152 patients with single-vessel proximal LAD disease comparing balloon angioplasty with bypass surgery.
Carrie D, Elbaz M, Puel J, et al. Five-year outcome after coronary angioplasty versus bypass surgery in multivessel coronary artery disease: results from the French Monocentric Study. Circulation. 1997;96(9 Suppl):II-1–6.

PCI=percutaneous coronary intervention; PTCA=percutaneous transluminal coronary intervention; CABG=coronary artery bypass grafting; MIDCAB=minimally-invasive coronary artery bypass grafting; BMS=bare-metal stent; DES=drug-eluting stent; MVD=multi-vessel disease; SVD=single-vessel disease; LAD=left anterior descending

Trials were evenly split between single center and multi-center studies, and most were conducted in Europe or the United Kingdom, or both (only three trials were performed in the United States) (Table 4). Trials were conducted in two major waves: the early studies (patient entry 1987-1993) principally used balloon angioplasty as the PCI technique, and the recent studies (1994-2002) principally used stents as the PCI technique. Only one small trial of PCI versus CABG used drug-eluting stents. ^34^ Nine trials limited entry to patients with single-vessel disease of the proximal left anterior descending (LAD) artery, while the remaining 14 trials enrolled patients with multi-vessel disease, either exclusively (11 trials) or predominantly (three trials) (Table 5).

Table 4 General description of the randomized controlled trials

Trial (Associated References) | Number of enrolling centers | Countries | Setting | Years of enrollment | Number of subjects randomized | | PCI Intervention | Surgical Intervention
| | | | | PCI | Surgery
AMIST ^36^ | 6 | UK | Cardiac centers: 100% | 1999 to 2001 | 50 | 50 | Stents available, not required | LIMA to LAD
ARTS ^37^ ( ^38^ – ^49^ ) | 67 | Canada; UK; Europe; South America | Cardiovascular centers: 100% | 1997 to 1998 | 600 | 605 | Bare metal stent | Standard CABG with at least one arterial conduit
AWESOME ^50^ ( ^51^ – ^57^ ) | 16 | US | Academic Centers: 94%; Community Hospitals: 6% | 1995 to 2000 | 222 | 232 | Operator choice of balloon angioplasty, stents, atherectomy, adjunctive pharmacologic support. | Surgeon choice of conduits, cardioplegia, sternotomy or thoracotomy, off-pump or on-pump.
BARI ^58^ ( ^59^ – ^86^ ) | 18 | US; Canada | Academic Centers: 100% | 1988 to 1991 | 915 | 914 | Balloon angioplasty | Standard CABG
CABRI ^87^ ( ^88^ – ^93^ ) | 26 | UK; Europe | Not specified | 1988 to 1992 | 541 | 513 | Balloon angioplasty | Standard CABG with arterial graft encouraged
EAST ^94^ ( ^95^ – ^103^ ) | 1 | US | Academic Centers: 100% | 1987 to 1990 | 198 | 194 | Balloon angioplasty; 40% staged procedures | Standard CABG.
ERACI-I ^104^ ( ^105^ ) | 1 | South America | Academic Centers: 100% | 1988 to 1990 | 63 | 64 | Balloon angioplasty | Hypothermic arrest, blood cardioplegia. LIMA used when possible.
ERACI-II ^106^ ( ^107,^ ^108^ ) | 7 | South America | Not specified | 1996 to 1998 | 225 | 225 | Bare metal stent | Standard CABG. Arterial conduits encouraged.
GABI ^109^ ( ^110,^ ^111^ ) | 8 | Europe | Academic Centers: 62.5%; Other: 37.5% | 1986 to 1991 | 182 | 177 | Balloon angioplasty | Standard CABG
Groningen ^112^ ( ^113^ – ^115^ ) | 1 | Europe | Academic Centers: 100% | 1997 to 1999 | 51 | 51 | Bare metal stent | LIMA using small left anterior thoracotomy, beating heart with mechanical stabilizer
Lausanne ^116^ ( ^117^ ) | 1 | Europe | Academic Centers: 100% | 1989 to 1993 | 68 | 66 | Balloon angioplasty | median sternotomy, LIMA, hypothermia
Leipzig ^118^ ( ^119,^ ^120^ ) | 1 | Europe | Academic Centers: 100% | 1997 to 2001 | 110 | 110 | Bare metal stent | MIDCAB: limited left anterolateral thoractomy, LIMA with mechanical stabilizers, beating heart.
MASS ^121^ ( ^122^ ) | 1 | South America | Academic Centers: 100% | 1988 to 1991 | 72 | 70 | Balloon angioplasty | LIMA, mild hypothermia, extracorporeal circulation
MASS-II ^123^ ( ^124,^ ^125^ ) | 1 | South America | Academic Centers: 100% | 1995 to 2000 | 205 | 203 | Operator choice BMS, lasers, atherectomy, balloon. | LIMA encouraged. Normothermic arrest with blood cardioplegia.
Myoprotect I ^126^ | 1 | Europe | Academic Centers: 100% | 1998 to 2001 | 23 | 21 | PCI with retroinfusion catheter in cardiac venous system | Standard CABG, off-pump by operator choice.
Octostent ^127^ ( ^128,^ ^129^ ) | 3 | Europe | Academic Centers: 33%; Other: 67% | 1998 to 2000 | 138 | 142 | Bare metal stent | Off-pump CABG with Octopus tissue stabilizer. Operator choice of median sternotomy or left anterior thoracotomy. Arterial grafting encouraged.
Poland ^130^ ( ^131^ ) | 1 | Europe | Academic Centers: 100% | 2000 to 2001 | 50 | 50 | Bare metal stent | MIDCAB: LIMA under mechanical stabilization on beating heart through anterior thoracotomy.
RITA-1 ^132^ ( ^133^ – ^137^ ) | 16 | UK | Not specified | 1988 to 1991 | 510 | 501 | Balloon angioplasty | Standard CABG.
Seoul-Hong ^34^ | 1 | Asia | Academic Centers: 100% | 2003 | 119 | 70 | Drug-coated stent | Off-pump LIMA with mechanical stabilization on beating heart, anterolateral thoractomy
Seoul-Kim ^35^ | 1 | Asia | Academic Centers: 100% | 2000-2001 | 50 | 50 | Bare metal stent | MIDCAB: LIMA with mechanical stabilization on beating heart through ministernotomy
SIMA ^138^ | 6 | Europe | Academic Centers: 50%; Community Hospitals: 50% | 1994 to 1998 | 63 | 60 | Bare metal stent | Minimally invasive, cardioplegia and hypothermia
SoS ^139^ ( ^140^ – ^145^ ) | 53 | Canada; UK; Europe | | 1996 to 1999 | 488 | 500 | Bare metal stent | Standard CABG, 93% use of IMA.
Toulouse ^146^ | 1 | Europe | Academic Centers: 100% | 1989 to 1993 | 76 | 76 | Balloon angioplasty | Standard CABG, 58% use of IMA.

PCI=percutaneous coronary intervention; CABG=coronary artery bypass grafting; UK=United Kingdom; US=United States; LIMA=left internal mammary artery; IMA=internal mammary artery; LAD=left anterior descending artery; MIDCAB=minimally invasive direct coronary artery bypass; BMS=bare metal stent

Table 5 Randomized controlled trials inclusion and exclusion criteria

Trial | Inclusion criteria | | | | | | Exclusion criteria
| MVD | SVD | PCI eligible lesion | Stable or unstable angina | Positive stress test | Other | Prior CABG | Prior PCI | Prior stroke or TIA | Age (years) | Left main CAD | SVD | Total occlusion | LVEF | Unsuitable coronary anatomy | Recent MI | Life limiting illness | Other HD
AMIST ^36^ | | ✓ | | | ✓ | | ✓ | ✓ | | | | | ✓ | <30% | ✓
ARTS ^37^ | ✓ | | at least 2 | | | | ✓ | ✓ | ✓ | | ✓ | ✓ | | 30% | ✓ | ✓
AWESOME ^50^ | | | | ✓ | | ✓a | | in last 6 months | | | ✓ | | | | | | ✓ | ✓
BARI ^58^ | ✓ | | | | | | ✓ | ✓ | | <80 | ✓ | ✓ | | | ✓ | | ✓
CABRI ^87^ | ✓ | | 1 | ✓ | | ✓b | ✓ | ✓ | ✓ | <76 | ✓ | ✓ | | 35% | | ✓ | ✓ | ✓
EAST ^94^ | ✓ | | | | | | ✓ | ✓ | | | ✓ | ✓ | ✓ | 25% | ✓ | ✓
ERACI-I ^104^ | ✓ | | ✓ | | ✓ | | | | | | ✓ | ✓ | | 35% | ✓ | ✓ | ✓ | ✓
ERACI-II ^106^ | ✓ | | | | ✓ | ✓c | ✓ | ✓ | | | | | ✓ | < 35% | ✓ | ✓ | ✓ | ✓
GABI ^109^ | ✓ | | at least 2 | | | | ✓ | ✓ | | <75 | ✓ | ✓ | ✓ | | ✓ | ✓
Groningen ^112^ | | ✓ | | | | | ✓ | ✓ | ✓ | | | | | ✓ | | ✓
Lausanne ^116^ | | ✓ | | | ✓ | ✓d | ✓ | ✓ | | | ✓ | | | 50% | ✓ | ✓
Leipzig ^118^ | | ✓ | | | | ✓e | ✓ | ✓ | | | | | ✓ | | ✓ | | | ✓
MASS-I ^121^ | | ✓ | | | | | ✓ | ✓ | | | ✓ | | | ✓ | ✓
MASS-II ^123^ | ✓ | | | | ✓ | | ✓ | ✓ | | | ✓ | | | <40% | ✓ | ✓ | | ✓
Myoprotect I ^126^ | ✓ | | at least 1 | | | ✓f | | | | | | | | | | ✓ | ✓
Octostent ^127^ | ✓ | | at least 1 | ✓ | | ✓g | ✓ | in last 6 months | | > 18 | ✓ | | ✓ | ✓ | ✓ | ✓ | ✓
Poland ^130^ | | ✓ | | | | ✓h | ✓ | ✓ | | | | | ✓ | 40% | | ✓ | | ✓
RITA-1 ^132^ | ✓ | | | ✓ | | | ✓ | ✓ | | | ✓ | | | | | | ✓ | ✓
Seoul-Hong ^34^ | | ✓ | | | | | ✓ | ✓ | | | | | ✓ | | | ✓
Seoul-Kim ^35^ | | ✓ | | ✓ | | ✓i | ✓ | ✓ | | | ✓ | | | | ✓ | | | ✓
SIMA ^138^ | | ✓ | | | | | | | | | | | | 45%
SoS ^139^ | ✓ | | at least 1 | | | | ✓ | ✓ | | | | | | | | ✓ | ✓
Toulouse ^146^ | ✓ | | | | | | ✓ | ✓ | | > 40 | ✓ | | ✓ | | ✓ | | ✓

MVD=multi-vessel disease; SVD=single-vessel disease (single-vessel or proximal Left Anterior Descending); PCI=percutaneous coronary intervention; CABG=coronary artery bypass graft; TIA=transient ischemic attack; CAD=Coronary Artery Disease; LVEF=Left ventricular ejection fraction; MI=myocardial infarction; HD=heart disease

a=Refractory ischemia; high risk for adverse outcomes (either over age 70, one or more prior open heart operations, LVEF < 0.35, MI within the last 7 days, or intraaortic balloon pump necessary to stabilize)

b=At least 1 lesion ( > 50% reduction in luminal diameter) and the vessel distal to the lesion at least 2 mm;

c=A stress test that showed a large area or multiple areas of ischemia; At least one vessel to be stented had to have > 3mm diameter; LM was OK if interventionalist was comfortable stenting;

d=documented ischemia by ETT or spontaneous ST changes with pain;

e=minimum stenosis 75%;

f=main-stem or a main-stem-equivalent lesion (defined as a leading proximal left anterior descending coronary artery (LAD) stenosis or stenosis of and LAD bypass (>/=75%) with concomitantly documented proximal occlusion of the right coronary artery and/or the left circumflex artery and a history of myocardial infarction); symptomatic coronary artery disease; Parsonnet score >6;

g=Refractory ischemia; normal or moderately impaired global left ventricular function; one or more significant stenosis in at least one major epicardial coronary artery (LAD, left CX, RCD, or combo of one of the former and a side branch providing different myocardial territories);

** Left circumflex—only patients in whom one graft needs to be inserted are eligible;

h=CCS class II or higher angina; minimum stenosis 70% in LAD; minimum artery diameter 3 mm; minimum lesion length 20 mm; no significant lesions in other arteries; ARTS excluded patients with aspirin or ticlopidine allergies; Myoprotect 1 excluded patients with aspirin or clopidogrel allergies; Poland excluded patients with insulin dependent diabetes;

i=minimum stenosis 70%

Trial participants averaged 61 years of age, and 27% were women (Appendix C Table 1). The vast majority of patients were of European ancestry, since most trials were conducted in Europe and only 5–7% of patients in the US-based studies were of African American ancestry (less than 2% of patients randomized in all trials). The baseline clinical characteristics of trial participants were typical for a population of patients with coronary disease: roughly 20% had diabetes, half had hypertension, and half had hyperlipidemia (Appendix C Table 2). While roughly 40% of patients had a prior myocardial infarction, the prevalence of heart failure was low, and left ventricular function was generally well preserved. Among studies that enrolled patients with multi-vessel coronary disease, most patients had two-vessel rather than three-vessel disease (Table 6).

Table 6 Randomized controlled trials subjects' baseline coronary anatomy

Trial | Intervention | Mean Number diseased vessels | I VD % | 2 VD % | 3 VD % | LAD (prox) | LAD (other) | LAD (any) | LCX | RCA
AMIST ^36^ | PCI | | 100* | | | 100**
| CABG | | 100* | | | 100**
ARTS ^37^ | PCI | 2.8 | 2 | 68 | 30 | | | 90 | 71 | 71
| CABG | 2.8 | 0 | 67 | 33 | | | 90 | 72 | 72
AWESOME ^50^ | PCI | | 20 | 40 | 40 | | | 87
| CABG | | 17 | 33 | 50 | | | 88
BARI ^58^ | PCI | | 2 | 57 | 41 | 36
| CABG | | 2 | 58 | 41 | 37
CABRI ^87^ | PCI | 2.4 | 2 | 58 | 40
| CABG | 2.4 | 1 | 56 | 43
EAST ^94^ | PCI | 3.4 | | 60 | 40 | 71
| CABG | 3.4 | | 60 | 40 | 74
ERACI-I ^104^ | PCI | | | 57 | 43 | | | 38 | 33 | 29
| CABG | | | 53 | 47 | | | 37 | 30 | 34
ERACI-II ^106^ | PCI | | | 40 | 55 | 50 | | 91
| CABG | | | 38 | 58 | 52 | | 93
GABI ^109^ | PCI | | | 85 | 15
| CABG | | | 78 | 22
Groningen ^112^ | PCI | | 100* | | | 100
| CABG | | 100* | | | 100
Lausanne ^116^ | PCI | | 100 | | | 100
| CABG | | 100 | | | 100
Leipzig ^118^ | PCI | | 100* | | | 100**
| CABG | | 100* | | | 100**
MASS-I ^121^ | PCI | | 100 | | | 100
| CABG | | 100 | | | 100
MASS-II ^123^ | PCI | | | 42 | 58 | | | 93
| CABG | | | 42 | 58 | | | 93
Myoprotect I ^126^ | PCI | 2.7 | | 17 | 65 | | 30 | 52
| CABG | 2.6 | | 33 | 81 | | 19 | 43
Octostent ^127^ | PCI | | 68 | 30 | 1 | | | 88 | 17 | 27
| CABG | | 74 | 24 | 2 | | | 90 | 18 | 20
Poland ^130^ | PCI | | 100* | | | 100**
| CABG | | 100* | | | 100**
RITA-1 ^132^ | PCI | 1.7 | 46 | 42 | 12
| CABG | 1.7 | 44 | 43 | 12
Seoul-Hong ^34^ | PCI | | 100* | | | 100
| CABG | | 100* | | | 100
Seoul-Kim ^35^ | PCI | | 100* | | | 100**
| CABG | | 100* | | | 100**
SIMA ^138^ | PCI | | 100* | | | 100**
| CABG | | 100* | | | 100**
SoS ^139^ | PCI | | | 63 | 37 | 48 | 44 | | 70 | 74
| CABG | | | 52 | 47 | 44 | 48 | | 75 | 79
Toulouse ^146^ | PCI | | | 72 | 28 | | | 91 | 71 | 54
| CABG | | | 70 | 30 | | | 89 | 70 | 59

* This study included patients with single-vessel disease (SVD) only; however, the final percentage of group with SVD was not specified.

** Study design included patients with proximal LAD disease only; however, the final percentage of patients with proximal LAD disease was not reported. Poland did not report data on diseased vessels. VD=diseased vessels; LAD (prox)=proximal left anterior descending artery; LCX=left circumflex artery; RCA=right circumflex artery

Revascularization procedures were generally performed with standard methods for the time period of the trial (Appendix C Table 3). Among patients with multi-vessel disease, more grafts were placed during CABG than vessels dilated during PCI (Appendix C Table 3). Among PCI-assigned patients, use of stents and adjunctive therapy with aspirin, clopidogrel or ticlopidine, and heparin was common in the recent studies, but not in the earlier trials conducted when balloon angioplasty was standard. Arterial grafting with the left internal mammary artery (LIMA) was frequently employed, especially in more recent trials. A minority of CABG procedures were performed off-pump, although a few studies used minimally invasive direct coronary artery bypass (MIDCAB) incisions and beating heart operations to perform CABG in patients with single-vessel LAD disease (Appendix C Table 3).

### Quality of the Randomized Controlled Trials

The quality of most trials was high and 21 trials received a grade of “A” because their randomization methods were sound and clearly explained, their dropout rates were low, and they performed intention-to-treat analyses. The Seoul-Kim ^35^ trial received a grade of “B” because it was not clear that there was concealment of allocation or intention-to-treat, and some data were obtained via a “retrospective review” of charts. The Seoul-Hong ^34^ trial received a grade of “C” because it may not have been truly randomized, as the imbalance between the number of patients assigned to PCI (119) and to CABG (70) is unlikely to have arisen by chance. Neither the authors nor the journal editor responded to requests for clarification of the method of randomization. In addition, the trial from Seoul-Hong is small and has a very short follow-up (six months). We performed sensitivity analyses by removing this study from the analysis of our main outcomes to evaluate the effect of this trial's outcomes on our results. We note that the Seoul-Hong trial is the only included trial that compared PCI using drug-eluting stents with CABG.

### Description of Observational Studies

Our searches identified 357 potentially relevant observational studies: 104 articles from the Scientific Resource Center MEDLINE^®^ search, 161 articles from our MEDLINE^®^ search, 85 articles from expert consultants, and seven from our initial RCT search. Twenty-eight of these related to the generalizability of RCT data and 68 and nine related to key questions 2g and 2h, respectively—the key questions for which insufficient RCT data were available. Key registries identified during the searches are described briefly in Table 7 and are mapped to the key questions for which their results supplemented RCT data. The references presented in Table 7 encompass all articles identified for Key Questions 1a and 2h; additional articles identified for Key Question 2g are presented in Appendix C Tables 8–13. We show comparisons of the RCT and observational studies populations in Table 8 and Figure 2 and describe the salient differences between them in the sections that follow. Details about the results for each key question are presented in the corresponding sections of the report.

Table 7 Overview of selected registries

Registry Name | Description | References from the Registry Addressing Key Questions
| | KQ 1 | KQ 2g | KQ 2h
Alberta Provincial Project for Outcome Assessment in Coronary Heart Disease (APPROACH) | A Multicenter clinical registry of all cardiac catheterization procedures in the Canadian province of Alberta, in the period 1995-1998. | ^147^
American College of Cardiology National Cardiovascular Disease Registry (ACC) | Multicenter voluntary registry of coronary angioplasty procedures. | | ^148^ – ^150^
Angina with Extremely Serious Operative Mortality Evaluation (AWESOME) Registry | A Multicenter clinical registry of patients eligible for the AWESOME trial but not randomized | ^151^ | | ^52^
Bypass Angioplasty Revascularization Investigation (BARI) Registry | A Multicenter registry established in parallel with a randomized clinical trial. Includes patients who were eligible but not randomized, and a sample of patients who were clinically eligible but angiographically excluded. | ^152^
Cleveland Clinic | A single institution clinical registry of all coronary revascularization procedures at a major referral hospital. Reports cover procedures performed 1992-2000. | ^153^ | | ^154,^ ^155^
Duke | A single institution clinical registry of all procedures at a major referral center. Reports cover procedures 1984-2000. | ^156^ – ^159^
Emory | A single institution registry of PCI and CABG procedures, 1980-1994. | ^160,^ ^161^ | | ^162^ – ^166^
Emory Angioplasty Surgery Trial (EAST) Registry | A single center clinical registry of patients eligible for the EAST trial but not randomized. | ^167^
Hospital Corporation of America (HCA) | A multicenter administrative database from a system of 76 hospitals in 17 states performing PCI or CABG 1999-2002. | ^168^
Kansas City (Mid-American Heart Institute) | A single center clinical registry of patients undergoing PCI and CABG 1987-1989 | | | ^169^
Mayo Clinic | A single-center institution registry of all PCI and CABG procedures, 1982-1991 | ^170^
Medicare | A multicenter administrative database from a publicly-funded health insurance program for those 65 and older administered by the US government. | ^171^ – ^176^ | ^177^ – ^185^
New York State Registry (NYSR) | A state mandated clinical registry collecting data from all hospitals in New York State. | ^186^ – ^188^ | ^189^ – ^200^
Northern New England | A Multicenter clinical registry of all five centers in Maine, New Hampshire and Vermont performing coronary revascularization. Reports on the period 1992-1996. | ^201^ – ^203^ | ^204,^ ^205^
Scottish Registry | Multicenter clinical registry of all CABG and PCI procedures in Scotland 1997-2003 | ^206^ | ^207^
Society of Thoracic Surgeons (STS) | Multicenter voluntary registry of cardiac surgery, with procedural data and outcomes from up to 500 sites. | ^208,^ ^209^ | ^210,^ ^211^
Multi-state Registries | NYSR/State of California—Contains data from the NYSR and State of California obtained through Patient Discharge Database of the Office of Statewide Health Planning and Development | | ^212^

® This table presents selected registries used to analyze both the generalizability of the RCT data and address Key Questions left unanswered by the RCTs. Observational studies describing these registries were found through a variety of literature sources, including: MEDLINE searches, Scientific Resource Center supplemental searches, expert input, and web searches. In each of the sections describing the Key Questions, we describe more fully the particular observational studies pertinent to that section.PCI=percutaneous coronary intervention; CABG=coronary artery bypass grafting

Table 8 Comparison of randomized controlled trials and registry populations

Characteristic | Type of Study | Number of trials/studies | Weighted Mean | Weighted Median
Age (Median) | PCI/RCT | 20 | 61.3 | 61.0
| PCI/Registry | 11 | 63.5 | 65
| CABG/RCT | 21 | 61.2 | 61.1
| CABG/Registry | 13 | 65.0 | 67.0
Women (%) | PCI/RCT | 21 | 24.3 | 23.0
| PCI/Registry | 11 | 31.0 | 31.4
| CABG/RCT | 21 | 23.4 | 22.0
| CABG/Registry | 12 | 27.2 | 28.6
White (%) | PCI/RCT | 4 | 86.1 | 91.0
| PCI/Registry | 2 | 87.0 | 87.0
| CABG/RCT | 3 | 90.2 | 89.0
| CABG/Registry | 2 | 89.1 | 89.0
African-American (%) | PCI/RCT | 2 | 5.4 | 5.0
| PCI/Registry | 2 | 6.4 | 6.4
| CABG/RCT | 2 | 6.8 | 7.0
| CABG/Registry | 2 | 5.4 | 5.5
Diabetes (%) | PCI/RCT | 11 | 17.4 | 19.0
| PCI/Registry | 12 | 20.3 | 17.4
| CABG/RCT | 11 | 18.4 | 17.0
| CABG/Registry | 14 | 29.0 | 33.0
HTN (%) | PCI/RCT | 10 | 47.9 | 46.0
| PCI/Registry | 9 | 45.6 | 46.0
| CABG/RCT | 10 | 48.3 | 49.0
| CABG/Registry | 11 | 53.2 | 53.0
Hyper-cholesterolemia (%) | PCI/RCT | 7 | 58.2 | 58.0
| PCI/Registry | 2 | 38.5 | 47.0
| CABG/RCT | 7 | 49.4 | 58.0
| CABG/Registry | 2 | 40.4 | 48.0
Prior MI (%) | PCI/RCT | 9 | 46.6 | 44.0
| PCI/Registry | 10 | 38.8 | 27.0
| CABG/RCT | 9 | 46.1 | 42.0
| CABG/Registry | 12 | 36.6 | 25.0
CHF (%) | PCI/RCT | 1 | 9.0 | 9.0
| PCI/Registry | 11 | 7.8 | 5.3
| CABG/RCT | 1 | 9.0 | 9.0
| CABG/Registry | 12 | 16.9 | 16.0
Current Smoking (%) | PCI/RCT | 7 | 28.6 | 28.0
| PCI/Registry | 6 | 42.8 | 25.0
| CABG/RCT | 7 | 26.1 | 26.0
| CABG/Registry | 6 | 50.9 | 65.0
Stable Angina (%) | PCI/RCT | 7 | 56.7 | 57.0
| PCI/Registry | 3 | 19.7 | 22.0
| CABG/RCT | 7 | 55.6 | 60.0
| CABG/Registry | 3 | 27.5 | 34.0
Unstable Angina (%) | PCI/RCT | 9 | 47.0 | 37.0
| PCI/Registry | 4 | 39.7 | 33.0
| CABG/RCT | 9 | 48.0 | 35.0
| CABG/Registry | 4 | 39.9 | 40.0
EF (Mean) | PCI/RCT | 13 | 59.4 | 59.0
| CABG/RCT | 13 | 59.2 | 60.0
| PCI/Registry | 6 | 53.1 | 53.0
| CABG/Registry | 9 | 50.4 | 50.0
Prior Stroke (%) | PCI/RCT | 3 | 5.6 | 5.0
| PCI/Registry | 2 | 10.5 | 11.0
| CABG/RCT | 3 | 7.1 | 2.0
| CABG/Registry | 2 | 10.5 | 11.0
PVD (%) | PCI/RCT | 6 | 8.8 | 8.0
| PCI/Registry | 3 | 11.8 | 11.0
| CABG/RCT | 6 | 8.5 | 8.0
| CABG/Registry | 3 | 23.0 | 18.0
Family history of CAD (%) | PCI/RCT | 3 | 43.4 | 39.0
| PCI/Registry | 1 | 47.0 | 47.0
| CABG/RCT | 3 | 44.9 | 42.0
| CABG/Registry | 1 | 51.0 | 51.0
Number Diseased Vessels (Mean) | PCI/RCT | 7 | 2.3 | 2.4
| PCI/Registry | 6 | 2.1 | 2.2
| CABG/RCT | 7 | 2.3 | 2.4
| CABG/Registry | 8 | 2.6 | 2.7

PCI=percutaneous coronary intervention; CABG=coronary artery bypass grafting; RCT=randomized controlled trials; HTN=hypertension; MI=myocardial infarction; CHF=congestive heart failure; EF=ejection fraction; PVD=peripheral vascular disease; CAD=coronary artery disease

Table 13 Quality of life information reported by randomized controlled trials

Trial | Instrument | Measure | Time point | PCI | CABG | Intervention Favored
ARTS | Visual Analog Scale | Average Thermometer (VAS 0–100) | Year 1 | 78 | 80 | NS
ARTS | Euroqol | Average Summary (mobility, self-care, usual activity, pain or discomfort, anxiety or depression; scale 0–100) | Year 1 | 86 | 87 | NS
AWESOME | SF-36 | Physical component summary score (mean) | 6 months | 38.7 | 37.3 | NS
AWESOME | SF-36 | Mental component summary score (mean) | 6 months | 45.5 | 46.1 | NS
CABRI | Nottingham Health Profile (part I) | Total Score | Baseline to Year 1 | -8.7 +/-16.9 | -11.9 +/-19.5 | NS
| | Emotional reaction (change in score) | Baseline to Year 1 | -8.3 +/- 20.7 | -8.4 +/- 25.0 | NS
| | Sleep (change in score) | Baseline to Year 1 | -2.6 +/- 31.4 | -13.7 +/- 33.4 | NS
| | Energy (change in score) | Baseline to Year 1 | -17.3 +/- 38.1 | -28.8 +/- 39.3 | CABG^§^
| | Pain (change in score) | Baseline to Year 1 | -9.6 +/- 25.8 | -11.1 +/- 21.5 | NS
| | Physical mobility (change in score) | Baseline to Year 1 | -7.0 +/- 16.0 | -7.3 +/- 21.5 | NS
| | Social relations (change in score) | Baseline to Year 1 | -6.0 +/- 20.5. | -3.7 +/- 26.0 | NS
CABRI* | Nottingham Health Profile (part II); % change in perceived health problems | At work | Baseline to Year 1 | 15 | 20 | NS
| | Household chores | Baseline to Year 1 | 21 | 22 | NS
| | Social life | Baseline to Year 1 | 13 | 15 | NS
| | Family life | Baseline to Year 1 | 8 | 14 | NS
Myoprotect I | SF-12 | Questionnaire score (mean) | Year 1 | 32.8 +/- 9 | 30.6 +/- 8 | NS
Octostent | | Quality-adjusted life years | Year 1 | 0.82 | 0.79 | NS
Octostent | Euroqol | Summary score (estimated) | Year 1 | 0.82 | 0.83 | NS
Octostent | SF-36 | | 6 months*
| | | Year 1**
RITA | Nottingham Health Profile (Part I) | Mean Quality of Life (energy, pain, emotional reaction, sleep, social isolation and mobility) (change in score) | 6 months | 4.83 | 6.04 | CABG
| | | 12 months | At 12 months, the difference between PCI and CABG in score change was 0.79, with CABG patients having a larger change | | NS
SIMA | SF-36 | | 9–15 months*
| SAQ | Physical Limitation | 9–15 months | 86 | 91 | NS
| | Quality of Life | 9–15 months | 79 | 76 | NS
EAST | | Able to engage in moderate or strenuous activity | Year 3 | 47 | 44 | NS
| | Overall health good or very good | Year 3 | 61.1 | 64 | NS
| | Complete recovery | Year 3 | 58.7 | 69 | NS
SoS | SAQ | Physical Limitation | 6 months | 73.6 | 76 | NS
| | Quality of Life | 6 months | 65.4 | 69 | CABG^§^
| | Physical Limitation | Year 1 | 75.2 | 76 | NS
| | Quality of Life | Year 1 | 69.8 | 71 | NS
AMIST | SAQ | Physical Limitation | 6 months | 76.3 | 78.6 | NS
| | Quality of Life | 6 months | 68.1 | 68 | NS
| | Physical Limitation | Year 1 | 80.4 | 81 | NS
| | Quality of Life | Year 1 | 72.6 | 71.5 | NS
| SF-36 | Physical Component Summary Score | 6 months | 37.4 | 38.0 | NS
| | Mental Component Summary Score | 6 months | 51.1 | 52.4 | NS
| | Physical Component Summary Score | Year 1 | 37.7 | 39.4 | NS
| | Mental Component Summary Score | Year 1 | 51.4 | 55.0 | CABG^§^
| Euroqol | Utility | 6 months | 0.78 | 0.80 | NS
| | Health Status | 6 months | 74.3 | 79.7 | NS
| | Utility | Year 1 | 0.77 | 0.82 | NS
| | Health Status | Year 1 | 74.6 | 81.7 | NS
BARI | Duke Activity Status Index | (change in score) | Year 1 | 4.4 | 7.0 | CABG^§^
| | (change in score) | Year 2 | 3.2 | 5.5 | CABG^§^
| | (change in score) | Year 3 | 3.2 | 5.6 | CABG^§^
| | (change in score) | Year 4 | 2.6 | 4.3 | NS
| | (change in score) | Year 5 | 2.0 | 3.6 | NS
| Nottingham Health Profile (Part II); % change in perceived health problems | At work | Year 1 | 25 | 20 | NS
| | Household chores | Year 1 | 32 | 28 | CABG^§^
| | Social life | Year 1 | 19 | 17 | NS
| | Family life | Year 1 | 16 | 13 | NS
| | At work | Year 3 | 19 | 22 | NS
| | Household chores | Year 3 | 37 | 35 | NS
| | Social life | Year 3 | 24 | 22 | NS
| | Family life | Year 3 | 19 | 18 | NS
| | At work | Year 5 | 16 | 16 | Neither
| | Household chores | Year 5 | 40 | 36 | NS
| | Social life | Year 5 | 27 | 27 | Neither
| | Family life | Year 5 | 20 | 19 | NS
| RAND Mental Health Inventory | (change in score) | Year 1 | 1.8 | 1.8 | Neither

PCI=percutaneous coronary intervention; CABG=coronary artery bypass grafting; NS=no significant difference between PCI and CABG;

§ p<0.05

* No summary scores were provided; however, the scores on each section are available in the text. There was no statistically significant difference between PCI and CABG scores in any domain.

** No summary scores were provided; however, the scores in each domain are available in the text. Patients in the CABG group scored significantly higher (p=0.03) than patients in the PCI group in the domain of General Health Perception.

Figure 2. Comparison of randomized controlled trials and registry populations

### Quality of Observational Studies

Overall the quality of the observational studies was high and each received an “A” grade on the basis of enrolling large numbers of subjects who had good follow-up and adequate descriptions of most key subject characteristics.

## Key Question 1a. In patients with ischemic heart disease, and angiographically-proven single or multi-vessel disease, what is the comparative effectiveness of PCI compared to CABG, in reducing the occurrence of adverse objective outcomes and improving subjective outcomes?

For consistency, we adopted the following conventions for presenting the results: we present the summary risk difference as a percent difference, all outcomes were calculated in their “positive frame” (e.g., survival rather than mortality, freedom from angina rather than angina, etc.), and all of the forest plots are oriented such that the studies on the left of the origin favor CABG and those to the right of the origin favor PCI. We present PCI-CABG risk differences such that positive numbers favor PCI and negative numbers favor CABG. Similarly, PCI/CABG odds ratios greater than 1.0 favor PCI and ratios less than 1.0 favor CABG.

### Short-Term/Procedural Outcomes

Short-term, procedural complications were typically more common among CABG-assigned patients than PCI-assigned patients in the randomized trials (Appendix C Table 4); however, these differences did not generally reach statistical significance.^b^

#### Procedural survival

Short-term survival in randomized trials was relatively high for both procedures: only 59 of the 5019 PCI recipients died and only 85 of the 4944 CABG recipients died. When data from all randomized trials were combined, procedural survival did not differ significantly between procedures: PCI-CABG procedural survival difference was 0.1 percent (CI: -0.3 percent to +0.6 percent) and PCI/CABG odds ratio (OR) 1.4 (CI: 0.98 to 1.97) (Figure 3 and Appendix C Figure 1).

Figure 3. Procedural survival

While procedural survival was not specifically reported by the SoS trial, we extracted it from the Kaplan Meier curve. Also, two trials, AWESOME and Myoprotect I had significantly worse short- and long-term outcomes than the other trials (Figure 4), likely because these trials enrolled patients who were more acutely ill. We recalculated the procedural survival excluding AWESOME and Myoprotect; the difference in procedural survival remained small (PCI-CABG procedural survival difference: 0.4 percent [CI: -0.1 percent to +0.8 percent]; PCI/CABG odds ratio: 1.4 [CI: 0.96 to 2.08]).

Figure 4. Survival (all studies by procedure)

We also examined procedural survival according to whether the trial (1) enrolled single- or multi-vessel disease patients and (2) used balloon angioplasty or stents (Figures 5 and 6). We found no statistically significant differences between PCI and CABG recipients compared across these parameters. Similarly, we found no statistically significant differences between PCI and CABG when we examined the procedural survival according to whether the trial used the more invasive on-pump/median sternotomy approaches versus MIDCAB/off-pump techniques (Appendix C Figure 2).

Figure 5. Comparison of procedural survival in balloon angioplasty or stent trials versus CABG in patients with SVD

Figure 6. Comparison of procedural survival in balloon angioplasty or stent trials versus CABG in patients with MVD

The procedural survival in PCI-CABG RCTs was higher than that reported by large clinical registries and administrative databases, even after taking into account the secular trends towards lower procedural risk over time for both CABG and PCI. For example, analyses from the Society of Thoracic Surgeons (STS) database has found that unadjusted operative survival rose from about 96.8 percent to 97.8 percent between 1996 and 2005, despite higher risk profiles among CABG patients (Table 9). ^208^ A detailed report of procedural survival in the STS database by Ferguson et al. found that operative survival rose from 96.1 percent in 1990 to 97.0 percent in 1999. ^209^ A study of CABG and PCI procedural outcomes from the Hospital Corporation of America from 1999 to 2002 found that, for the entire period, PCI survival was 98.75 percent vs. 97.37 percent for CABG and that survival for both procedures rose over time. ^168^ To evaluate whether the difference in procedural survival has changed over the past decade in randomized trials, we calculated the procedural survival difference according to the final year of subject recruitment (Figure 7). This analysis supports the conclusions of the large observational studies: namely, that the procedural survival of both procedures has increased over time and that the procedural survival after PCI is higher, albeit not statistically significantly so.

Table 9 Procedural survival reported in observational studies

Study Reference | Registry | Population | Intervention | Number of Patients | Demographics | | | | | Unadjusted Procedural Survival %
| | | | | Mean Age | Women % | White % | Diabetes % | Prior MI %
Feit et al. ^152^ | BARI | Patients in the registry arm of the BARI trial who underwent PCI or CABG | PCI | 1189 | 61.0 | 26 | 94 | 15 | 50 | 99.3
| | | CABG | 625 | 62.5 | 26 | 96 | 19 | 50 | 98.2
Brenner et al. ^153^ | Cleveland | Patients with MVD who underwent PCI or CABG 1995-1999 | PCI | 872 | 65 | 32 | | 30 | 48 | 98.7
| | | CABG | 5161 | 64 | 27 | | 40 | 58 | 98.9
King et al. ^167^ | EAST registry | Patients in the registry arm of the EAST trial who underwent PCI or CABG | PCI | 168 | | | | | | 99.4
| | | CABG | 270 | | | | | | 98.9
Weintraub et al. ^160^ | Emory | Patients who underwent CABG 1973-1979 | CABG | 3939 | 54.5 | 18.9 | | 12.5 | 54.1 | 99.0
Weintraub et al. ^161^ | Emory | Patients with 2VD who underwent PCI or CABG 1984-1985 | PCI | 415 | 57 | 18 | | 10 | 44 | 100.0
| | | CABG | 454 | 60 | 20 | | 15 | 55 | 98.9
Mack et al. ^168^ | Hospital Corporation of America (HCA) | Patients undergoing either PCI or CABG | PCI 1999 | 26,868 | 65.6 | 35 | | 25.6 | 45.6 | 98.6
| | | PCI 2002 | 32,060 | | | | | | 98.8
| | | On-pump CABG 1999 | 12,786 | 66.5 | 29 | | 33.3 | 40.4 | 97.1
| | | On-pump CABG 2002 | 11,418 | | | | | | 97.8
| | | Off-pump CABG 1999 | 3024 | | | | | | 97.6
| | | Off-pump CABG 2002 | 3474 | | | | | | 97.6
Harris et al. ^170^ | Mayo | Patients who underwent PCI or CABG 1982-1991 | PCI 1/1982–4/1985 | 636 | 58 | 25 | | 8 | 44 | 97.0
| | | PCI 5/1985–8/1988 | 1804 | 62 | 26 | | 14 | 45 | 98.0
| | | PCI 9/1988–12/1991 | 2497 | 65 | 29 | | 18 | 51 | 96.0
| | | CABG 1/1982–4/1985 | 2250 | 61.6 | 19.4 | | | 57.0 | 96.3
| | | CABG 5/1985–8/1988 | 2705 | 64.4 | 22.4 | | | 55.6 | 96.3
| | | CABG 9/1988–12/1991 | 2144 | 65.8 | 24.3 | | | 50.7 | 96.7
Rosen et al. ^171^ , Geraci et al. ^172^ , and Rosen et al. ^173^ | Medicare | Random sample of patients admitted 1/1985–6/1986 in Alabama, Arizona, Indiana, New York, Pennsylvania, Utah, and Wisconsin | PCI | 693 | 70.4 | 37.5 | 97 | 15.6 | 31 | 96.5
| | | CABG | 2213 | 70.7 | 29.6 | 97.6 | 19.8 | 44 | 93.4
Peterson et al. ^174^ | Medicare | Patients aged 65 years or older who had angioplasty or bypass surgery from 1987-1990 | PCI | 225,915 | 71.7 | 42.6 | 94.8 | | | 96.7
| | | CABG | 357,885 | 71.6 | 33 | 95.2 | | | 94.2
Hartz et al. ^175^ | Medicare | Patients aged 65 years or older who had angioplasty or bypass surgery in 1985 | PCI | 25,423 | 68.7 | 38.4 | | | | 96.2
| | | CABG | 71,243 | 69.4 | 31.2 | | | | 93.6
Venkatappa et al. ^176^ | Medicare | Patients who had a CABG 7/1995–6/996 and patients who had a CABG surgery from 7/1998 through 12/1998 | CABG in 1995-1996 | 2312 | 70.8 | 33.7 | 94.5 | 27 | | 96.4
| | | CABG 1998 | 926 | 71.6 | 35.2 | 93.4 | 31.9 | | 95.1
Likosky et al. ^202^ | Northern New England | Patients undergoing isolated CABG between 1/1992 and 12/2001 | CABG | 31,592 | | | | | | 96.6^a^
Malenka et al. ^201^ | Northern New England | Patients with MVD who underwent PCI or CABG 1994-2001 | PCI | 4295 | 62.2 | 30.4 | | 26.3 | 48.5 | 99.5*
| | | CABG | 10198 | 64.5 | 26.7 | | 34.4 | 44.7 | 98.3*
Mc Grath et al. ^203^ | Northern New England | Patients undergoing PCI 1990-1997 | PCI 1990-1993 | 13,014 | 60.9 | 31.4 | | 21.2 | 29.8 | 99.0
| | | PCI 1994–6/95 | 7,248 | 61.3 | 32.3 | | 21.4 | 26.5 | 98.9^b^
| | | PCI 7/95–1997 | 14,490 | 61.9 | 32.4 | | 22.3 | 23.5 | 98.8^b^
Hannan et al. ^186^ | NYSR | All patients in New York State undergoing PCI from 1/91–6/91 | PCI | 5827 | | 29.6 | | | | 99.4
Hannan et al. ^187^ | NYSR | All patients in New York State who underwent isolated PCI or CABG 1993-1995 | PCI | 29,930 | | 32.0 | | 17.4 | | 99.6
| | | CABG | 29,646 | | 28.6 | | 27.3 | | 98.1
Hannan et al. ^188^ | NYSR | All patients in New York State who underwent PCI or CABG1997-2000 | PCI | 22,102 | 65** | 31.4 | 87 | 25.3 | 27.4 | 99.3
| | | CABG | 37,212 | 67** | 29.1 | 89.2 | 33.2 | 25.0 | 98.2
Hannan et al. | NYSR | All patients in New York State who underwent CABG in 2002 | CABG | 16,120 | | | | | | 97.7
Pell et al. ^206^ | Scottish | All patients in Scotland undergoing PCI or CABG between 4/97 and 3/99. | PCI | 4775 | 61** | 33 | | 11 | | 98.7
| | | CABG | 5691 | 63** | 24 | | 12 | | 96.8
Ferguson et al. ^209^ | STS | Patients undergoing isolated CABG from 1990-1999 | CABG 1990 | 31,444 | 63.7 | 25.7 | 94.4 | 21.4 | 59 | 96.1^c^
| | | CABG 1999 | 182,407 | 65.1 | 28.7 | 89.8 | 32.7 | 49 | 97.0^c^
Steinbrook et al. ^208^ | STS | Patients undergoing CABG from 1996 to 2005 | CABG 1996 | | | | | | | 96.8
| | | CABG 2005 | | | | | | | 97.8

a Adjusted Survival: CABG=96.6%;

b Adjusted Survival: PCI 1990-1993=98.8%; PCI 1994–6/95=98.9%; PCI 7/95–1997=98.9%;

c Adjusted Survival: CABG 1990=95.1%; CABG 1999=97.1%

* Adjusted procedural Survival;

® Median; PCI=percutaneous coronary intervention; CABG=coronary artery bypass grafting; MVD=multi-vessel disease; VD=diseased vessels; MI=myocardial infarction; NYSR=New York State Registry; STS=Society of Thoracic Surgeons. The observational studies presented in this table were derived from our searches for representative registries and large administrative data, from our MEDLINE search, and from expert advisors.

Figure 7. Comparing the procedural survival by final year of patient recruitment

We identified six articles that compared short-term procedural outcomes of CABG and PCI among the US Medicare population (Table 9). The minimum age of patients included in these studies was 65 years which is approximately four years older than the average age of patients in the RCTs, and most were conducted in the 1980's. Procedural survival in the unselected Medicare population was substantially lower than in the randomized trials both for PCI and for CABG. The procedural survival of CABG patients was consistently lower than for PCI patients.

#### Other procedural outcomes

Freedom from procedural stroke was reported by 16 trials, and the freedom from stroke was significantly lower after CABG than after PCI (98.8 percent vs. 99.5 percent) (Figure 8). The PCI-CABG difference in freedom from procedural stroke of 0.6 percent (CI: +0.2 percent to +1 percent, p=0.002) and PCI/CABG odds ratio 1.96 (CI: 1.16 to 3.3, p=0.01) (Appendix C Figure 3) were statistically homogeneous.

Figure 8. Freedom from procedural stroke

We found that the definition of procedural myocardial infarction varied among studies and that post-procedure serial monitoring of electrocardiograms and serum biomarker levels was not routine, so that ascertainment of procedural myocardial infarctions may not have been complete. Freedom from procedural myocardial infarctions was somewhat heterogeneous among the trials (heterogeneity statistics for the PCI-CABG difference in freedom from procedural MI: Q-value 35.7, p value 0.01; I^2^ 46.8). However, when we performed sensitivity analyses, removing one study at a time, the overall results did not change. Freedom from procedural myocardial infarction was slightly higher among PCI recipients but was not statistically significant: PCI-CABG difference in freedom from procedural MI 0.1 percent (CI: -1.0 percent to +1.2 percent) (Figure 9) and PCI/CABG odds ratio 1.04 (CI: 0.71 to 1.5) (Appendix C Figure 4).

Figure 9. Freedom from procedural MI

Other procedural outcomes were not generally reported or consistently defined by clinical trials, making it difficult to compare quantitatively the risk of non-fatal procedural adverse events such as pulmonary complications, renal failure, infections, heart failure, and arrhythmias.

#### Quality of evidence for procedural outcomes

We rated the quality of the evidence providing short term-procedural data as acceptable for mortality and stroke given that it comes from RCTs that were consistent and did not appear to be significantly affected by publication bias (Appendix C Figure 5). Event rates were low, however, which reduces the strength of inference, especially for mortality. The quality of the evidence regarding short term-procedural data for MI was weak, however. Although 19 RCTs of high quality reported procedural MI data, the results and the definitions of procedural MI were significantly heterogeneous.

### Long-Term Outcomes

#### Survival

Survival data from the individual RCTs are presented in a standard format (Figure 10) to facilitate comparison of long-term outcomes. Overall survival across all randomized trials did not differ significantly between CABG and PCI between one and five years of follow-up: PCI-CABG survival difference at each time point was less than 1 percent. We present the forest plots of survival at six months to five years in Appendix C Figures 6–15. The one- and five-year survival data for the 11 studies that reported survival at both of these intervals (Figure 11) demonstrated no significant difference between groups at these intervals.

Figure 10. Survival reported by each RCT

Figure 11. PCI-CABG survival difference from the 11 RCTs reporting both 1 and 5 year survival data

Figure 15. Comparison of survival between RCTs and registries (AWESOME, BARI, and EAST)

Similarly, there was no significant difference in the comparative survival benefit in either the first or fifth year post-procedure between trials enrolling patients with single-vessel LAD disease and trials enrolling patients with multi-vessel disease (Figure 12).

Figure 12. Comparison of single (SVD) with multi-vessel (MVD) survival at 1 and 5 years

Overall, the survival difference between PCI and CABG favored CABG in the older trials that employed balloon angioplasty and trended toward favoring PCI in the more recent trials that employed coronary stents (Appendix Figures 16–17). However, the recent trials included more patients with single-vessel LAD disease and had much shorter follow-up. In Figures 13 and 14, we present the survival differences between PCI and CABG separately for the single-vessel versus multi-vessel disease trials. At one year, in trials of single-vessel-LAD disease, survival in studies using balloon angioplasty was 1 percent greater for CABG recipients (CI: -5 percent to +2 percent) but was 0.1 percent greater for PCI recipients (CI: -4 percent to +4 percent) for trials using stents; these differences were not statistically significant. Similarly, among trials of multi-vessel disease, the survival difference at one year for balloon trials was 0.6 percent greater for CABG (CI: -1.5 percent to +0.4 percent) versus a survival difference among stent trials of 1.4 percent greater for PCI (CI: -1 percent to +3.8 percent); again, these differences were not statistically significant (Figure 13). The same pattern was also evident at five years (Figure 14). Odds ratios demonstrate the same trend found using risk differences.

Figure 13. Comparison of one-year survival in balloon angioplasty or stents versus CABG in patients with MVD

Figure 14. Comparison of five-year survival in balloon angioplasty or stents versus CABG in patients with MVD

To evaluate the generalizability of the RCT survival results in non-RCT settings, we examined survival data from registries associated with clinical trials. However, interpretation of these results is complicated by potential sources of bias in treatment allocation and the need for survival outcomes adjusted for key factors likely to affect mortality (e.g., age, co-morbid conditions, and severity of CAD). Three of the randomized trials (AWESOME, BARI, and EAST) reported the details of their screening as well as the characteristics and outcomes of the “eligible, not randomized” patients (Appendix C Tables 5 and 6), especially those who chose PCI. We note that these outcome data were not adjusted to reflect the differences in baseline characteristics. Survival in eligible, not randomized patients was better than that of randomized patients in two trials, but not in the third trial (Figure 15). It is, therefore, hard to draw general conclusions, especially since patients and their physicians may decline randomization based on the perception that the patient is either too sick or too well to leave the choice of therapy to chance.

Five major clinical registries ^147,^ ^157,^ ^187,^ ^201,^ ^206^ included more than 1000 PCI and 1000 CABG patients, reported long-term survival patterns, and used multivariable statistical methods to adjust for clinical differences in patients selected for PCI and CABG (Table 10). These registries reported striking differences in the patients selected for these two procedures, with most patients with single-vessel disease receiving PCI and most patients with triple-vessel disease receiving CABG. Across the entire spectrum of disease severity, the CABG/PCI hazard ratio ranged from 0.48 ^206^ to 0.86 ^201^ favoring CABG. The CABG/PCI hazard ratio was significantly affected, however, by extent of coronary disease; in the Duke registry the CABG/PCI hazard ratio varied from 2.1 among patients with the least severe disease to 0.45 in patients with the most severe disease. ^157^ Similar variations in the hazard ratio according to severity of disease were reported by the Alberta, ^147^ Northern New England ^201^ and New York State ^187^ registries. In the patients with intermediate extent of disease who were most similar to patients enrolled in randomized trials, the clinical registries reported PCI/CABG hazard ratios were closer to 1.0.

Table 10 Long-term survival in major clinical registries

Name | Centers | Enrollment Interval | N PCI | N CABG | 1VD | 2VD | 3VD | HR Overall CABG/PCI | HR Subgroup Range*
NY State ^188^ | 35 | 1997-2000 | 22102 | 37212 | 0% | 80% | 20% | NR | 0.64 to 0.75
NY State ^187^ | 32 | 1993-1995 | 29930 | 29646 | 40% | 28% | 32% | NR | 0.6 to 1.7
Duke ^157^ | 1 | 1986-1990 | 2924 | 3890 | 37% | 32% | 32% | NR | 0.4 to 2.1
N New England ^201^ | 5 | 1994-2001 | 4295 | 10198 | 0% | 60% | 40% | 0.86 | 0.60 to 0.98
Alberta ^147^ | 4 | 1995-1998 | 3540 | 3782 | 0% | 31% | 70% | 0.81 | 0.3 to 1.43
Scotland ^206^ | 6 | 1997-1999 | 4775 | 5115 | 23% | 18% | 59% | 0.48 | NR

PCI=percutaneous coronary intervention; CABG=coronary artery bypass grafting; VD=vessels diseased; HR=hazard ratio; MVD=multi-vessel disease

* CABG/PCI Hazard Ratio from most severe to least coronary artery disease

#### Freedom from angina

Freedom from angina was more common after CABG than after PCI between one and five years post-procedure (PCI-CABG difference in freedom from angina ranged from -5 percent to -8 percent; PCI/CABG odds ratio ranged from 0.5 to 0.66, p<0.0001 at 1-, 3-, and 5-years) (Figure 16). At one year, freedom from angina was 75 percent in PCI-assigned patients and 84 percent in CABG-assigned patients. At five years, freedom from angina grew to 79 percent in PCI-assigned patients and remained 84 percent in CABG-assigned patients. It is uncertain whether the greater angina relief was due to more complete initial revascularization with surgery or because of restenosis after PCI.

Figure 16. Angina relief

The relationship between residual myocardial jeopardy (a measure of the completeness of revascularization) and freedom from angina after PCI or CABG was examined in the angiographic substudy of the BARI trial. ^62,^ ^213^ At one year after randomization, myocardial jeopardy was significantly lower (p<0.01) in the sample of 135 patients randomized to CABG (14.1 percent) than in the sample of 135 patients randomized to PCI (25.5 percent). Freedom from angina at one year was in 88 percent of the CABG-assigned patients versus 70 percent of the PCI-assigned patients (p=0.004). Myocardial jeopardy on the one year angiogram was a significant predictor of angina at one year (PCI/CABG odds ratio 1.28 per 10 percent increment in jeopardy), but initial randomization assignment remained a significant predictor of angina even after adjustment for the degree of myocardial jeopardy, suggesting that additional mechanisms beyond completeness of revascularization may affect angina after CABG. ^213^ At five years of follow-up, progression of disease in the untreated coronary arteries was the predominant predictor of late angina in patients enrolled in the BARI angiographic substudy. ^62^

#### Freedom from repeat revascularization

Individual randomized trials provide clear and consistent evidence that freedom from repeat coronary revascularization was much higher after CABG than after PCI (Figure 17). At 1-year, patients who received PCI required 23 percent more repeat procedures than CABG recipients (p <0.0001) (PCI/CABG OR 0.11; CI: 0.07, 0.17). This difference climbed to 33 percent at five years (p<0.0001) (PCI/CABG OR 0.13; CI: 0.11, 0.16). However, although the trials consistently favored CABG, they were statistically heterogeneous (Figure 17).

Figure 17. Freedom from repeat revascularization

This gap between PCI and CABG was wider in trials that used balloon angioplasty than in more recent trials that used coronary stents (Figure 18 and Table 11). Nevertheless, patients undergoing PCI with stents require repeat procedures considerably more often than patients undergoing CABG.

Table 11 Absolute rates of freedom from repeat revascularization

Year Post-procedure | All Studies | | Balloon-Era Trials | | Stent-Era Trials
| PCI | CABG | PCI | CABG | PCI | CABG
1 | 73.5% | 96.2% | 58.3% | 96% | 81.9% | 96.3%
3 | 61.6% | 91.6% | 51.8% | 88.1% | 64.5% | 92.9%
5 | 53.9% | 90.2 | 51.5% | 90.1% | 59.9% | 90.3%

PCI=percutaneous coronary intervention; CABG=coronary artery bypass grafting

Figure 18. Freedom from repeat revascularization at 5 years: balloon angioplasty or stents versus CABG trials

#### Freedom from myocardial infarction

Ten studies reported myocardial infarction in follow-up (Appendix C Figure 18). Between one and five years after the procedure, freedom from myocardial infarction decreased among all patients, but at a somewhat higher rate for PCI recipients. However, the PCI-CABG differences in freedom from myocardial infarction were small (less than 1 percent) (PCI/CABG odds ratio ranged from 0.87 to 0.92) and did not achieve statistical significance.

#### Freedom from stroke

Seven studies reported freedom from stroke in follow-up (Table 12). These studies were heterogeneous in terms of the types of stroke reported (i.e., fatal, non-fatal, not specified) and in terms of their results. For example, at one year, two trials found greater freedom from strokes among PCI patients, one trial found great freedom from strokes among CABG patients, and two found no differences between the procedures. This heterogeneity and the paucity of studies reporting strokes beyond one year precludes us from drawing conclusions about the comparative effects of PCI and CABG on freedom from strokes after the initial procedural period.

Table 12 Long-term freedom from stroke

Trial | Procedure | N at randomization | Procedural (%) | 6 months (%) | Year 1 (%) | Year 2 (%) | Year 3 (%) | Year 4 (%) | Year 5 (%)
ARTS | PCI | 600 | 590 (98.3) | 590 (98.3)* | 590 (98.3) | | 580 (96.7) | | 577 (96.1)
| CABG | 605 | 592 (97.9) | 592 (97.9)* | 592 (97.9) | | 585 (96.7) | | 584 (96.5)
Groningen | PCI | 51 | 50 (98.0) | 50 (98.0)* | 50 (98.0)* | 50 (98.0)* | 50 (98.0) | 49 (96.1)
| CABG | 51 | 51 (100) | 51 (100)* | 51 (100)* | 51 (100)* | 51 (100) | 51 (100)
Leipzig | PCI | 110 | 110 (100) | 108 (98.2)
| CABG | 110 | 109 (99.1) | 109 (99.1)
MASS | PCI | 72 | 72 (100) | | | | | | 71 free from fatal stroke
| CABG | 70 | 70 (100) | | | | | | 70 free from fatal stroke
Octostent | PCI | 138 | 138 (100) | 138 (100)* | 138 (100)
| CABG | 142 | 142 (100) | 142 (100)* | 142 (100)
Poland | PCI | 50 | 50 (100)* | 50 (100) | 50 (100) | 50 (100)
| CABG | 50 | 50 (100)* | 50 (100) | 50 (100) | 50 (100)
SoS | PCI | 488 | | | 481(98.6) free from non-fatal strokes
| CABG | 500 | | | 492 (98.4) free from non-fatal strokes

Note: Most studies did not specify fatal or non-fatal strokes, those that did are so noted.

* Data marked with an asterisk were imputed from knowing that the stroke risk did not change between the preceding and subsequent time intervals.

#### Quality of life

Data on quality of life and functional status were collected by 11 trials (Table 13). The measures chosen were different from trial to trial, however, with the SF-36 or its subscales used by four studies, the Seattle Angina Questionnaire (SAQ) used by two studies, the Nottingham Health Profile by two studies, the EuroQol by two studies, and the Duke Activity Status Index (DASI) by one study. In general, these quality of life scores were higher among CABG patients over one to three years of follow-up; however, many trials reported no significant differences between PCI and CABG recipients. Quality of life scores were strongly correlated with the presence and severity of angina in the RITA trial, and change in quality of life scores was significantly related to relief of angina in the BARI trial. Since generally accepted models suggest that symptoms mediate the effect of disease on quality of life, the comparative quality of life outcomes are consistent with the greater relief of angina by CABG over the first few years of follow-up.

#### Cognitive function

Several studies of CABG have used sensitive tests of cognitive function and documented declines from baseline to short-term follow-up (two to six weeks) after the procedure, with substantial recovery by three to six months. The mechanism responsible for this effect has not been fully established.

Despite the widespread concerns about cognitive function, only two PCI-CABG trials included detailed cognitive function testing. The BARI trial assessed cognitive function five years after randomization in a substudy of 125 patients. ^73^ There was no significant difference between PCI and CABG on any of the five measures of cognitive function (Logical and Figural Memory Scales, Wechsler Memory Scale, the Digit Symbol and Digit Span Subtests, and Part B of the Reitan Trail Making Test). The SOS Trial ^141^ measured a battery of five cognitive function tests in a substudy of 145 patients at baseline, six months and twelve months. There were no significant differences between PCI and CABG patients in follow-up on any of the measures (Digit Span Forward and Backward, Visual Reproduction, Bourdon, and Block Design). These two randomized substudies are too small to provide a definitive conclusion about the comparative effects of CABG and PCI on cognitive function.

#### Cost

Cost was examined in ten trials (Figure 19), although the methods of cost determination varied among these trials, which were conducted in the United States, Europe, and South America, and which have quite different health care systems. Consequently, we normalized costs by dividing the cumulative costs for PCI patients by the cumulative costs for CABG patients, which eliminates the variations in monetary units and in costing methods between trials. In all but one trial, PCI-assigned patients had much lower initial costs than CABG-assigned patients, but the difference in costs between PCI and CABG narrowed substantially over subsequent follow-up. (The exception to this was the ERACI trial which employed a different method of accounting for the cost of stents than was used in other trials.) In medium to long-term follow-up, PCI-assigned patients had only modestly lower costs (roughly 5 percent). These same trends are apparent in both balloon angioplasty trials and in trials that used coronary stents (Figure 19).

Figure 19. Comparative cost data

#### Other outcomes of interest

There were several additional long term outcomes that we were interested in for which neither the RCTs nor the registries provided data. These included information regarding the comparative effectiveness of PCI and CABG on congestive heart failure, chronic pulmonary conditions, chronic renal failure, cardiac arrhythmias, target lesion revascularization, restenosis or graft closure, and readmission rates.

#### Quality of evidence for Key Question 1a

Given the large sample of generally consistent RCT results, the quality of the evidence addressing Key Question 1a was robust for most outcomes. However, MI and QOL were both rated acceptable; MI received this rating due to heterogeneity in the methods used to classify and assess patients for MI, and QOL received this rating due to inconsistency of findings across the studies. Cognitive function was rated weak given the paucity and heterogeneity of that literature.

## Key Question 1b. Over what period of time are the comparative benefits of PCI and CABG sustained?

Coronary revascularization with either PCI or CABG treats a limited number of localized obstructions within the vascular bed. However, coronary atherosclerosis is a diffuse and progressive disease process, so revascularization is inherently limited and does not “cure” the underlying disease. Revascularization does not replace the need for ongoing medical therapies, including antiplatelet agents, cholesterol reduction, smoking cessation, control of hypertension and diabetes, and lifestyle modification. Progressive coronary disease in untreated segments of the coronary arterial system, as well as late deterioration of vein grafts, surgical anastamoses, dilated segments, and implanted stents may lead to subsequent events. Long-term comparative results of PCI and CABG are important for assessing the durability of these techniques.

The follow-up reported in the RCTs ranged from six months to 13 years. Eleven trials (randomizing 7,412 patients, 77 percent of all patients enrolled in the trials) have reported two or more years of follow-up and ten trials (randomizing 6,314 patients, 65 percent of all patients enrolled) have reported five or more years of follow-up.

The PCI-CABG survival difference in these 11 trials was +0.1 percent at one year and -0.6 percent at five years (Figure 11). There is no solid evidence that the survival difference changed significantly between one year and five years. (An analysis of odds ratios provided a similar result.)

More extended follow-up of PCI and CABG trials would be desirable to establish whether the well-known tendency of saphenous vein grafts to deteriorate over time affects late comparative outcomes. Only four trials reported follow-up beyond five years (BARI, EAST, GABI, and RITA). The GABI study has reported the longest follow-up of any randomized trial and found the Kaplan-Meier survival curves crossed three times between two and seven years of follow-up, with the advantage for CABG over PCI between seven and ten years almost gone at 13 years. In the EAST trial, the small survival advantage for CABG at three years (0.9 percent) grew slightly at five years (3.3 percent) and remained essentially unchanged at eight years (3.4 percent). In the BARI trial, the CABG survival advantage was 3.0 percent at five years, 3.5 percent at seven years, and 2.5 percent at ten years. ^85^ In the RITA trial, the PCI-CABG survival difference was 0 percent at five years and 1.4 percent at seven years. These four trials with long-term follow-up show no consistent pattern in PCI-CABG survival difference after five years.

The advantage of CABG in relief of angina grew progressively smaller between one year (8.5 percent) and five years of follow-up (6.5 percent) (Figure 16). The few trials reporting longer follow-up suggest that the prevalence of angina continues to equalize over extended follow-up. It is uncertain whether recurrent angina results more from progression of underlying coronary disease or eventual failure of the initial treatment (i.e., restenosis, graft failure).

The quality of evidence demonstrating little change in the survival difference between CABG and PCI between five and eight years after initial treatment is acceptable because, although only four trials report data during this interval, they are large, well-designed RCTs. However, there is insufficient information after ten years to draw reliable conclusions about the comparative efficacy of PCI and CABG. None of the stent-era trials has reported follow-up beyond five years, and the late effects of stent implantation may differ from those of balloon angioplasty.

## Key Question 2. Is there evidence that the comparative effectiveness of PCI and CABG varies based on

a Age, sex, race, or other demographic risk factors?
b Coronary disease risk factors, diabetes, or other comorbid disease?
c Angiographic-specific factors?
d CABG-specific factors?
e Clinical presentation?
f Adjunctive medical therapies?
g Process characteristics such as provider volume?
h Prior PCI or CABG revascularization procedures?

### Comparative Effectiveness by Age, Gender, and Race (2a)

Demographic factors such as age and sex are well-established prognostic factors in patients with coronary artery disease. Procedural, short-term risk of coronary revascularization is also affected by age and sex, with older patients and women experiencing more short-term adverse effects. The extent to which age, sex, and demographic factors affect the comparative outcomes of PCI and CABG has not, however, been clearly established.

#### Age

Outcomes by age were examined by the BARI, AWESOME, and stent trials. Overall, older patients had more procedural complications, especially stroke. In the BARI trial, patients aged 65 years and older had lower overall survival compared with younger patients. The survival difference between PCI and CABG at seven years was slightly greater for CABG in the older patients (-4.7 percent PCI-CABG survival difference; CABG survival 78.7 percent vs. PCI 74.0 percent) than younger patients (-2.8 percent PCI-CABG survival difference; CABG 88.1 percent vs. PCI 85.3 percent). Older patients had less recurrent angina, however, and fewer repeat revascularization procedures. The pooled results of four trials employing stents (ARTS, ERACI-II, MASS-II, SOS) found a lower one-year survival, freedom from MI, and freedom from stroke among patients aged 65 years or older compared with younger patients. However, there was no statistically significant survival difference PCI and CABG.

An important limitation of the randomized trial data is that very few patients over 75 years of age were enrolled. While a formal upper age limit was imposed by only a few trials, relatively few very old patients met eligibility criteria or were considered for enrollment. Consequently, no conclusions can be drawn about the comparative effectiveness of PCI and CABG in patients above 75 years of age.

#### Gender

Women were enrolled in essentially every RCT comparing PCI and CABG, so there is a substantial basis for applying trial results to both women and men. Outcomes according to gender were analyzed by BARI, SOS, and the pooled stent trials. In the BARI trial, women had lower overall survival, however only at seven years. The survival difference between PCI and CABG was similar, however, in women (-3.4 percent PCI-CABG survival difference: 82.6 percent CABG vs. 79.2 percent PCI) and in men (-3.5 percent PCI-CABG survival difference: 85.1 percent CABG vs. 81.6 percent PCI). In the SOS trial, women had lower quality of life at baseline, but improved after coronary revascularization. In men, quality of life scores improved more with CABG than with PCI, whereas in women the improvements were similar with CABG and PCI. In the pooled stent-trial data (ARTS, ERACI-II, MASS-II, SOS), women had slightly more events at one year, but relatively similar clinical outcomes as men.

#### Race

The vast majority of patients in the clinical trials were of European ancestry, so relatively few conclusions can be drawn regarding variation in outcomes according to race and ethnicity. Outcomes according to race were reported only by the BARI trial and registry. Overall, African-American patients had a 1.49 times lower risk of overall survival (CI: 1.07 to 2.08). There was no significant interaction between race and treatment assignment on outcome.

#### Summary (2a)

The evidence is robust that age and sex affect survival after both CABG and PCI. The evidence regarding the comparative effectiveness of PCI and CABG by age and gender is only acceptable, because relatively few RCTs reported these data and those that did showed no consistent effect of age or gender upon the comparative effectiveness of PCI and CABG. However, there is weak evidence regarding the effect of race on the comparative effectiveness of these procedures—a key gap in the literature.

### Comparative Effectiveness for Patients With Diabetes (2b)

Patients with diabetes who have coronary disease have substantially higher morbidity and mortality than patients without diabetes who have coronary disease. The poor prognosis among patients with diabetes has been reported consistently in patients undergoing coronary revascularization procedures, and may be due to more extensive coronary disease at the time of revascularization, more rapid progression of coronary atherosclerosis in follow-up, or both. The relative efficacy of PCI and CABG in the high-risk population of patients with diabetes has been of particular interest.

The BARI trial examined in detail the outcomes of patients with diabetes. While this subgroup was not prespecified for analysis in the published BARI protocol, it was added by the Data and Safety Monitoring Board early in the trial. At five years, the 353 patients in BARI with treated diabetes randomized to CABG had significantly better survival (80.5 percent) than patients with treated diabetes randomized to PCI (65.5 percent). By contrast, patients without treated diabetes in BARI had equivalent survival at five years when assigned to PCI (91.1 percent) or CABG (91.1 percent).

The BARI findings prompted other randomized trials to examine their outcomes in patients with diabetes, including CABRI, EAST, and RITA-I among the early balloon angioplasty studies, and ARTS, AWESOME, ERACI-II, and MASS-II among the more recent trials that used coronary stents. Survival at one and five years was reported for six trials (Appendix C Table 7 and Figures 20 and 21). None of these studies reported as dramatic a difference in survival in patients with diabetes as BARI. In EAST, for example, the 59 patients with treated diabetes had slightly better survival in the PCI arm at three years, equivalent survival at five years, and slightly better survival in the CABG arm at eight years. In CABRI, the 124 patients with diabetes had twice the overall risk of patients without diabetes, with a four year survival of 87.5 percent among patients assigned to surgery and 78.4 percent among patients assigned to angioplasty (no p-value reported). Among the 62 patients with diabetes in the RITA trial, 27 of the 29 PCI patients survived compared with 25 of the 33 CABG patients at a median follow-up of 6.5 years (no p value reported). Several of the stent-era trials reported data on patients with diabetes, but the best analysis comes from the pooled individual patient data from the ARTS, ERACI-II, MASS-II, and SOS trials. At one year, patients with diabetes had one year survival difference of 2.1 percent (94.6 percent when assigned to PCI versus 96.5 percent when assigned to CABG), which was larger than the overall one year survival difference of 0.2 percent (PCI 97.0 percent, CABG 98.2 percent).

Figure 20. Comparison of survival among patients with and without diabetes at 1 year

Figure 21. Comparison of survival among patients with and without diabetes at 5 years

A quantitative analysis of the comparative outcomes of PCI and CABG in patients with diabetes shows no significant difference in survival at one year (Figure 20) or at five years (Figure 21). The summary PCI-CABG survival difference at five years was greater for CABG by only 0.8 percent, but with very wide confidence limits of -8.3 percent to 6.6 percent (PCI/CABG odds ratio 0.87; CI: 0.51 to 1.49).

The quality of the evidence comparing PCI with CABG in patients with diabetes is only acceptable given that it is neither consistent nor conclusive despite the number of trials that have examined this issue. The marked benefit of CABG reported by the BARI trial was not seen in other randomized trials, suggesting this result may be attributable to the play of chance. None of the other trials enrolled large numbers of patients with diabetes, however, and follow-up in the recent stent-era trials is too short to be conclusive. Pooling of the individual patient level data from all randomized trials would provide the most definitive analysis of outcomes in patients with diabetes. The ongoing FREEDOM trial (Future Revascularization Evaluation in patients with Diabetes: Optimal Management of multi-vessel disease, ID NCT00086450), Veterans Affairs CARDS Trial (Coronary Revascularization in Diabetes, ID NCT 00326196) and CARDia Trial (Coronary Artery Revascularization in Diabetes) ^214^ will provide data on outcomes in patients treated using drug-eluting stents and contemporary bypass surgery (Appendix C Table 14).

### Comparative Effectiveness for Patients With Other Coronary Disease Risk Factors (2b)

The major risk factors for the development of coronary artery disease include age, sex, diabetes, smoking, hyperlipidemia, hypertension, and family history of premature vascular disease. Other risk factors include obesity, chronic kidney disease, and the presence of atherosclerosis in other vascular beds. The effects of age, sex, and diabetes upon the comparative efficacy of PCI and CABG have been studied extensively and have already been discussed. The potential effects of the other cardiac risk factors have not been studied as often.

#### Tobacco use

Cigarette smoking is an established risk factor for the development of coronary disease, and continued smoking is an adverse prognostic factor after coronary events and coronary revascularization. Patients are strongly urged to stop smoking at the time of coronary revascularization. The effect of smoking upon outcome of PCI and CABG was examined only by the BARI trial and by the pooled stent trials (ARTS, ERACI-II, MASS-II, SOS). In the BARI study, ^61^ current smoking increased overall mortality with an adjusted relative risk of 1.72 (CI 1.28 to 2.32), and former smoking also increased overall mortality, with an adjusted odds ratio of 1.35 (CI 1.06 to 1.72). The interaction between smoking and treatment was not significant, indicating that current and former smoking increased risk to a similar extent in PCI- and CABG-assigned patients. In the pooled stent trial data, ^17^ smoking was not consistently associated with one-year mortality.

#### Hypertension

Hypertension is an established risk factor for cardiovascular morbidity and mortality. The BARI trial ^61^ found that hypertension increased total mortality, with an adjusted relative risk of 1.40 (CI: 1.14 to 1.72). There was no evidence of interaction with treatment assignment, suggesting that hypertension increased risk similarly in PCI-assigned and CABG-assigned patients.

#### Hyperlipidemia and family history

Hyperlipidemia and family history of coronary artery disease have not been studied in PCI-CABG RCTs to determine whether they affect subsequent outcome.

#### Obesity

Obesity is a risk factor for coronary artery disease, primarily through its effect on diabetes, hypertension, and hyperlipidemia. Obesity also increases the risk of cardiac procedures directly, as PCI and CABG can be more difficult to perform in obese patients. The ARTS trial and the BARI trial analyzed the effect of obesity on subsequent outcomes. In ARTS, only 28 percent of the patients had a normal body mass index (BMI) of less than 25 kg/m^2^, while 50 percent were overweight (BMI 25 to 30), and 22 percent were obese (BMI >30). Overall survival in ARTS was not affected by BMI, nor were freedom from MI and stroke. ^42^ Repeat revascularization was not related to BMI in patients assigned to PCI, but increased BMI was associated with fewer repeat procedures in patients assigned to CABG. ARTS did not analyze functional outcomes, such as angina or quality of life, according to BMI. In the combined BARI trial and registry of 3,634 patients, ^72^ 2 percent of patients had a low BMI (<20), 24 percent had a normal BMI (20–25), 46 percent were overweight (BMI of 25–30), 21 percent were obese (BMI 30–35), and 7 percent were morbidly obese (BMI>35). Obesity in the BARI data was strongly associated with diabetes and hypertension, and inversely with age and smoking. All cause survival was decreased in those with either a BMI <20 or a BMI ≥35, with the relationship attenuated somewhat by adjustment for other prognostic factors. Survival decreased steadily as BMI increased in CABG-assigned patients, but not in PCI-assigned patients. Consequently, the differences in five-year crude survival rates between CABG-assigned and PCI-assigned patients diminished with increasing weight: for BMI <20 the five-year PCI-CABG survival difference was -12.5 percent, for BMI of 20–25 it was -4.6 percent, for BMI 25–30 it was -0.5 percent, for BMI 30–35 it was 0 percent, and for BMI ≥35 it was +1.4 percent (i.e., PCI-assigned patients had higher survival). This analysis was not, however, adjusted for potential confounding factors such as age, gender, or diabetes.

#### Renal dysfunction

Renal dysfunction is increasingly recognized as a cardiac risk factor. While patients with end-stage renal disease and severely compromised renal function were generally excluded from trials of PCI and CABG, the effects of modestly abnormal renal function upon outcome have been analyzed by the BARI trial ^84^ and the ARTS trial. ^43^ Patients in ARTS with estimated creatinine clearance of ≤ 60 ml/min were defined as having chronic kidney disease. ^43^ The 25 percent of the ARTS population with chronic kidney disease had a significantly higher risk of death, MI, stroke, and transient ischemic attack, with a relative risk of 1.9 (CI: 1.4 to 2.7). There was no difference in the ARTS trial between PCI and CABG in this outcome over three years of follow-up (PCI/CABG hazard ratio 0.93), nor of overall mortality (PCI/CABG hazard ratio 0.98). In the combined BARI trial and registry, ^84^ only 2.1 percent of patients had chronic kidney disease, defined as a serum creatinine above 1.5 mg/dL. Chronic kidney disease was associated with increased procedural risk and with long-term (seven year) mortality, with a relative risk of 2.3 (CI: 1.6 to 3.3). The interaction with treatment assignment was not significant, however, implying that risk was increased by chronic kidney disease to a similar extent in PCI- and CABG-assigned patients.

#### Vascular disease

Atherosclerosis in other arterial beds, including the cerebrovascular and peripheral vascular systems, is generally associated with more extensive coronary atherosclerosis and worse prognosis. Only the BARI trial examined the outcomes of patients with concomitant vascular disease. ^83^ Peripheral vascular disease decreased five-year survival in the combined BARI trial and registry population, with a relative risk of 1.50 (CI: 1.20 to 1.88). There was no significant interaction with treatment assignment, however. In the BARI trial population the presence of clinically evident disease in either the peripheral vascular system (claudication, peripheral vascular surgery or abdominal aortic aneurysm) or in the cerebrovascular system (prior stroke, transient ischemic attack, carotid surgery, carotid bruit, or documented carotid disease) was present in 17 percent of the trial population. Overall five year survival was substantially worse in patients with evident non-coronary atherosclerosis (75.8 percent versus 90.2 percent p<0.001). Five-year survival was better by 8.9 percent in CABG-assigned patients with vascular disease (80.3 percent vs. 71.4 percent, p=0.11), which was greater than the PCI-CABG survival difference of -3.0 percent in the overall BARI trial. Angina was more frequent in follow-up among patients with non-coronary atherosclerosis.

#### Summary (2b)

The quality of evidence regarding the comparative effectiveness of patients with coronary disease risk factors other than diabetes is generally weak given the paucity of consistent, RCT data.

### Comparative Effectiveness by Extent of Coronary Artery Disease (2c)

Coronary revascularization procedures treat obstructive coronary artery disease in any of the three major epicardial coronary artery systems: the left anterior descending (LAD), the left circumflex, and the right coronary artery. The mechanism of action of coronary revascularization suggests a dose-response relationship between the number of vessels treated and the therapeutic benefit of revascularization; comparisons of CABG with medical therapy show the survival benefit conferred by CABG increases directly with extent of disease. ^158^ It would be reasonable to expect that the difference in outcome between PCI and CABG might depend upon the extent of disease.

Previously, we presented the comparison of survival difference between PCI and CABG for single- versus multi-vessel disease trials (Figure 12). When compared across all trials, we found no significant survival difference between the procedures. However, a within-trial comparison of outcomes according to the extent of disease is the best test of a possible “dose-response” relationship, since the sources of variation are reduced when revascularization is done within the same centers and after applications of the same inclusion and exclusion criteria. Most studies did not, however, report outcomes separately for patients with one-, two-, and three-vessel disease. The BARI trial found overall better survival among the 1,024 patients with two-vessel disease than the 750 patients with three-vessel disease. The survival difference between PCI and CABG at five years was greater in patients with three-vessel disease (-3.9 percent PCI-CABG survival difference: 84.7 percent PCI vs. 88.6 percent CABG) than in patients with two-vessel disease (-2.1 percent PCI-CABG survival difference; 87.6 percent PCI vs. 89.7 percent CABG) (Table 14). The smaller EAST trial also reported a larger CABG-PCI survival difference among patients with three-vessel disease than patients with two-vessel disease. A similar trend was reported in the pooled data from four stent-era trials (ARTS, ERACI-II, MASS-II, SOS). By contrast, the RITA-I study found very little difference in survival between the 455 patients with single-vessel disease and the 556 patients with multi-vessel disease (mostly two-vessel disease) and similar PCI-CABG survival differences at a median 6.5 years of follow-up.

Table 14 Survival for patients according to the extent of coronary artery disease

| | PCI | | | CABG
Trial Name | Anatomy | N randomized | N alive at 5 years | 5 year survival (%) | N randomized | N alive at 5 years | 5 year survival (%)
RITA | SVD | 233 | | 92.7 | 222 | | 90.5
| MVD | 277 | | 92.1 | 279 | | 91.4
BARI | 2 vessel disease | 521 | | 87.6 | 521 | | 89.7
| 3 vessel disease | 375 | | 84.7 | 375 | | 88.6
EAST | 2 vessel disease | 119 | 108 | 90.8 | 117 | 106 | 90.6
| 3 vessel disease | 79 | 66 | 83.5 | 77 | 71 | 92.2
ERACI-II | 2 vessel disease | | | | | 94 | 89.4
| 3 vessel disease | | | | | 131 | 87.8

PCI=percutaneous coronary intervention; CABG=coronary artery bypass grafting; SVD=single-vessel disease; MVD=multi-vessel disease

As previously discussed, clinical registry studies show a significant interaction between extent of coronary artery disease and the PCI/CABG hazard ratio for long-term survival. The Duke data, for instance, show a graded relationship for PCI/CABG hazard across a scale with nine categories of extent of disease. ^156,^ ^159^ Other clinical registries show a similar relationship between extent of disease and the relative efficacy of CABG and PCI.

Overall, these data suggest that mortality in patients with three-vessel disease may be reduced somewhat more by CABG than by PCI and that in one-vessel disease there is little mortality difference between PCI and CABG. A more definitive analysis would require pooling individual patient level data from randomized trials that enrolled patients with different extent of coronary disease.

The quality of evidence specifically addressing the comparative effectiveness of PCI and CABG is acceptable for two-vessel versus three-vessel disease, with consistent results from within several trials and confirmed by evidence from clinical registries. The quality of evidence regarding single-vessel LAD versus multi-vessel disease is also acceptable.

### Comparative Effectiveness for Patients With Low Left Ventricular (LV) Function (2c)

Left ventricular (LV) function is generally accepted to be one of the strongest prognostic factors in patients with coronary artery disease. A clear association between decreased LV ejection fraction (EF) and survival has been repeatedly demonstrated in numerous studies enrolling various patient populations. Coronary revascularization increases survival compared with medical therapy to a greater extent in absolute terms in patients with reduced EF compared with patients with normal EF, even though the degree of relative risk reduction is similar in these populations. ^158^ This reflects the principle that higher risk populations benefit more than low risk populations when a therapy provides a consistent relative reduction.

Most trials comparing PCI and CABG enrolled patients with relatively preserved LV function (Appendix Table 2) and a low prevalence of heart failure. The limited range of ejection fractions within the trials may not permit a stringent test of whether the comparative effectiveness of PCI and CABG varies with LV function. Only the BARI trial ^63,^ ^68^ and the AWESOME trial ^56^ reported specific analyses of LV function. Overall five year survival in the BARI trial was worse in the 22 percent of patients with reduced LV function than in patients with normal LV function. ^58^ The PCI-CABG survival difference at five years was 0.4 percent in the patients with reduced LV function (CABG 80.7 percent, PCI 81.1 percent), whereas it was -4 percent in patients with normal LV function. At seven years, the PCI-CABG survival differences were -1.3 percent for the abnormal and -3.6 percent for the normal LV function groups. A similar pattern was seen in BARI randomized patients with a history of congestive heart failure, in whom the seven year CABG-PCI survival difference was 4.3 percent compared with 3.4 percent in patients without heart failure. The AWESOME trial enrolled a very high risk population of patients with refractory angina and increased risk for CABG, 20 percent of whom had an EF <35 percent. The patients with low EF had worse overall survival at three years, with a slight advantage of 3 percent in the CABG-assigned patients (CABG survival 72 percent, PCI survival 69 percent), while in the overall trial population PCI-assigned patients had a slightly better survival (PCI-CABG survival difference 1 percent, CABG survival 79 percent, PCI survival 80 percent). Overall, the small and inconsistent differences seen in the trials provide no convincing evidence of variation in the comparative efficacy for PCI and CABG by the level of LV function.

The quality of the evidence regarding the comparative effectiveness of PCI and CABG according to LV function was weak.

### Comparative Effectiveness by PCI-Specific Factors (2c)

Eleven trials used bare metal stents, 11 used balloon angioplasty, and only the Seoul-Hong trial used drug-eluting stents (Table 4). As discussed above, comparing the more recent stent trials to the earlier balloon trials, we found a smaller survival difference between PCI and CABG; however, this survival difference between PCI and CABG did not differ statistically from zero for either PCI procedure (Figures 13 and 14).

The quality of the evidence regarding the comparative effectiveness of various PCI techniques on key comparative outcomes of PCI versus CABG was acceptable.

### Comparative Effectiveness by CABG-Specific Factors (2d)

The technique of conventional coronary bypass surgery includes a median sternotomy, cardiopulmonary bypass, and use of venous or arterial grafts. There are numerous technical variations upon this basic CABG technique, with inter-institutional and inter-operator variability. There are also secular trends in the technical approach, primarily an increased emphasis on the use of internal mammary grafts, which have much better long-term patency than saphenous vein grafts.

There has been considerable interest recently in coronary surgery that avoids either a median sternotomy or cardiopulmonary bypass or both. “Minimally invasive” surgery (MIDCAB), which is performed through a small throracotomy incision on a beating heart, has been compared with PCI in several small randomized trials: including the AMIST, Groningen, Leipzig, Octostent, Poland, Seoul-Kim, Seoul-Hong, and SIMA studies. These studies enrolled patients with single-vessel proximal LAD disease (predominantly or exclusively) and generally used PCI with stents as the comparator. These trials showed similar outcomes over a relatively short follow-up period. There are only a few early trials of balloon angioplasty and standard CABG (Lausanne, MASS-I) in patients with single-vessel disease whose results can be compared with these trials. In general, the survival differences over one to two years of follow-up are comparable (Figure 9).

Standard CABG was used in all trials that enrolled patients with multi-vessel disease. There was some variability in the use of left internal mammary (IMA) grafting among these trials, ranging from a low of 37 percent in the early GABI study to over 90 percent in the more recent ARTS, MASS-II, and SoS studies. The PCI-CABG survival differences at one year are plotted in Figure 22 against the percentage of surgical patients who received an IMA graft. We performed a regression weighted by the sample size of the RCT and found that as the percentage of IMA grafts increases, there is a trend toward higher survival in CABG-assigned patients at 1-year but not at 5-years (neither association was statistically significant). There was a much weaker association between use of IMA graft and survival at 5-years (Figure 23).

Figure 22. Association between survival at 1-year and use of mammary artery grafts

Figure 23. Association between survival at 5-years and use of mammary artery grafts

The randomized trials did not report in any detail the use of normothermic versus hypothermic cardiopulmonary bypass, the use of specific types of cardioplegia, or details of saphenous vein harvesting and handling. The PCI-CABG trials therefore provide little direct evidence about the potential effects of these variations in CABG technique upon the comparative effectiveness of CABG and PCI. It is beyond the scope of this report to review trials that randomized patients receiving CABG to different technical approaches. A recent meta-analysis concluded that blood cardioplegia provided superior myocardial protection as compared with crystalloid cardioplegia, based on a review of 34 randomized trials. ^215^ Off-pump CABG has been shown to have fewer short-term complications than conventional on-pump CABG in several meta-analyses; long-term clinical follow-up has not yet been reported, however.

No RCTs comparing PCI and CABG have used transmyocardial revascularization. A recent meta-analysis of seven trials suggested that transmyocardial revascularization improved angina, but not survival. ^216^

Given these gaps in the literature, the quality of the evidence regarding the comparative effectiveness of various CABG techniques on key comparative outcomes of PCI versus CABG was weak.

### Comparative Effectiveness for Patients With Stable Angina Versus Unstable Angina (2e)

Patients with unstable angina or acute myocardial infarction have decreased short-term survival and increased serious morbidity compared with patients with stable forms of coronary artery disease. The procedural risks of coronary revascularization procedures are also increased in patients with acute coronary syndromes. It is uncertain whether procedural risks are increased to a similar extent by PCI and CABG, however.

While patients with acute coronary syndromes were enrolled in most trials (Appendix C Table 2), only three randomized trials examined in any detail the clinical outcomes of patients according to their clinical presentation: the ARTS trial, ^41^ the BARI trial ^58,^ ^61^ and the SOS trial. ^139,^ ^144^ In ARTS, 63 percent of the 1,205 patients had stable angina, while the remaining 37 percent had unstable angina as the qualifying clinical symptoms. At one-year of follow-up, the PCI-CABG difference in freedom from death, MI, and stroke was -2.2 percent among stable patients (CABG 92.6 percent, PCI 90.4 percent), versus 2.3 percent among unstable patients (CABG 88.9 percent, PCI 91.2 percent). More CABG patients than PCI patients were free of angina at one year: 13 percent more in stable angina (90 percent CABG, 77 percent PCI), and 6 percent more in unstable angina (89 percent CABG, 83 percent PCI). None of these differences were statistically significant. In the BARI trial, roughly two-thirds of patients had acute coronary syndrome, and one-third had stable angina. At five years of follow-up, the survival differences between CABG and PCI were similar in these subgroups: 2.7 percent in acute coronary syndromes (88.8 percent CABG, 86.1 percent PCI), versus 5.5 percent in stable angina (91 percent CABG, 85.5 percent PCI). In SOS, only 24 percent of patients had unstable angina, and they had relatively similar clinical outcomes at one year as patients with stable angina. Survival or freedom from Q-wave MI was slightly lower among PCI patients who had either unstable symptoms (0.4 percent) or stable angina (1.3 percent), and both groups had improved scores on the Seattle Angina Questionnaire.

The evidence from these three studies is that the comparative effectiveness of PCI and CABG is not greatly affected by the mode of clinical presentation. This statement should be qualified by noting that few patients were experiencing severe clinical instability at the time of randomization. Given the consistency of these results, we rated the evidence addressing this key question as acceptable.

### Comparative Effectiveness by Adjunctive Medical Therapies (2f)

Adjunctive medical therapies may improve the safety and efficacy of coronary revascularization procedures. There have been multiple studies examining the efficacy of intravenous glycoprotein IIb/IIIa inhibitors, anticoagulation (heparin, low molecular weight heparin, etc.), and antiplatelet agents (clopidogrel, ticlopidine) in the setting of coronary angioplasty. A review of this extensive literature is beyond the scope of the present evidence report, since these studies did not compare PCI with CABG, only two alternative methods of PCI. ^217^

Use of adjunctive medical therapy for PCI has been closely related to the increased use of coronary stents, because of concerns about stent thrombosis. Prolonged antiplatelet therapy has become standard after PCI, initially using aspirin and ticlopidine, and more recently using aspirin and clopidogrel. Anti-platelet therapy may reduce coronary events independent of any effect on the site of PCI, however, and may contribute to improved long-term outcomes in PCI-treated patients. Anti-platelet therapy is also recommended for patients after CABG, and so the comparative effectiveness of PCI and CABG would not necessarily be affected.

A subsidiary issue is whether patients who have undergone CABG are as likely as patients who have undergone PCI to comply with recommendations to use aspirin, beta-blockers, ACE-inhibitors, and statins. To the extent that evidence-based therapies are used differentially after PCI and CABG, long-term outcomes may be affected. There is relatively little evidence on this question, and patients in randomized trials may be more likely to comply with recommended therapies than the average patient who has had coronary revascularization. Recent data from the Duke Database shows relatively similar use medical of therapies after PCI and CABG. ^218^

Given that the randomized trials did not provide comparative effectiveness data on the use of adjunctive medical therapy for PCI or CABG, we rated the quality of the evidence to answer this question weak.

### Comparative Effectiveness by Hospital and Provider Volume (2g)

Randomized trials have not directly tested for differences in clinical outcomes of PCI and CABG on the basis of process characteristics. However, observational studies from administrative and clinical data sets have examined the relationship between procedure volume and short-term outcomes, both at the hospital level and the physician level.

Over the past several decades, a robust body of evidence has been developed demonstrating an inverse relationship between procedure volume and short-term adverse outcomes (primarily mortality) for numerous surgical procedures. ^219,^ ^220^ These observations have led to recommendations that many procedures should be performed in “centers of excellence” meeting minimum standards for procedure volumes and outcomes. ^221,^ ^222^ These volume-based referral recommendations ^c^ are controversial because of concerns about applying aggregate data to individual hospitals and individual practitioners; in reducing a continuous, non-linear relationship between volume and outcome to a binary “high/low” classification; and by considering procedure volume a good surrogate marker for outcome. ^223^ – ^226^ There are also several methodologic issues about the appropriate statistical approaches to test for the effects of volume upon outcome. ^219,^ ^220^ In this section, we summarize the evidence available to date for CABG and PCI.

c Leapfrog's hospital annual procedural volume thresholds are currently 450 for CABG and 400 for PCI. ^222^ The ACC/AHA 2004 Guidelines suggest “a posture of close monitoring of institutions or individuals that perform less than 100 cases annually.” ^150^ The AHRQ Guidelines Clearinghouse presents “Level B” evidence from the 2005 ACC/AHA/SCAI guideline that “elective PCI should be performed by operators with acceptable annual volume (at least 75 procedures) at high-volume centers (more than 400 procedures),” along with additional contingencies for lower volume operators and institutions. ^148,^ ^149^

#### Systematic reviews

We identified four formal systematic reviews that examined the relationship between hospital or physician volume of coronary revascularization procedures and patient outcomes (Appendix C Tables 8 and 9). Two reviews focused exclusively on CABG, ^22,^ ^23^ and the other two reviews analyzed both PCI and CABG (as well as other procedures). ^219,^ ^221^

Sowden and colleagues conducted a systematic review of U.S.-based studies of CABG hospital volume-outcome relationships, based on data from 1972 to 1992. ^23^ Of the eight unique studies, seven reported significantly or nearly significant reduced mortality with increasing hospital CABG volume, with the adjusted odds ratios for mortality in high versus low volume hospitals ranging from 0.44 (CI: 0.29 to 0.65) to 0.84 (CI: 0.66 to 1.07), at thresholds close to 200 cases per year (varied from 150 to 215 depending upon the study). They also observed case mix adjustment and time period effects, though could not distinguish the relative importance of each with the small number of studies.

A subsequent review by Kalant and Shrier identified 28 independent patient cohorts receiving CABG between 1972 and 1999. Based on 16 cohorts with volume as a categorical variable (above and below 200 procedures a year), the authors plotted odds ratios for perioperative survival (adjusted to varying degrees) by year of publication, and showed that 1) most cohorts evaluated (13 of 16) showed higher survival in the higher volume hospitals, and 2) the relationship between volume and outcome was not as strong in the cohorts from more recent years. ^22^ Five of the nine cohorts demonstrated an inverse association between surgeon volume and outcomes, but all five cohorts were from New York State.

Dudley and colleagues reviewed volume-outcome studies for a broad range of procedures, including 11 studies of CABG and six studies of PCI. ^221^ Almost all studies reported statistically significantly better outcomes in high volume hospitals, including nine of 11 CABG studies and all six PCI studies.

Halm and associates found that five of nine studies reported a significant association between volume and outcome based on PCI procedures performed between 1989 and 1997, and that six of eight CABG studies reported a significant association based on procedures performed between 1980 and 1995. ^219^ The absolute in-hospital survival rate difference (unadjusted) for high volume PCI hospitals versus low volume PCI hospitals had a median of 0.2 percent (range 0.0 percent to 1.4 percent), across studies, while the median difference between high and low volume CABG hospitals was 1.6 percent (range 0 percent to 4.4 percent). Studies of the relationship between physician volume and outcome were less uniform, with only one of five included PCI studies showing a significant association, whereas all three studies of individual surgeon volume and CABG outcome showed a significant association.

The previous reviews of volume-outcome associations generally pre-dated the introduction of coronary stents for angioplasty and of minimally invasive techniques for CABG. In addition, the previous reviews cover PCI less comprehensively than CABG. We therefore identified and extracted basic findings from 29 PCI volume-outcome studies (Appendix C Tables 10 and 11) conducted using large administrative or clinical registries (greater than 2500 patients), and targeted our data extraction to 12 CABG studies published since the Kalant review (Appendix C Table 12). Some of these studies evaluated volume as a continuous variable, but most categorized hospitals or physicians into specific volume ranges with varying distributions from lopsided to completely even splitting among categories (Appendix C Table 13). We describe recent studies of the association between volume and outcome to explore whether the relationships established for earlier coronary revascularization methods continue to apply to more recently developed techniques.

Hannan and associates reviewed the outcomes of 107,713 PCI procedures performed in 34 hospitals in New York State between 1998 and 2000. Hospitals performing less than 400 procedures per year had roughly twice the rate of death and of death or same-day CABG, as higher volume hospitals. McGrath and coworkers also found a significant inverse relationship between volume and PCI procedural risk in their analysis of 167,208 Medicare patients treated in 1,003 hospitals during 1997. ^182^ Burton and colleagues found no relationship between hospital volume and procedural survival in their analysis of all 17,417 PCI procedures performed in Scotland between 1997 and 2003, but their study included only six hospitals ^207^ and did show a significant effect of hospital volume on the rate of emergency CABG.

All but one of the recent CABG volume-outcomes studies found a significant relationship between increased hospital volume and higher risk-adjusted short-term survival, though several have pointed to potential subgroups in which the relationship does not persist (Appendix C Table 12). The recent study by Welke evaluated Medicare patients from 1996 through 2001, and found that hospital volume was a poor discriminator of survival given the large ranges of risk-adjusted mortality among hospitals in each quintile examined. The few recent CABG studies that reported on associations between surgeon volume and outcomes reported a significant association as well.

Three recent studies ^227,^ ^212,^ ^228^ examined both PCI and CABG outcomes according to hospital volume in large administrative datasets that included procedure outcomes between 1998 and 2001 (Table 14). The two studies that used thresholds of 450 CABG procedures and 400 PCI procedures to define high versus low volume hospitals reported statistically significant relationships between volume and outcome in separate analyses of the same national data set (Table 14). In contrast, the single study that used thresholds of 300 CABG procedures and 600 PCI procedures to define high and low volume hospitals found a significant relationship for CABG but not for PCI. The summary data from all three studies (Figure 24) suggest that the volume-outcome relationship is stronger when lower thresholds are used to classify hospitals.

Figure 24. Summary data from comparative effectiveness studies

Overall, recent studies that included large numbers of procedures performed at a large number of hospitals have confirmed the relationship between increased volume and PCI procedural survival persists even with the availability of coronary stents. Similarly, higher hospital and physician CABG procedural volumes are generally associated with better outcomes in recent studies. The evidence is robust that CABG and PCI hospital volume are associated with short-term procedural risk in a number of circumstances. Nevertheless, the direction of the association is unknown for revascularization - whether “practice makes perfect” (poor outcomes are caused by less experience of lower volume environments) or whether “selective referral” (increasing volume in settings known to have good outcomes) or perhaps both are explanations of the association.

### Comparative Effectiveness by Prior Revascularization Procedures (2h)

The procedural risk of a second (“re-do”) CABG operation is considerably higher than that of an initial CABG procedure. This excess risk may be related to the technical difficulties of operating in the presence of scar tissue from the first CABG. By contrast, second PCI procedures are generally regarded as having similar risk as initial PCI procedures, especially if performed to treat re-stenosis. Most studies have included patients with prior balloon angioplasty rather than prior coronary stenting, however, so the potential for increased risk of a second PCI in the area of an implanted stent has not been adequately studied.

One randomized trial and several clinical registries have compared PCI with re-do CABG in patients with a prior CABG (Table 15). In the AWESOME trial 142 patients with prior CABG were randomized to either re-do CABG (75 patients) or PCI (67 patients). While procedural survival was considerably higher in the patients assigned to PCI (100 percent vs. 92 percent), three-year survival was only slightly higher (78 percent vs. 73 percent) and not significantly different. In the large clinical registry studies from Cleveland, Emory, and Kansas City, patients with re-do CABG generally had more extensive coronary disease and a longer interval from initial CABG than patients treated with PCI (Table 15). Procedural mortality was higher for re-do CABG, but survival at five to six years of follow-up did not differ significantly.

Table 15 Comparative effectiveness by volume-outcome

Citation | Population | Year | # Patients | Type of Data | Hosp Vol Levels | Hospital Vol & Risk-adjusted Mortality | Volume Distribution
Birkmeyer J et al. ^227^ | HCUP Nationwide Inpatient Sample | 2000 only | 394,165 (CABG) | Admin | CABG: <450, 450+/yr | 3.3% for less than 450 to 2.9% for 450 or more CABG cases (p<0.05); | CABG: 39% patients at low volume; PCI: 14% at low volume (# of hospitals not provided)
| | | 678,296 (PCI) | | PCI: <400, 400+/yr | 2.0% to 1.4% for PCI below cutoff versus at or above 400 cutoff (p<0.05)
| | | | | | [Odds Ratios and 95% CI not reported, but calculated OR for CABG: 1.14; for PCI: 1.43]
Carey JS et al. ^212^ | Discharge abstracts from the California Office of Statewide Health Planning | 1999-2001 | 82,353 (CABG) | Admin | CABG: <300, 300+/yr | 3.22% for less than 300 CABG cases versus 2.58% for 300 or more CABG cases (OR: 1.29 [CI: 1.19–1.41], p=0.0001); | CABG: 95 low volume hospitals, 26 high volume; PCI: 116 low volume, 22 high volume (# of patients by category not provided)
| | | 153,755 (PCI) | | PCI: <600, 600+/yr | 1.39% to 1.41% for PCI below cutoff versus at or above 600 cutoff (not statistically significantly different for risk adjusted rates)
Epstein AJ et al. ^228^ | HCUP Nationwide Inpatient Sample | 1998-2001 | 1,496,937 (CABG) | Admin | CABG: <450, 450+/yr | CABG: OR 1.16 (1.10–1.24) for low volume vs. high volume [p=0.001]. | CABG: 38.4% patients treated at low volume; PCI: 14% patients treated at low volume (# of hospitals not provided)
| | | 2,500,796 (PCI) | | PCI:<400, 400+/yr | PCI: OR 1.12 (1.05–1.20) for low volume vs. high volume [p=0.001].

Vol=volume; PCI=percutaneous coronary intervention; CABG=coronary artery bypass grafting; HCUP=Healthcare cost and utilization project; OR=odds ratio; CI=confidence interval; n/a: not available

Table 16 Studies of patients with prior revascularization procedures

Study | Years | Procedure | # Pts | Age | Male | Prior MI | DM | Years p CABG | 3-VD | LVEF | Proc Survival% | Proc Q wave MI | F/U Years | Survival | Survival Comparison
Kansas City ^169^ | 1987-1988 | PTCA | 468 | 62.2 | 83% | 56% | 19% | 6.6 | 77% | 46% | 99.6 | 0.9% | 6 | 74%
Kansas City ^169^ | 1987-1989 | re-CABG | 164 | 63.6 | 85% | 42% | 21% | 8.9 | 74% | 48% | 92.7 | 6.1% | 6 | 73% | p=0.32
Emory ^166^ | 1980-1994 | PTCA | 2613 | 61 | 80% | 56% | 22% | 6.1 | 56% | 53% | 98.8 | 1.4% | 5 | 78%
Emory ^166^ | 1980-1995 | re-CABG | 1561 | 61 | 84% | 20% | 22% | 7.9 | 75% | 51% | 93.2 | 5.4% | 5 | 76% | Hazard Ratio CABG/PCI 1.01 after adjustment (insignificant)
Cleveland ^154^ | 1995-2000 | PTCA | 704 | 66 | 79% | 57% | 34% | 8.2 | 83% | 48% | 98.3 | 0.3% | 5 | 75%
Cleveland ^154^ | 1995-2001 | re-CABG | 1487 | 65 | 84% | 19% | 33% | 11.8 | 88% | 44% | 97.2 | 1.4% | 5 | 80% | Hazard Ratio PCI/CABG 1.27 (1.07–1.51) unadjusted, 1.47 (0.94–2.28) after adjustment
AWESOME RCT ^52^ | 1995-2000 | PTCA | 67 | 39% > 70 | | | 28% | | 65% | 16% < 35 | 100.0 | | 3 | 76%
AWESOME RCT ^52^ | 1995-2001 | re-CABG | 75 | 40% > 70 | | | 44% | | 70% | 15% < 35 | 92.0 | | 3 | 73% | Not significant
AWESOME Pt-Choice Registry ^52^ | 1995-2002 | PTCA | 74 | 45% > 70 | | | 38% | | 62% | 8% < 35 | 100.0 | | 3 | 86%
AWESOME Pt-Choice Registry ^52^ | 1995-2003 | re-CABG | 32 | 47% > 70 | | | 20% | | 62% | 25% < 35 | 84.0 | | 3 | 65% | p< 0.05 in patient choice
AWESOME MD-Directed ^52^ | 1995-2004 | PTCA | 357 | 38% > 70 | | | 35% | | 58% | 17% < 35 | 99.4 | | 3 | 77%
AWESOME MD-Directed ^52^ | 1995-2005 | re-CABG | 155 | 36% > 70 | | | 28% | | 71% | 11% < 35 | 91.6 | | 3 | 71% | Not significant

Pts=patients; MI=myocardial infarction; DM=diabetes; VD=vessel disease; Year p CABG=years prior coronary artery bypass graft; LVEF=left ventricular ejection fraction; Proc Mort=procedural mortality; Proc Q-wave MI=procedural Q-wave myocardial infarction; F/U=follow-up; RCT=randomized controlled trial; PTCA=percutaneous transluminal coronary angioplasty; CABG=coronary artery bypass grafting; MD=physician

The evidence is therefore weak that re-do CABG carries a higher procedural risk, but there is no clear evidence that long-term outcomes differ significantly.