# Acknowledgments

We thank Robert Jones for providing expert cardiovascular surgery advice and Ingram Olkin for his statistical guidance. We are grateful to Olga Saynina for digitizing the survival curves and Cristina Galvin for administrative assistance.

## AHRQ Contacts

- Beth A. Collins-Sharp, R.N
- Director
- Evidence-based Practice Center Program
- Agency for Healthcare Research and Quality
- Rockville, MD

- Artyom Sedrakyan, M.D., Ph.D.
- Task Order Officer
- Evidence-based Practice Center Program
- Agency for Healthcare Research and Quality
- Rockville, MD