# Abstraction Forms

To see the Abstraction Forms, please select the link below. This link will take you to a PDF version of the forms.

Abstraction Forms