# Peer Reviewers

- Charles R. Bridges, M.D. Sc.D.
- Chief of Cardiothoracic Surgery
- Division of Cardiothoracic Surgery
- Pennsylvania Hospital

- Rochelle Fu, Ph.D.
- Assistant Professor
- Department of Public Health and Preventative Medicine
- Oregon Health and Science University