# Additional Analyses and Evidence Tables

Figure 1 Procedural survival (PCI/CABG odds ratio)

Figure 2 Procedural survival by type of surgical procedure (PCI-CABG survival difference)

Figure 3 Freedom from procedural stroke (PCI/CABG odds ratio)

Figure 4 Freedom from procedural MI (PCI/CABG odds ratio)

Figure 5 Funnel plot for procedural survival analysis

Figure 6 Forest plots for survival at 6 months using all studies (PCI-CABG survival difference)

Figure 7 Forest plots for survival at 6 months using all studies (PCI/CABG odds ratio)

Figure 8 Forest plots for survival at 12 months (PCI-CABG survival difference)

Figure 9 Forest plots for survival at 12 months (PCI/CABG odds ratio)

Figure 10 Forest plot for survival at 24 months (PCI-CABG survival difference)

Figure 11 Forest plot for survival at 24 months (PCI/CABG odds ratio)

Figure 12 Forest plot for survival at 36 months (PCI-CABG survival difference)

Figure 13 Forest plot for survival at 36 months (PCI/CABG odds ratio)

Figure 14 Forest plot for survival at 60 months (PCI-CABG survival difference)

Figure 15 Forest plot for survival at 60 months (PCI/CABG odds ratio)

Figure 16 Comparative survival at 1-year between balloon and stent trials

Figure 17 Comparative survival at 5-years between balloon and stent trials

Figure 18 Freedom from MI post-procedure (PCI-CABG difference in freedom from MI)

Appendix Table 1. RCT subject demographics

Trial | Intervention | Number subjects randomized at start of study | Number subjects received assigned therapy | Age (Mean) | Women % | White % | African American % | Other race % | Body Mass Index (mean)
AMIST ^36^ | PCI | 50 | 48 | Median 54.5 | 14 | 96
| CABG | 50 | 46 | Median 58.8 | 30 | 98
ARTS ^37^ | PCI | 600 | 593 | 61.0 | 23 | | | | 27.2
| CABG | 605 | 579 | 61.0 | 24 | | | | 27.4
AWESOME ^50^ | PCI | 222 | 213 | 67.0
| CABG | 232 | 215 | 67.0
BARI ^58^ | PCI | 915 | 904 | 61.8 | 27 | 91 | 5
| CABG | 914 | 892 | 61.1 | 26 | 89 | 7
CABRI ^87^ | PCI | 541 | 522 | 60.3 | 22 | | | | 26.1
| CABG | 513 | 478 | 60.0 | 22 | | | | 26.4
EAST ^94^ | PCI | 198 | 196 | 61.8 | 25 | 93 | 7 | 0.5
| CABG | 194 | 193 | 61.4 | 27 | 94 | 6 | 0
ERACI-I ^104^ | PCI | 63 | 55 | 59.0 | 19
| CABG | 64 | 56 | 55.0 | 11
ERACI-II ^106^ | PCI | 225 | 222 | 62.5 | 23 | | | | 28.8 % obese
| CABG | 225 | 208 | 61.4 | 19 | | | | 23.5 % obese
GABI ^109^ | PCI | 182 | 176 | 65.0 | 21
| CABG | 177 | 161 | 65.0 | 20
Groningen ^112^ | PCI | 51 | 51 | 61.0 | 25
| CABG | 51 | 48 | 60.0 | 22
Lausanne ^116^ | PCI | 68 | 68 | 57.0 | 20
| CABG | 66 | 59 | 54.0 | 20
Leipzig ^118^ | PCI | 110 | 110 | 62.5 | 28 | | | | 28.2
| CABG | 110 | 110 | 61.6 | 23 | | | | 27.2
MASS-I ^121^ | PCI | 72 | | 54.0 | 19
| CABG | 70 | | 58.0 | 17
MASS-II ^123^ | PCI | 205 | 194 | 60.0 | 33
| CABG | 203 | 198 | 60.0 | 28
Myoprotect I ^126^ | PCI | 23 | 23 | 69.0 | 17
| CABG | 21 | 21 | 71.0 | 43
Octostent ^127^ | PCI | 138 | 131 | 60.3 | 30 | | | | BMI>30: 17%
| CABG | 142 | 136 | 58.9 | 28 | | | | BMI>30: 15%
Poland ^130^ | PCI | 50 | 50 | 53.3 | 16 | | | | BMI>30: 26%
| CABG | 50 | 50 | 54.1 | 18 | | | | BMI>30: 20%
RITA-1 ^132^ | PCI | 510 | 493 | | 17
| CABG | 501 | 490 | | 21
Seoul-Hong ^34^ | PCI | 119 | | 60.5 | 36 | | | | 25.5
| CABG | 70 | | 61.4 | 36 | | | | 26.6
Seoul-Kim ^35^ | PCI | 50 | 49 | 61 | 40
| CABG | 50 | 49 | 63 | 30
SIMA ^138^ | PCI | 63 | 62 | 59.0 | 24
| CABG | 60 | 54 | 60.0 | 17
SoS ^139^ | PCI | 488 | 480 | 61.0 | 20
| CABG | 500 | 487 | 62.0 | 22
Toulouse ^146^ | PCI | 76 | 76 | 66.0 | 28
| CABG | 76 | 76 | 68.0 | 18

PCI=percutaneous coronary intervention; CABG=coronary artery bypass graft; 1 study (EAST) reported data on number of patients working full time; 2 studies (MASS and MASS-II) reported data on % of patients employed; 1 study (RITA-1) reported on patients not working due to coronary disease; 1 (BARI) study reported data on education high school or less.

Appendix Table 2. RCT subject clinical characteristics

Trial | Intervention | Diabetes % | HTN % | Hyperlipidemia % | Current smoking % | Ever smoking % | Prior stroke % | PVD% | Family history coronary disease % | Stable angina % | Unstable angina % | LVEF (mean) | Prior MI % | Heart failure (present) %
AMIST ^36^ | PCI | | | | | | | | | | 18
| CABG | | | | | | | | | | 20
ARTS ^37^ | PCI | 19 | 45 | 58 | 28 | | | 6 | 39 | 57 | 37 | 61 | 44
| CABG | 16 | 45 | 58 | 26 | | | 5 | 42 | 60 | 35 | 60 | 42
AWESOME ^50^ | PCI | 29 | 67 | | | | 9 | | | | 100 | 47 | 70
| CABG | 34 | 69 | | | | 14 | | | | 100 | 44 | 71
BARI ^58^ | PCI | 19 | 49 | | | | | 9 | | 32 | 63 | 57 | 54 | 9
| CABG | 20 | 49 | | | | | 8 | | 29 | 65 | 58 | 55 | 9
CABRI ^87^ | PCI | 12 | 35 | 58 | 15 | 58 | 6‡ | 8 | | 81 | 14 | 63 | 41
| CABG | 12 | 37 | 43 | 13 | 55 | 5‡ | 6 | | 80 | 15 | 63 | 42
EAST ^94^ | PCI | 25 | 54 | 36 | 70 | 45 | | | | | | 61 | 41 | 3
| CABG | 21 | 52 | 38 | 21 | 42 | | | | | | 62 | 41 | 4
ERACI-I ^104^ | PCI | 11 | 52 | 56 | 62 | | | | | | 76 | 59 | 51
| CABG | 11 | 58 | 61 | 70 | | | | | | 89 | 62 | 48
ERACI-II ^106^ | PCI | 17 | 71 | 63 | 54 | | | 19 | | | 92 | | 29
| CABG | 17 | 71 | 60 | 50 | | | 27 | | | 91 | | 28
GABI ^109^ | PCI | 10 | 42 | 60 | | 70† | 5 | 8 | | | 13 | | 46
| CABG | 15 | 39 | 61 | | 67† | 2 | 8 | | | 15 | | 47
Groningen ^112^ | PCI | 18 | | 45 | 28 | 30 | | | | 100 | | | 18
| CABG | 8 | | 41 | 25 | 37 | | | | 100 | | | 24
Lausanne ^116^ | PCI | 12 | 46 | 50 | 59 | | | | 50 | | 12
| CABG | 12 | 41 | 52 | 52 | | | | 48 | | 8
Leipzig ^118^ | PCI | 34 | 72 | 70 | 25 | | | 18 | | | | 63 | 45
| CABG | 25 | 71 | 73 | 25 | | | 17 | | | | 63 | 45
MASS-I ^121^ | PCI | 15 | 34 | | 36 | | | | | 100 | | 77
| CABG | 18 | 30 | | 37 | | | | | 100 | | 74
MASS-II ^123^ | PCI | 23 | 61 | | | 27† | | | | | | 67 | 52
| CABG | 29 | 63 | | | 32† | | | | | | 67 | 41
Myoprotect I ^126^ | PCI | 39 | 96 | | | | | | | | 78 | 52
| CABG | 86 | 86 | | | | | | | | 57 | 56
Octostent ^127^ | PCI | 9 | 33 | 59 | 25 | | 1 | 7 | | 50 | 22 | | 25
| CABG | 14 | 31 | 6 | 19 | | 2 | 7 | | 46 | 24 | | 23
Poland ^130^ | PCI | 8 | 52 | 78 | 52 | | | 40 | | 90 | 10
| CABG | 6 | 56 | 76 | 48 | | | 44 | | 92 | 8
RITA-1 ^132^ | PCI | | | | | | | | | 39 | 55 | | 43
| CABG | | | | | | | | | 38 | 55 | | 42
Seoul-Hong ^34^ | PCI | 37 | 50 | 55 | 40 | | 3 | | | | 50 | 53 | 22
| CABG | 49 | 56 | 51 | 46 | | 3 | | | | 43 | 52 | 23
Seoul-Kim ^35^ | PCI | 20 | 55 | 60 | 45 | | 2 | | | 35 | 65 | 51 | 22
| CABG | 15 | 55 | 70 | 55 | | 2 | | | 45 | 55 | 49 | 22
SIMA ^138^ | PCI | 11 | 44 | 60 | 56 | | 2 | | 35 | | 48 | 67 | 2
| CABG | 13 | 47 | 53 | 50 | | 2 | | 27 | | 48 | 67 | 2
SoS ^139^ | PCI | 14 | 43 | 53 | 16 | 53 | 1 | 6 | 48 | 43 | | 57 | 44
| CABG | 15 | 47 | 50 | 14 | 57 | 3 | 7 | 48 | 48 | | 57 | 47
Toulouse ^146^ | PCI | 15 | 41 | 36 | 51 | | | | | | | <40 in 3 | 37
| CABG | 12 | 43 | 36 | 54 | | | | | | | <40 in 3 | 38

HTN=hypertension; PVD=peripheral vascular disease; LVEF=left ventricular ejection fraction; MI=myocardial infarction; PCI=percutaneous coronary intervention; CABG=coronary artery bypass grafting

† Current or former smoking;

‡ Prior stroke or transient ischemic attack

Octostent reported prior PCI among 4% and 5% of patients in the PCI and CABG arms, respectively.

AWESOME reported prior PCI among 17% and 22% of patients in the PCI and CABG arms, respectively.

AWESOME reported prior CABG among 30% and 32% of patients in the PCI and CABG arms, respectively.

AWESOME reported MI within the past 7 days for 35% and 32% among PCI and CABG arms, respectively

RITA-1 reported 36 and 33 asymptomatic patients in the PCI and CABG arms, respectively

Myoprotect I reported 10 patients each in PCI and CABG arms who underwent reoperation.

Appendix Table 3. RCT interventions

| | | | | | PCI adjunctive treatment recommended | | | | CABG procedures
Trial | Group | Complete revascularization achieved % | Vessels treated (mean) | Stents used (mean) | Type of stent used | ASA | Heparin | Gycloprotein 2b/3a Inhibitors | Other treatment | Bypass mode | Cardioplegia type | Incision Type | Arterial Grafts (% of patients) | Anastamoses (mean) | Bypass time (mean)
AMIST ^36^ | PCI | | | | | ✓ | ✓ | | T
| CABG | | | | | ✓ | ✓ | | T
ARTS ^37^ | PCI | | | | BMS | | | | | | | | 93%
| CABG | | | | | | | | | | | | | 2.6 | 234
AWESOME ^50^ | PCI | | | | Stents in 54%, type not specified | | | 11%
| CABG | | | | | | | | | | | | 76% | 2.9
BARI ^58^ | PCI | | 2.5
| CABG | | | | | | | | | | Blood 47%; Crystaloid: 60 | | 82% | 3.1 | 91
CABRI ^87^ | PCI | 99 | 2.1*
| CABG | 97 | 2.8*
EAST ^94^ | PCI
| CABG
ERACI-I ^104^ | PCI | 51 | 1.7 | 0 | BMS (Gianturco Robin III) | ✓ | ✓
| CABG | 88 | | | | | | | | Hypothermia: 100% | Blood: 100% | | 77%
ERACI-II ^106^ | PCI | 50 | | 1.4 | | ✓ | ✓ | 28% | T
| CABG | 85 | | 0.08 | | ✓ | ✓ | ✓ | T | | | | 88%
GABI ^109^ | PCI | 86 | 1.9
| CABG | | 2.2 | | | | | | | | | | 37%
Groningen ^112^ | PCI | | | | BMS | ✓ | ✓ | | T
| CABG | | | | | ✓ | ✓ | | T | None: 100% | | Median sternotomy: 2%; Midcab: 98%
Lausanne ^116^ | PCI | | | | | ✓ | ✓
| CABG | | | | | ✓ | ✓ | | | None: 100% | Crystaloid: 100% | Median sternotomy: 100% | 100%
Leipzig ^118^ | PCI | | 1.0 | 1.2 | BMS (GFX, Pura-Vario, Inflow, Micro II, MAC, MAC Carbon, Sito) | ✓ | ✓ | 2% | T/C
| CABG | | 1.0 | | | | ✓ | | | None: 100% | | Median sternotomy: 5%; Midcab 95%
MASS-I ^121^ | PCI | | 1.0 | | | ✓ | ✓
| CABG | | 1.0 | | | ✓ | ✓ | | | Hypothermia: 100% | | | 100%
MASS-II ^123^ | PCI | | 2.1
| CABG | | | | | | | | | Normothermic: 100% | Blood: 100% | | 92% | 3.3
Myoprotect I ^126^ | PCI | | 1.0 | | Stent (PUVA or MAC)
| CABG | | 2.6
Octostent ^127^ | PCI | | 1.5 | 1.4 | Stent type not specified | | | 12%
| CABG | | | | | | | | | None: 100% | | Median sternotomy: 67%; Midcab 30% | 100%
Poland ^130^ | PCI | | | | BMS (Tristar, Tera, or Penta-Guidant) | ✓ | ✓ | | T
| CABG | | | | | | | | | None: 100% | | Midcab: 100%
RITA-1 ^132^ | PCI | 81 | 1.6** | 0 | None
| CABG | 97 | 2.1† | 0 | | | | | | | | | 74% | 2.1
Seoul-Hong ^34^ | PCI | | | 1.2 | Drug-coated stent (sirolimus n=115, paclitaxel n=28) | | ✓ | | T/C
| CABG | | | | | | | | | None: 100% | | Midcab: 100%
Seoul-Kim ^35^ | PCI | | | | | ✓ | ✓ | | T
| CABG | | | | | | | | | None: 100% | | Midcab: 100%
SIMA ^138^ | PCI
| CABG | | | | | | | | | None: 6; Hypothermia: 47 | | | 98%
SoS ^139^ | PCI | | 2.7 | median: 2 | BMS | | | 40
| CABG | | | | | | | | | None: 16 | | | | 2.8 | 70 (median)
Toulouse ^146^ | PCI | 84 | 2.0
| CABG | 92 | | | | | | | | | | | 58% | 2.3

RCT=randomized controlled trials; PCI=percutaneous coronary intervention; CABG=coronary artery bypass grafting; BMS=bare metal stent; ASA=aspirin; R=recommended; T=Ticlopidine; C=Clopidogrel; MIDCAB=minimally-invasive coronary artery bypass grafting;

* segments;

** angioplasties;

† grafts;

AWESOME recommended PCI adjunctive treatment but did not specify medication

Appendix Table 4. Procedural (30-day) complications from the RCTs

Trial | Intervention | Procedural Survival %* | Freedom from Procedural non-fatal MI %* | Other short-term complications*
| | | | Freedom from Stroke % | NI %** | CHF % | Respiratory failure^a^ % | Renal failure % | PCI re-intervention % | Surgical re-intervention % | Local hematoma % | Pleural effusion % | Major adverse coronary event %
AMIST ^36^ | PCI | 100 | 100 | | 1.0
| CABG | 100 | 100 | | 3.0 | | | | | 2.0
ARTS ^37^ | PCI | 98.5 | 96.8 | 98.3 | | | | | 0.3 | 0.2
| CABG | 98.7 | 97.7 | 97.9 | | | | | | 2.3
AWESOME ^50^ | PCI | 97 | NR | 99.1 | | | | 1.8 | 2.3 | 4.1
| CABG | 95 | NR | 98.7 | | | | 1.3 | 1.7 | 0.0
BARI ^58^ | PCI | 98.9 | 97.9 | 99.8 | | 2.3 | 1.0 | 0.2
| CABG | 98.7 | 95.5 | 99.2 | | 3.8 | 2.2 | 0.1
CABRI ^87^ | PCI | 98.7 | NR
| CABG | 98.7 | NR
EAST ^94^ | PCI | 99 | 97 | 99.5 | | | | | | 0.0
| CABG | 99 | 89.7 | 98.5 | | | | | | 1.5
ERACI-I ^104^ | PCI | 98.4 | 93.7 | | 1.6 | | | | 1.6
| CABG | 95.3 | 93.8 | | 3.1 | | | | | 1.6
ERACI-II ^106^ | PCI | 99.1 | 91 | 100 | | | | | 1.8 | | | | 3.6
| CABG | 94.3 | 94.3 | 99.1 | | | | | | | | | 1.2
GABI ^109^ | PCI | 98.9 | 97.8 | 100 | | | 1.1 | | 2.7 | 0.0
| CABG | 97.7 | 92.1 | 98.9 | | | 9.6 | | 0.6 | 3.4
Groningen ^112^ | PCI | 100 | 90.2 | 98 | | | | | | 0.0
| CABG | 96.1 | 98 | 100 | | | | | | 2.0
Lausanne ^116^ | PCI | 100 | 97.1
| CABG | 100 | 98.5
Leipzig ^118^ | PCI | 100 | 98.2 | 100 | | | | | 1.8 | | 2.0
| CABG | 98.2 | 96.4 | 99.1 | | | | | | 2.7
MASS-I ^121^ | PCI | 100 | 97.2 | 100
| CABG | 100 | 98.6 | 100
MASS-II ^123^ | PCI | 97.6 | 99 | 99
| CABG | 97.5 | 99 | 97
Myoprotect I ^126^ | PCI | 91.3 | NR
| CABG | 90.5 | NR
Octostent ^127^ | PCI | 100 | 97.8 | 100 | | | | | 2.2 | 1.4
| CABG | 98.6 | 96.5 | 100 | | | | | 1.4 | 0.7
Poland ^130^ | PCI | 100 | 98 | | | | | | 6.0 | | 4.0 | 0.0 | 6.0
| CABG | 100 | 100 | | | | | | 0.0 | | 0.0 | 4.0 | 0.0
RITA-1 ^132^ | PCI | 99.2 | 96.5 | 99.8* | | 0.2*
| CABG | 98.8 | 97.6 | 99* | | 0.6*
Seoul-Hong ^34^ | PCI | 98.3 | 96.7 | 100 | | | | | 1.7 | | 4.2 | 0.0
| CABG | 98.6 | 97.1 | 98.6 | | | | | 1.4 | | 0.0 | 2.9
Seoul-Kim ^35^ | PCI | 100 | 96 | | | | | | 2.0 | 2.0 | | | 4
| CABG | 100 | 98 | | | | | 2 | 2.0 | 0.0 | | | 2
SIMA ^138^ | PCI | 98.4 | 95.2 | 98.4
| CABG | 100 | 96.7
SoS ^139^ | PCI | NR | 96.1
| CABG | NR | 98.4
Toulouse ^146^ | PCI | 98.7 | 96.1
| CABG | 98.7 | 94.7 | | | | 5.3

RCTs=randomized controlled trials; MI=myocardial infarction; NI=nosocomial infection; CHF=congestive heart failure; PCI=percutaneous coronary intervention; CABG=coronary artery bypass grafting; NR=not reported

* Percentage based on the number of subjects randomized at the start of the study.

** Wound infection

a=Respiratory failure or other pulmonary complication

Appendix Table 5. BARI, EAST, AWESOME RCT/registry demographics

Study | Intervention | RCT/Registry | Number of subjects at start of study | Length of follow-up | Age (Mean) | Women % | White % | African-American % | Diabetes %
BARI | PCI | RCT | 915 | 7 years | 61.8 | 27 | 91 | 5 | 19
BARI | PCI | Registry | 1189 | 7 years | 61.0 | 26 | | | 15
BARI | CABG | RCT | 914 | 7 years | 61.4 | 26 | 89 | 7 | 20
BARI | CABG | Registry | 625 | 7 years | 62.5 | 26 | | | 19
EAST | PCI | RCT | 198 | 8 years | 61.8 | 25 | 93 | 7 | 25
EAST | PCI | Registry | 168 | 3 years | 60.3 | 24.4 | 92.8 | | 19.2
EAST | CABG | RCT | 194 | 8 years | 61.4 | 27 | 94 | 6 | 21
EAST | CABG | Registry | 270 | 3 years | 62.6 | 18.9 | 96.3 | | 21.6
AWESOME | PCI | RCT | 222 | 5 years | 67 | | | | 29
AWESOME | PCI | Registry—Physician-Directed | 651 | 5 years | 66 | | | | 31
AWESOME | PCI | Registry—Patient-Choice | 207 | 5 years | 66 | | | | 32
AWESOME | CABG | RCT | 232 | 5 years | 67 | | | | 34
AWESOME | CABG | Registry—Physician-Directed | 692 | 5 years | 69 | | | | 36
AWESOME | CABG | Registry—Patient-Choice | 95 | 5 years | 68 | | | | 22

RCT=randomized controlled trial; PCI=percutaneous coronary intervention; CABG=coronary artery bypass grafting

Appendix Table 6. BARI, EAST, AWESOME RCT/registry clinical characteristics

Study | Intervention | RCT/Registry | Hypertension % | Hyperlipidemia % | Prior MI % | Heart failure % | Current Smoking % | Stable angina% | Unstable Angina % | Ejection Fraction (mean) | Prior stroke % | Peripheral vascular disease % | Number diseased vessels (mean)
BARI | PCI | RCT | 49 | | 54 | 9 | | 32 | 63 | 57.1 | | 9 | 2.39
BARI | PCI | Registry | 47 | | 50 | 5 | 70 | 32 | 68 | | | 14 | 3.0
BARI | CABG | RCT | 49 | | 55 | 9 | | 29 | 65 | 57.6 | | 8 | 2.41
BARI | CABG | Registry | 52 | | 50 | 6 | 64 | 30 | 70 | | | 15 | 3.6
EAST | PCI | RCT | 54 | 36 | 41 | 3 | 70 | | | 60.8 | | | 3.4
EAST | PCI | Registry | 48.8 | | 35.7 | 4.2 | 63.7 | CCS III/IV=71.2. | | 60.9
EAST | CABG | RCT | 52 | 38 | 41 | 4 | 21 | | | 62 | | | 3.4
EAST | CABG | Registry | 54.4 | | 41.9 | 3.3 | 66.7 | CCS III/IV=75.2. | | 59.7
AWESOME | PCI | RCT | 67 | | 70 | | | | 100 | 47 | 9 | | 2.2
AWESOME | PCI | Registry—Physician-Directed | 66 | | 65 | 57 | 32 | | | | 11
AWESOME | PCI | Registry—Patient-Choice | 64 | | 61 | 60 | 36 | | | 46 | 9
AWESOME | CABG | RCT | 69 | | 71 | | | | 100 | 44 | 14 | | 2.33
AWESOME | CABG | Registry—Physician-Directed | 69 | | 51 | 83 | 28 | | | 43 | 11
AWESOME | CABG | Registry—Patient-Choice | 66 | | 54 | 47 | 33 | | | 45 | 7

RCT=randomized controlled trial; MI=myocardial infarction; PCI=percutaneous coronary intervention; CABG=coronary artery bypass grafting; CCS=Canadian Cardiovascular Society

Appendix Table 7. Survival in patients with or without diabetes

Trial | Subgroup | PCI | | | | CABG
| | N randomized | 1 year Survival (%) | N at 5 years | 5 year Survival (%) | N randomized | 1 year Survival (%) | N at 5 years | 5 year Survival (%)
ARTS | DM | 112 | 93.8 | | | 96 | 96.9
| No DM | 488 | 98.4 | | | 509 | 97.2
AWESOME | DM | 65 | 86.0 | | 74.0 | 79 | 81.0 | | 74.0
BARI | No DM or untreated DM | 742 | | 468 | 91.1 | 734 | | 449 | 91.1
| Treated DM | 173 | | 69 | 65.5 | 180 | | 93 | 80.5
EAST | DM | 29 | | 26 | 89.7 | 30 | | 27 | 90.0
| No DM | 169 | | 148 | 87.6 | 164 | | 150 | 91.5
ERACI-II | DM | 39 | | | 90.0 | 39 | | | 89.8
| No DM | 186 | | | 93.6 | 186 | | | 88.2
MASS-II | DM | 56 | 94.6 | | 89.3 | 59 | 93.2 | | 91.5
| No DM | 149 | 94.6 | | 92.6 | 144 | 95.1 | | 88.9

PCI=percutaneous coronary intervention; CABG=coronary artery bypass grafting; DM=diabetes mellitus

Appendix Table 8. CABG volume-outcomes primary studies and coverage in previous reviews

Study (Author, Journal) | Citation Year | Sowden CABG | Kalant CABG | Halm CABG | Dudley CABG
Luft HS et al. ^225^ | 1979 | YES | YES | NO | NO
Luft ^231^ | 1980 | NO (ex) | NO | NO | NO
Maerki SC et al. ^226^ | 1986 | YES | NO (ex) | NO | NO
Sloan et al. ^232^ | 1986 | NO (ex) | NO | NO | NO
Hughes RG et al. ^233^ | 1987 | NO (ex) | YES (H&P) | NO | YES
Kelly JV et al. ^234^ | 1987 | NO | YES | NO | NO
Luft HS et al. ^235^ | 1987 | NO (ex) | NO (cited) | NO (cited) | YES
Riley G et al. ^183^ | 1985 | YES | YES | NO | NO
Rosenfeld et al. ^236^ | 1987 | YES | NO | NO | NO
Rosenfeld K et al. ^236^ | 1987 | NO (ex) | YES | NO | NO
Showstack JA et al. ^237^ | 1987 | YES | YES | YES | YES
Hannan EL et al. ^197^ | 1989 | YES | YES (H&P) | YES (H&P) | YES
Hannan et al. ^199^ | 1990 | NO | NO (ex) | NO | NO
Hannan EL et al. ^198^ | 1991 | NO | NO | YES (H&P) | YES
Williams SV et al. ^238^ | 1991 | NO (ex) | NO (ex) | NO | NO
Zelen J et al. ^239^ | 1991 | NO (ex) | NO (ex) | NO | NO
Farley DE et al. ^240^ | 1992 | NO (ex) | YES | YES | YES
Hannan EL et al. ^190^ | 1994 | YES | YES (H&P) | NO | NO (cited)
Grumbach K et al. ^241^ | 1995 | NO | YES | NO | NO
Hannan EL et al. ^195^ | 1995 | NO | YES (P) | YES | NO
Clark RE et al. ^211^ | 1996 | NO | YES | NO | NO
Shroyer AL et al. ^242^ | 1996 | NO | NO (cited) | YES | YES
Ghali WA et al. ^243^ | 1998 | NO | YES | NO | NO
Sollano JA et al. ^200^ | 1999 | NO | YES | NO | NO
Brown PP et al. ^244^ | 2001 | NO | YES | NO | NO
Nallamothu BK et al. ^245^ | 2001 | NO | NO (ex) | NO | NO
Birkmeyer JD et al. ^177^ | 2002 | NO | YES | NO | NO
Birkmeyer JD et al. ^178^ | 2003 | NO | NO | NO | NO
Hannan EL et al. ^194^ | 2003 | NO | NO | NO | NO
Rosenthal GE et al. ^192^ | 2003 | NO | NO | NO | NO
Birkmeyer JD et al. ^227^ | 2004 | NO | NO | NO | NO
Peterson ED et al. ^210^ | 2004 | NO | NO | NO | NO
Wu C et al. ^191^ | 2004 | NO | NO | NO | NO
Rathore et al. ^246^ | 2004 | NO | NO | NO | NO
Carey JS et al. ^212^ | 2005 | NO | NO | NO | NO
Epstein AJ et al. ^228^ | 2005 | NO | NO | NO | NO
Glance LG et al. ^189^ | 2005 | NO | NO | NO | NO
Welke ^185^ | 2005 | NO | NO | NO | NO

CABG=coronary artery bypass grafting

Table Notes:

1) “NO (ex)” means that the article was identified in the review's search, but excluded from the analysis, often because the data duplicated that of other studies included. “NO” means that the article was not reported in the systematic review. “YES” means that the article was included in the systematic review's analysis for hospital volume, unless the YES is followed by “(P)” meaning that only provider volume was available. If the YES is followed by “(H&P)” both hospital and provider volume-outcomes results were reported in the review. NO (cite) means that the article was not included in the analysis, nor were exclusion reasons given, but the article was cited in the review.
2) Shaded citations were not cited in any reviews and therefore were abstracted and provided in this report to supplement the previous systematic review findings.
3) “NO (ex)” means that the article was identified in the review's search, but excluded from the analysis, often because the data duplicated that of other studies included. “NO” means that the article was not reported in the systematic review. “YES” means that the article was included in the systematic review's analysis for hospital volume, unless the YES is followed by “(P)” meaning that only provider volume was available. If the YES is followed by “(H&P)” both hospital and provider volume-outcomes results were reported in the review. NO (cite) means that the article was not included in the analysis, nor were exclusion reasons given, but the article was cited in the review.
4) Shaded citations were not cited in any reviews and therefore were abstracted and provided in this report to supplement the previous systematic review findings.

Appendix Table 9. PCI volume-outcomes primary studies and coverage in previous reviews

Study (Author, Journal) | Citation Year | Halm | Dudley
Ritchie JL et al. ^247^ | 1993 | YES | YES
Jollis JG et al. ^179^ | 1994 | YES | YES
Kimmel, SE et al. ^248^ | 1995 | NO | YES
Phillips KA et al. ^249^ | 1995 | YES | YES
Ellis SG et al. ^250^ | 1996 | NO | NO
Ellis SG et al. ^251^ | 1997 | NO | NO
Hannan EL et al. ^196^ | 1997 | YES (H&P) | YES
Jollis JG et al. ^180^ | 1997 | YES (H&P) | YES
Kastrati A et al. ^252^ | 1998 | NO | NO
McGrath PD et al. ^205^ | 1998 | YES (P) | NO
Malenka DJ et al. ^204^ | 1999 | YES (P) | NO
Maynard C et al. ^253^ | 1999 | YES | NO
Ritchie JL et al. ^184^ | 1999 | NO | NO
Ritchie JL et al. ^254^ | 1999 | YES | NO
Ho V ^255^ | 2000 | YES | NO
Maynard C et al. ^181^ | 2000 | NO | NO
McGrath PD et al. ^182^ | 2000 | YES (H&P) | NO
Ho V ^256^ | 2002 | NO | NO
Kimmel SE et al. ^257^ | 2002 | NO | NO
Watanabe CT et al. ^258^ | 2002 | NO | NO
Brown DL et al. ^259^ | 2003 | NO | NO
Birkmeyer JD et al. ^227^ | 2004 | NO | NO
Epstein AJ et al. ^21^ | 2004 | NO | NO
Harjai KJ et al. ^260^ | 2004 | NO | NO
Carey JS et al. ^212^ | 2005 | NO | NO
Epstein AJ et al. ^228^ | 2005 | NO | NO
Hannan EL et al. ^193^ | 2005 | NO | NO
Moscucci M et al. ^261^ | 2005 | NO | NO
Burton KR et al. ^207^ | 2006 | NO | NO

PCI=percutaneous coronary intervention

Appendix Table 10. Basic finding from primary studies of PCI volume-outcomes in clinical registries

Citation | Population | Year(s) | # Pts | Hosp Vol Levels | Hosp Vol-Death* | Hosp Vol-CABG* | Dr Vol Levels | Dr Vol-Death* | Dr Vol-CABG* | Notes
Primary Studies: National
Kimmel S et al. ^248^ | Society for Cardiac Angiography and Interventions Registry | 1992**-1993 | 19,594 | <200, 200–399, 400–599, 600+; AND <200 vs. 200+ | yes^§^ | yes | | n/a | n/a | Hosp cutoff <200 vs. 400+. Sample restricted to cases of balloon angioplasty only.
Primary Studies: Regional/State
McGrath P et al. ^205^ | Northern New England Cardiovascular Disease Study Group | 1990-1993 | 12,988 | | n/a | n/a | 23–85, 89–144, 153–463 | no | yes
Malenka et al. ^204^ | | 1994-1996 | 15,080 | | n/a | n/a | 22–84, 88–129, 138–370 | no | no | All operators performed in high volume hospitals (>600 procedures per year).
Hannan E Racz et al. ^196^ | Coronary Angioplasty Reporting System (NY State Registry) | 1991-1994 | 62,670 | <400, 400–599, 600–799,800–999, 1000+ | yes^§^ | yes | <75, 75–124, 125–174, 175–249, 250+ | yes | yes | Hosp cutoff <400. Dr cutoff <75.
Hannan E et al. ^193^ | | 1998-2000 | 107,713 | 400, 500, 600 cutoffs | yes | yes | 75, 100, 125 cutoffs | no | yes
Ellis S et al. ^251^ | Quality-controlled databases at 5 high-volume centers (Cleveland Clinic central data repository) | 1993-1994 | 12,985 | | n/a | n/a | 70-, 70–99, 100–142, 142–270, 270+ | yes | yes | All at high volume hospitals (>1,000)
Burton K et al. ^207^ | Scottish Coronary Revascularization Register | 1997-2003 | 17,417 | <400, 400–750, 750+ | no | n/a | | n/a | n/a | Long-term f/up analysis
Harjai K et al. ^260^ | William Beaumont Hospital Interventional Cardiology database | 1999-2001 | 12,293 | | n/a | n/a | 92-, 93–140, >140 | no | no | High-volume hospital
Moscucci M et al. ^261^ | Michigan regional | 2002 only | 18,504 | | n/a | n/a | 1–33, 34–89, 90–139, 140–206, 207–582; AND 75 cutoff | no | yes (with other cardiac events)
Primary Studies: Institutional
Ellis S et al. ^250^ | Cleveland Clinic Interventional Database (multicenter) | 1990-1996 | 4,860 | | n/a | n/a | 25–75, 75+ | n/a | n/a | Results by individual provider only, with one outlier per volume group.
Kastrati A et al. ^252^ | Deutsches Herzzentrum Munchen database | 1992-1997 | 3,409 | | yes (with MI, CABG) | yes (with death, MI) | 80-, 80–168, 169–298, 299–483, 483+ | yes | yes | Dr. cutoff <70.

PCI=percutaneous coronary intervention; Pts=patients; Hosp=hospital; Vol=volume; Dr=physician; CABG=coronary artery bypass grafting; RA= Risk adjusted; AE= Adverse events; HCUP= Healthcare Cost and Utilization Project; N/A=not available

* Yes/No answers to whether risk adjusted mortality and same stay CABG outcomes are significantly associated with hospital and doctor volume.

** The first year of each data source is bolded, though analyses may vary by study in subsequent years. Common data sources are boxed. Study citation and their results are shaded in cases where there is overlap between studies (e.g., a common year from the same data source in more than one study).

§ Yes and no bolded for answers without qualifiers related to risk adjustment (RA) or outcomes

Appendix Table 11. Basic finding from primary studies of PCI volume-outcomes in administrative data

Citation | Population | Year(s) | # Pts | Hosp Vol Levels | Hosp Vol-Death* | Hosp Vol-Same Stay CABG* | Dr Vol Levels | Dr Vol-Death* | Dr Vol-Same Stay CABG* | Notes
Primary Studies: National
Jollis J et al. ^179^ | Medicare Provider Analysis and Review | 1987**-1990 | 217,836 | 50-, 50–100, 100+ | yes | yes (not RA) | | n/a | n/a
Jollis, J et al. ^180^ | | 1992 only | 97,478 | 100-, 100–200, 200+ | yes (with CABG) | yes (with death) | 25-, 25–50, 50+ | n/a | yes | Association for hosp cutoff <200. Dr cutoff <75.
Ritchie et al. ^184^ | | 1994 and 1996 | 165,657(1994); 201,869 (1996) | 100-, 101–200, 200+ | no - 1994 (not RA); no - 1997 (not RA) | yes - 1994 (not RA); no - 1996 (not RA) | | n/a | n/a
Maynard C et al. ^181^ | | 1996 only | 201,869 | 100-, 101–200, 200+ | yes (not RA) | yes (not RA) | | n/a | n/a
McGrath P et al. ^182^ | | 1997 only | 167,208 | 80-, 80–160, 160+ | yes | yes | 30-, 30–60, 60+ | no | n/a | Study reports stent analysis. Dr-Hosp interaction analysis.
Ritchie J et al ^254^ | HCUP Nationwide Inpatient Sample | 1993-1994 | 163,527 | 200-, 201–400, 400+ | yes | yes | | n/a | n/a
Watanabe C et al. ^258^ | | 1994 and 1997 | 202,584 | 201-, 201–400, 400+ | no - 1994 (not RA); yes - 1997 (not RA) | n/a | | n/a | n/a | Study reports stent analysis.
Epstein A et al. ^21^ | | 1998-2000 | 362,748 | 5–199, 200–399, 400–999, 1000+ | yes | n/a | | n/a | n/a | Association for hosp cutoff <200 vs. 400–999.
Epstein A et al. ^228^ | | 1998-2001 | 2,500,796 | 400-, 400+ | yes | n/a | | n/a | n/a
Birkmeyer J et al. ^227^ | | 2000 only | 678,296 | 400 cutoff | yes | n/a | | n/a | n/a
Primary Studies: Regional/State
Ho V. ^255^ and Ho V. ^256^ | California Office of Statewide Health Planning | 1984-1996 | 353,488 | 200-, 200–400, 400+ | yes | n/a | | n/a | n/a | Analysis divided into: 84–87, 88–92, 93–96. Association less clear in 93–96.
Phillips K et al. ^249^ and Ritchie et al. ^247^ | | 1989 only | 24,856 | 201-, 201–400, 400+ | yes (with CABG) | yes (with death) | | n/a | n/a | Association for hospital cutoff 200 or less vs. 201–400.
Maynard C et al. ^253^ | | 1996 only | 43,040 | <200, 201–400, >400; AND stenting volumes: <85, 85–167, >167) | no | yes | | n/a | n/a
Brown L et al. ^259^ | | 1997 only | 44,276 | 200-, 200–400, 400+ | yes | yes | | n/a | n/a
Carey J et al. ^212^ | | 1999-2001 | 153,755 | 600 cutoff | no | n/a | | n/a | n/a
Kimmel S et al. ^257^ | Pennsylvania Health Care Cost Containment Council database | 1994-1995 | 25,222 | 400-, 400–599, 600–899, 900+ | no | yes | | n/a | n/a

PCI=percutaneous coronary intervention; Pts=patients; Hosp=hospital; Vol=volume; Dr=physician; CABG=coronary artery bypass grafting; RA= Risk adjusted; AE= Adverse events; HCUP= Healthcare Cost and Utilization Project; N/A=not available

* Yes/No answers to whether risk adjusted mortality and same stay CABG outcomes are significantly associated with hospital and doctor volume.

** The first year of each data source is bolded, though analyses may vary by study in subsequent years. Common data sources are boxed. Study citation and their results are shaded in cases where there is overlap between studies (e.g., a common year from the same data source in more than one study).

§ Yes and no bolded for answers without qualifiers related to risk adjustment (RA) or outcomes.

Appendix Table 12. Basic finding from primary studies of CABG volume-outcomes published since 2001

Citation | Population | Year(s) | # Pts | Hosp Vol Levels | Hosp Vol-Death* | Dr Vol Levels | Dr Vol-Death *
Clinical Databases: National
Peterson E et al. ^210^ | Society of Thoracic Surgeons National Cardiac Database | 2000-2001 | 267,089 | 150-, 151–300, 301–450, 450+ | yes^§^ (though not for <65 year subgroup) | 10–85, 86–138, 139+ | n/a
Clinical Databases: Regional/State
Glance L et al. ^189^ | NY State Registry | 1998-1999 | 36,930 | Continuous variable | yes (though not for off-pump procedure) | OFF-PUMP: quartiles: 5-, 5–10, 11–31, 31+; ON-PUMP: 52-, 52–155, 156–273, 273+. | yes (but not for off-pump procedure)
Wu et al. ^191^ | NY State Registry | 1997-1999 | 57,150 | Thresholds between 200–600 cases/yr (units of 100) | yes (especially for low risk patients with expected risk of in-hosp death <2%) | Thresholds between 50–150 cases/yr (units of 25) | yes
Hannan E et al. ^194^ | NY State CSRS database | 1997-1999 | 57,150 | Thresholds between 100–800 cases/yr (units of 100); The % of patients and # of hospitals with annual volumes on either side of each threshold were calculated. | yes | Thresholds between 25–200 cases/year (units of 25) | yes
Rosenthal G et al. ^192^ | Databases from NY State, Northeast Ohio and Dept. of Veterans Affairs Hospitals | 1993-1996 | 73,209 total patients: 19,266 (VA) 44,247 (NY) 9,696 (OH) | 500-, 501–1000, 1000+ | yes (though potentially less so in VA patients where hospital volume varies less) | | n/a
Nallamothu B et al. ^245^ | Solucient EXPLORE database | 1997 | 13,644 | 200-, 200+ | yes (though only for moderate and high patient risk groups with predicted risk of 2–20% in-hospital death) | | n/a
Administrative Databases: National
Birkmeyer J et al. ^178^ | Medicare Claims Database | 1998-1999 | 474,108 (8 procedures) | 314-, 314–628, 628+ | yes | 100-, 101–162, 162+ | yes
Welke K et al. ^185^ | Medicare Provider and Analysis Review (MEDPAR) Part A data files | 1996-2001 | 948,093 | quintiles: 125-, 125–204, 205–299, 300–449, 449+; AND Leapfrog volumes AND deciles | no | | n/a
Rathore S et al. ^246^ | HCUP National Inpatient Sample database | 1998-2000 | 228,738 | 12–249, 250–499, 500+ | yes | | n/a
Birkmeyer J et al. ^227^ | HCUP Nationwide Inpatient Sample | 2000 only | 394,165 (CABG) 678,296 (PCI) | CABG: 450-, 450+/yr PCI: 400-, 400+/yr | yes | | n/a
Epstein A et al. ^228^ | HCUP Nationwide Inpatient Sample | 1998-2001 | 2,500,796 (PCI); 1,496,937 (CABG) | CABG: 450-, 450+/yr; PCI: 400-, 400+/yr | yes | | n/a
Administrative Databases: Regional/State
Carey JS et al. ^212^ | Discharge abstracts from the California Office of Statewide Health Planning | 1999-2001 | 82,353 (CABG) 153,755 (PCI) | CABG: 300-, 300+/yr PCI: 600-, 600+/yr | yes | | n/a

CABG=coronary artery bypass grafting; Pts=patients; Hosp=hospital; vol=volume; Dr=physician; RA= Risk adjusted; AE= Adverse events; CSRS=cardiac surgery reporting system; HCUP= Healthcare Cost and Utilization Project

* Yes/No answers to whether risk adjusted mortality and same stay CABG outcomes are significantly associated with hospital and doctor volume.

** The first year of each data source is bolded, though analyses may vary by study in subsequent years. Common data sources are boxed. Study citation and their results are shaded in cases where there is overlap between studies (e.g., a common year from the same data source in more than one study).

§ Yes and no bolded for answers without qualifiers related to risk adjustment (RA) or outcomes.

Appendix Table 13. Volume distribution for PCI and CABG primary studies

Citation | Population | Hosp Volume Distribution* | Dr Volume Distribution*
Clinical Databases PCI: National
Kimmel S et al. ^248^ | Society for Cardiac Angiography and Interventions registry | LOW (<200 procedures/yr): 10.3% of patients; MEDIUM-LOW (200–399): 31.1%; MEDIUM-HIGH (400–599): 25.8%; HIGH (600+): 32.8%; (48 total hospitals/19,594 total patients) | Not Applicable**
Clinical Databases PCI: Regional/State
McGrath P et al. ^205^ | Northern New England Cardiovascular Disease Study Group (NNECVDSG) database | Not Applicable | LOW (23–85 procedures/yr): 18.8% of patients; MEDIUM (89–144): 28.2%; HIGH (153–463): 53% of patients; (12,088 total patients)
Malenka et al. ^204^ | Northern New England Cardiovascular Disease Study Group (NNECVDSG) database | Not Applicable | LOW (22–84 procedures/yr): 31.9% of doctors/14.4% of patients; MEDIUM (88–129): 34%/27.9%; HIGH (138–370): 34%/57.7%; (47 total doctors / 15,080 total patients)
Hannan E L et al. ^193^ | Coronary Angioplasty Reporting System (CARS) of the NY State Registry | For annual hospital-volume threshold of 400: LOW (<400): 4–5 hospitals/2.3% of patients; HIGH (400+): 29–30 hospitals/97.7% of patients; For annual hospital-volume threshold of 500: LOW (<500): 6–7 hospitals/5.2% of patients, HIGH (500+): 27 hospitals/94.8% of patients; For annual hospital-volume threshold of 600: LOW (<600): 9–10 hospitals/9.8% of patients; HIGH (600+): 23–25 hospitals/90.2% of patients; (34 total hospitals/107,713 total patients) | LOW ( 75-/yr): 29.6%–30.8% of doctors; MEDIUM (100-/yr): 40.1%–40.7%; HIGH (125-/yr): 46.9%–51.87% (263 total doctors)
Hannan E et al. ^196^ | Coronary Angioplasty Reporting System (CARS) of the NY State Registry | LOW (<600 procedures/yr): 68.1% of hospitals; MEDIUM (600–999): 25.4%; HIGH (1000+): 6.5%; | LOW (<75 procedures/yr): 46.0% of doctors; MEDIUM (75–174): 38.0%; HIGH (175+): 16%; (608 total doctors)
Ellis S et al. ^251^ | Quality-controlled databases at 5 high-volume centers, central data analysis center at Cleveland Clinic | Not Applicable | Not Applicable
Burton K R et al. ^207^ | Scottish Coronary Revascularization Register | LOW (<400 procedures/yr): 28% of patients; MEDIUM (400–750): 53% of patients; HIGH (>750): 19% of patients; (17,417 total patients) | Not Applicable
Harjai K et al. ^260^ | William Beaumont Hospital Interventional Cardiology database | Not Applicable | LOW (92- procedures/yr): 14.8% of patients; MEDIUM (93–140): 30.2%; HIGH (140+): 54.9% (28 total doctors / 12,293 total patients)
Moscucci M et al. ^261^ | Michigan regional | Not Applicable | LOW (1–33 procedures/yr): 2.2% of total patients; MEDIUM-LOW (34–89): 11.4%; MEDIUM (90–139): 16.8%; MEDIUM-HIGH (140–206): 27.9%; HIGH (207–582): 41.9% of total patients (165 total doctors / 18,504 total patients) ALSO: For 75 procedures/yr cutoff LOW (<75): 32.7% of doctors; HIGH (75+): 67.3% (165 total doctors)
Clinical Databases PCI: Institutional
Ellis S et al. ^250^ | Cleveland Clinic Interventional Database (multicenter) | Not Applicable | Not Available**
Kastrati A et al. ^252^ | Deutsches Herzzentrum Munchen database | Not Applicable | LOW (<80 procedures/yr): 10% of doctors; MEDIUM-LOW (80–168): 30%; MEDIUM (169–298): 20%; MEDIUM-HIGH (299–483): 10%; HIGH (>483): 30%; (10 total doctors / 3,409 total patients)
Administrative Databases PCI: National
Jollis J et al. ^179^ | Medicare Provider Analysis and Review files | Not Available | Not Applicable
Jollis, J et al. ^180^ | Medicare Provider Analysis and Review files | LOW (<100 procedures/yr): 16.3% of patients; MEDIUM (100–200): 30.2%; HIGH (>200): 53.5%; (984 total hospitals / 97,478 total patients) | LOW (<25 procedures/yr): 37.4% of patients; MEDIUM (25–50): 31.5%; HIGH (50+): 31.1%; (97,478 total patients)
Ritchie et al. ^184^ | Medicare Provider Analysis and Review files | LOW (100- procedures/yr): 9.6% of patients; MEDIUM (101–200): 21.7%; HIGH (200+): 68.7%; (122,220 total patients) | Not Applicable
Maynard, C et al. ^181^ | Medicare Provider Analysis and Review files | LOW (100- procedures/yr): 34% of patients; MEDIUM (101–200): 32%; HIGH (200+): 34%; (996 total hospitals / 201,869 total patients) | Not Applicable
McGrath, PD et al. ^182^ | Medicare Provider Analysis and Review files | LOW (<80 procedures/yr): 5.0% of patients; MEDIUM (80–160 procedures/yr): 13.5%; HIGH (>160): 81.5%; (1,003 total hospitals / 167,208 total patients) | LOW (<30 procedures/yr): 20% of patients; MEDIUM (30–60): 30.8%; HIGH (>160): 49.2%; (6,534 total doctors / 167,208 total patients)
Ritchie JL et al. ^254^ | HCUP Nationwide Inpatient Sample | LOW (200- procedures/yr): 5.0% of patients; MEDIUM (201–400): 21%; HIGH (>400): 74%; (214 total hospitals / 163,527 total patients) | Not Applicable
Watanabe CT et al. ^258^ | HCUP Nationwide Inpatient Sample | 1994: LOW (<201 procedures/yr): 5.2% of patients; MEDIUM (201–400): 19.0%; HIGH (>400): 75.8%; (84,036 total patients) 1997: LOW (<201 procedures/yr): 4.2% of patients; MEDIUM (201–400): 11.3%; HIGH (>400): 84.5%; (118,558 total patients) | Not Applicable
Epstein et al. ^21^ | HCUP Nationwide Inpatient Sample | LOW (5–199 procedures/yr): 4% of patients; MEDIUM (200–399): 12%; HIGH (400–999): 42%; VERY HIGH (1000+): 42% (362,748 total patients) | Not Applicable
Epstein AJ et al. ^228^ | HCUP Nationwide Inpatient Sample | For annual hospital-volume threshold of 400: LOW (<400): 45.1% of hospital year groups/14.0% of patients; HIGH (400+): 54.9% of hospital year groups/86.0% of patients; | Not Applicable
Birkmeyer J et al. ^227^ | HCUP Nationwide Inpatient Sample | Not Available | Not Applicable
Administrative Databases PCI: Regional/State
Ho V. ^255^ and Ho V. ^256^ | Discharge abstracts from the California Office of Statewide Health Planning | Not Available | Not Applicable
Phillips K et al. ^249^ and Ritchie et al. ^247^ | Discharge abstracts from the California Office of Statewide Health Planning | FOR NON-AMI: LOW (>201 procedures/yr): 25.9% of patients; MEDIUM (201–400): 32.6%; HIGH (>400): 41.4% (20,064 total patients); FOR AMI: LOW (>201 procedures/yr): 36.4% of patients; MEDIUM (201–400): 36.5%; HIGH (>400): 27.1% (4,792 total patients) | Not Applicable
Maynard C et al. ^253^ | Discharge abstracts from the California Office of Statewide Health Planning | Not Available | Not Applicable
Brown L et al. ^259^ | Discharge abstracts from the California Office of Statewide Health Planning | LOW (<200 procedures/yr): 46% of patients; MEDIUM (200–400): 34%; HIGH (>400): 20%; (140 total hospitals/18,940 total patients) | Not Applicable
Carey JS et al. ^212^ | Discharge abstracts from the California Office of Statewide Health Planning | For annual hospital-volume threshold of 600 procedures/yr: LOW (<600): 84.0% of hospitals; HIGH (600+): 16.0%; (IN CALIFORNIA) | Not Applicable
Kimmel S et al. ^257^ | Pennsylvania Health Care Cost Containment Council database | LOW (<400 procedures/yr): 17.4% of patients; MEDIUM-LOW (400–599): 14.3%; MEDIUM-HIGH (600–899): 29.6%; HIGH (900+): 38.8%; (43 total labs / 25,222 total patients) | Not Applicable
Clinical Databases CABG: National
Peterson E et al. ^210^ | Society of Thoracic Surgeons National Cardiac Database | LOW (<150 procedures/year): 22.3% of hospitals/ 6.3% of patients; MEDIUM-LOW (151–300): 34.4%/22.5%; MEDIUM-HIGH (301–450): 20.7%/23.1%; HIGH (450+): 22.6%/48.1% (439 total hospitals/267,089 total patients) | Not available
Clinical Databases CABG: Regional/State
Glance L et al. ^189^ | NY State Registry | Not available | Not available
Wu et al. ^191^ | NY State Registry | LOWEST (for 200 procedures/yr cutoff): 3–4 Low-Volume Hospitals (LVH per year), 29–30 High-Volume Hospitals (HVH) per year; LOW (300 cutoff): 5–7 LVH per year, 26–28 HVH per year; MEDIUM (400 cutoff): 10–14 LVH per year, 19–23 HVH per year; MEDIUM-HIGH (500 cutoff): 14–17 LVH per year, 16–19 HVH per year; HIGH (600 cutoff): 18–21 LVH per year, 12–15 HVH per year (57,150 patients) | For annual hospital volume of >600: LOW (125 cutoff): 38–41doctors/year, HIGH (>125): 48–62; For annual hospital volume of <600: LOW (125-) 57–79, HIGH (>125): 21–26 (192 total doctors)
Hannan E et al. ^194^ | NY State CSRS database | LOW (<600 procedures/yr): 35.72% of patients, HIGH (more than 600 procedures/yr): 64.27% (57,150 total patients) | LOW (-125 procedures/year): 29.9% of patients; HIGH (>125 procedures/year): 70.1% (57,150 total patients)
Rosenthal G et al. ^192^ | Databases from NY State, Northeast Ohio and Dept. of Veterans Affairs Hospitals | VA: LOW (500- procedures/yr): 70% of hospitals, MEDIUM (501–1000): 30%, HIGH (1000+): 0% (43 total hospitals); NY State: LOW (500-): 16%, MEDIUM (501–1000): 19%, HIGH (1000+): 66% (32 total hospitals); NE Ohio: LOW (500-): 50%, MEDIUM (501–1000): 20%, and HIGH (1000+): 30% (10 total hospitals) | Not Applicable
Nallamothu B et al. ^245^ | Solucient EXPLORE database | LOW (for 200 procedures/yr cutoff): 44.6% of hospitals/ 14.9% of patients; HIGH (200 cutoff): 55.4%/ 85.1% (13,644 total patients)
Administrative Databases CABG: National
Birkmeyer J et al. ^178^ | Medicare Claims Database | LOW (<314 procedures/year): 33.5% of patients; MEDIUM (314–628): 33.3%; HIGH (more than 628): 33.3% (220,592 total patients) | LOW (less than 100 procedures/yr): 56.2% of doctors; MEDIUM (101–162): 25.7%; HIGH (more than 162): 18.2% (4,790 total doctors)
Welke K et al. ^185^ | Medicare Provider and Analysis Review (MEDPAR) Part A data files | LOWEST (for 200 procedures/yr cutoff): 3–4 Low-Volume Hospitals (LVH per year), 29–30 High-Volume Hospitals (HVH) per year; LOW (300 cutoff): 5–7 LVH per year, 26–28 HVH per year; MEDIUM (400 cutoff): 10–14 LVH per year, 19–23 HVH per year; MEDIUM-HIGH (500 cutoff): 14–17 LVH per year, 16–19 HVH per year; HIGH (600 cutoff): 18–21 LVH per year, 12–15 HVH per year (57,150 patients) | For annual hospital volume of >600: LOW (125 cutoff): 38–41doctors/year, HIGH (>125): 48–62; For annual hospital volume of <600: LOW (125-) 57–79, HIGH (>125): 21–26 (192 total doctors)
Rathore S et al. ^246^ | National Inpatient Sample database | LOW (12–249 procedures/yr): 16% of patients; MEDIUM (250–499): 26%; HIGH (500+): 58% (393 total hospitals/228,738 total patients)
Birkmeyer J et al. ^262^ | HCUP Nationwide Inpatient Sample | LOW (<55 procedures/yr): 53.5% of patients; HIGH (55+ procedures/yr): 46.5% (307,030 total patients) | Not Applicable
Birkmeyer J et al. ^227^ | HCUP Nationwide Inpatient Sample | Not Available | Not Applicable
Epstein A et al. ^228^ | HCUP Nationwide Inpatient Sample | LOW (for 450 procedures/yr cutoff): 38.4% of patients; HIGH (450 cutoff): 61.6% (374,234 total patients) | Not Applicable
Administrative Databases CABG: Regional/State
Carey JS et al. ^212^ | Discharge abstracts from the California Office of Statewide Health Planning | LOW (for 300 procedures/yr cutoff): 78.5% of hospitals; HIGH (300 cutoff): 21.5% (121 total hospitals) | Not Applicable

PCI=percutaneous coronary intervention; CABG=coronary artery bypass grafting; Hosp=hospital; Dr=physician; HCUP=healthcare cost and utilization project

* When volume is distributed across two groups, they are referred to as LOW and HIGH. When volume is distributed across three groups, they are referred to as LOW, MEDIUM, and HIGH. When volume is distributed across four groups, they are referred to as LOW, MEDIUM-LOW, MEDIUM-HIGH, and HIGH. When volume is distributed across five groups, they are referred to as LOW, MEDIUM-LOW, MEDIUM, MEDIUM-HIGH, and HIGH. Volume cut-offs are shown in parentheses after each volume level. Total number of hospitals, doctors or patients is also given wherever available.

** Not Available signifies that the volume distribution information is not given. Not Applicable signifies that there was no analysis of either Hospital Volume or Doctor Volume.

Appendix Table 14. Ongoing randomized trials comparing PCI with CABG

Trial Name | PI | Planned Sample Size | PCI Method | CABG Method | Population | Clinical Trials ID | References Available
CARDIA | Kapur | 600 | DES | CABG | Diabetics | | Am Heart J 2005; 149: 13–19 (Protocol Published)
COMBAT | Park, Leon | 1776 | | | Left Main
FREEDOM | Fuster | 2400 | DES | CABG | Diabetics | NCT00086450
Leipzig | Schuler | 200 | DES | CABG | Left Main | NCT00176397
Leipzig | Schuler | 100 | DES | MIDCAB LIMA | LAD Disease | NCT00299429
LeMans | Buszman | 105 | DES 35% | CABG | Left Main | | TCT 2005 abstract, see http://www.theheart.org/article/581205.do#
SYNTAX | Serruys | 1800 | DES | CABG | 3-vessel, Left Main | NCT00114972

PCI=percutaneous coronary intervention; CABG=coronary artery bypass grafting; PI=primary investigator; DES=drug-eluting stents; MIDCABG=minimally-invasive coronary artery bypass grafting; LIMA=left internal mammary artery; LAD=left anterior descending