# List of Excluded Studies

## References

Acute myocardial infarction: pre-hospital and in-hospital management. The Task Force on the Management of Acute Myocardial Infarction of the European Society of Cardiology. Eur Heart J. 1996 Jan;17(1):43–63. Not RCT
Alderman EL, Botas J. Selection of revascularization for patients with stable angina pectoris. Coron Artery Dis. Dec. 1993;4(12):1061-7. Not RCT. [pmid: 8162236].
Alexopoulos DK. Strategies for the invasive treatment of multivessel coronary artery disease. HJC Hellenic Journal of Cardiology. Jan–Feb. 2005;46(1):16-20. Not RCT. [pmid: 15807390].
Angelini G. AMIST A multicenter trial of minimally invasive bypass grafting versus angioplasty +/- stenting for single vessel disease of the left anterior descending coronary vessel. Http://www.cardiosource.com. 1999. Other
Anonymous. Routine invasive strategy within 24 hours of thrombolysis versus ischemia-guided conservative approach for acute myocardial infarction with ST-segment elevation: a randomized controlled trial. Indian Heart J. 2004;56(4):358. Other
Arterial Revascularization Therapies Study (ARTS). Indian Heart J. 2001 Mar–Apr;53(2):239. Not RCT
Beatt KJ. RITA trial protocol. Br Heart J. 1990;64(1):105. Not RCT.
Berger PB, Sketch MH Jr, Califf RM. Choosing between percutaneous coronary intervention and coronary artery bypass grafting for patients with multivessel disease: what can we learn from the Arterial Revascularization Therapy Study (ARTS)?[comment]. Circulation. Mar 9. 2004;109(9):1079-81. Not RCT. [pmid: 15007018].
Bhatt DL, Topol EJ. Debate: PCI or CABG for multivessel disease viewpoint: No clear winner in an unfair fight. Current Controlled Trials in Cardiovascular Medicine. 2001;2(6):260-2. Not RCT. [pmid: 11806809].
Borkon AM, Muehlebach GF, House J, et al. A comparison of the recovery of health status after percutaneous coronary intervention and coronary artery bypass. Ann Thorac Surg. Nov. 2002;74(5):1526-30. discussion 30. Not RCT. [pmid: 12440603].
Botas J, Stadius ML, Bourassa MG, et al. Angiographic correlates of lesion relevance and suitability for percutaneous transluminal coronary angioplasty and coronary artery bypass grafting in the Bypass Angioplasty Revascularization Investigation study (BARI). Am J Cardiol. 1996;77(10):805-14. Not CER. [pmid: 8623731].
Bourassa MG, Brooks MM, Mark DB, et al. Quality of life after coronary revascularization in the United States and Canada. Am J Cardiol. 2000;85(5):548-53. Not CER. [pmid: 11078265].
Brennan FJ. A randomized trial of multivessel stent versus coronary bypass.[comment]. J Am Coll Cardiol. Jul. 2001;38(1):286-7. Not RCT. [pmid: 11451289].
Burek KA, Sutton-Tyrrell K, Brooks MM, et al. Prognostic importance of lower extremity arterial disease in patients undergoing coronary revascularization in the Bypass Angioplasty Revascularization Investigation (BARI). J Am Coll Cardiol. 1999;34(3):716-21. Not CER. [pmid: 10483952].
Channer KS, English KM. Long-term results of RITA-1.[comment]. Lancet. Jan 23. 1999;353(9149):321. Not RCT. [pmid: 9929042].
Cishek MB, Gershony G. Roles of percutaneous transluminal coronary angioplasty and bypass graft surgery for the treatment of coronary artery disease. Am Heart J. 1996;131(5):1012-7. Not RCT. [pmid: 8615289].
Cohen HA, Zenati M. Integrated coronary revascularization. J Invasive Cardiol. Mar. 1999;11(3):184-90. discussion 90–1. Not RCT. [pmid: 10745509].
Detre KM, Lombardero MS, Brooks MM, et al. The effect of previous coronary-artery bypass surgery on the prognosis of patients with diabetes who have acute myocardial infarction. Bypass Angioplasty Revascularization Investigation Investigators. N Engl J Med. Apr 6. 2000;342(14):989-97. Not CER. [pmid: 10749960].
Drzewiecki J, Cisowski M, Bochenek A, et al. Direct stenting of anterior interventricular branch MIDCAB. Kardiol Pol. 2001;55(Suppl I):I–14 ( O 25). Other
Dunlap J. What is the protective effect of previous coronary artery bypass graft compared with percutaneous transluminal coronary angioplasty in patients with diabetes who suffer an acute myocardial infarction?. J Fam Pract. Jul. 2000;49(7):599-600. Not RCT. [pmid: 10923566].
Elami A, Merin G, Van den Brand M, et al. Stented angioplasty or coronary artery bypass graft surgery for multivessel disease?. J Am Coll Cardiol. 2002;40(11):2063-4. Not RCT. [pmid: 12475473].
Farquhar D. Bypass surgery or stenting for multivessel coronary artery disease?. Can Med Assoc J. Jun 12. 2001;164(12):1742. Not RCT. [pmid: 11450219].
Filart RA, Ryan TJ. Comparison of coronary angioplasty with bypass surgery for multivessel disease. Coron Artery Dis. Dec. 1993;4(12):1039-47. Not RCT. [pmid: 8162234].
Frye RL, Sopko G, Detre KM. The BARI trial: baseline observations. The BARI Investigators. Trans Am Clin Climatol Assoc. 1992;104:26-30. Not RCT. [pmid: 1343445].
Galli M, Genovesi Ebert A. MISTRAL whispers: STEMI trials forecast storm, registries blow breeze. Ital Heart J. Feb. 2004;5(2):146-51. Not RCT. [pmid: 15086145].
Gavaliatsis IP, Sowton E. Angioplasty or bypass? The ongoing randomized trials on the occasion of publication of the RITA trial interim results. Hellenic Journal of Cardiology. 1993;34(4):340-4. Not RCT.
Goldsmith MF. Once again, CABG vs PTCA—trial results today. JAMA. Jan 26. 1994;271(4):257. Not RCT. [pmid: 8295274].
Gottlieb S. Bypass grafts protect diabetic patients better than angioplasty. West J Med. 2000;172(6):362. Not RCT. [pmid: 10854372].
Grines CL, O'Neill WW. Multivessel angioplasty versus bypass surgery. A case for PTCA. Eur Heart J. Jul. 1995;16(Suppl E):29-31. Not RCT. [pmid: 8542877].
Gunn J, Taggart DP. Revascularisation for acute coronary syndromes: PCI or CABG?. Heart. Sep. 2003;89(9):967-70. Not RCT. [pmid: 12922989].
Hamm CW, Reimers J, Ischinger T, et al. Comparison of PTCA with bypass operations in patients with coronary multi-vessel disease: Results of the G.A.B.I. study. Z Kardiol. 1994;83(1). Other
Hamm CW, Reimers J, Ischinger T, et al. Comparison of PTCA with bypass operations in patients with coronary multi-vessel disease: The acute results of the G.A.B.I. Study. Z Kardiol. 1993;82(1). Other
Hampton JR. Education from RITA. Randomized Intervention Treatment of Angina. Eur Heart J. Jul. 1995;16(7):878-81. Not RCT. [pmid: 7498199].
Hampton JR. Lessons from the RITA trial: CABG vs PTCA for angina. Primary Cardiology. 1993;19(10):50-2. Not RCT.
Hampton JR. Long-term results of RITA-1. Eur Heart J. Jun. 1999;20(12):849-50. Not RCT. [pmid: 10329085].
Hartz AJ, Kuhn EM, Doorey AJ, et al. Coronary angioplasty compared with bypass grafting. N Engl J Med. 1995;332(13):888-90. Not RCT. [pmid: 7870148].
Hassan SA, Hlatky MA, Boothroyd DB, et al. Outcomes of noncardiac surgery after coronary bypass surgery or coronary angioplasty in the Bypass Angioplasty Revascularization Investigation (BARI). Am J Med. Mar. 2001;110(4):260-6. Not CER. [pmid: 11239843].
Haude M, Hopp HW, Rupprecht HJ, et al. Immediate stent implantation versus conventional techniques for the treatment of abrupt vessel closure or symptomatic dissections after coronary balloon angioplasty. Am Heart J. 2000;140(5):820. Other.
Hillis LD, Rutherford JD. Coronary angioplasty compared with bypass grafting. N Engl J Med. 1994;331(16):1086-7. Not RCT. [pmid: 7726899].
Hlatky MA, Boothroyd DB, Brooks MM, et al. Clinical correlates of the initial and long-term cost of coronary bypass surgery and coronary angioplasty. Am Heart J. 1999;138(2 Pt 1):376-83. Not CER. [pmid: 10426855].
Hodakowski GT, Craver JM, Jones EL, et al. Clinical significance of perioperative Q-wave myocardial infarction: the Emory Angioplasty versus Surgery Trial. J Thorac Cardiovasc Surg. Dec. 1996;112(6):1447-53. discussion 53–4. Not CER. [pmid: 8975835].
Hoye A. The CAPTIM study.[comment]. Lancet. Feb 22. 2003;361(9358):700. author reply 1. Not RCT. [pmid: 12606194].
Ivens K, Heering P, Leschke M, et al. Percutaneous coronary angioplasty (PTCA) or coronary artery bypass grafting (CABG)—which is the appropriate therapy of coronary artery disease in uraemic patients?. Nephrol Dial Transplant. Oct. 1996;11(10):1949-51. Not RCT. [pmid: 8918703].
Jones RH, Kesler K, Phillips HR 3rd, et al. Long-term survival benefits of coronary artery bypass grafting and percutaneous transluminal angioplasty in patients with coronary artery disease. J Thorac Cardiovasc Surg. May. 1996;111(5):1013-25. Not RCT. [pmid: 8622299].
Kapur A, Bartolini D, Beatt KJ. Has anything changed in multivessel coronary artery revascularization in diabetes since BARI?. Ital Heart J. May. 2004;5(5):358-63. Not RCT. [pmid: 15185899].
Kappetein AP, Dawkins KD, Mohr FW, et al. Current percutaneous coronary intervention and coronary artery bypass grafting practices for three-vessel and left main coronary artery disease. Insights from the SYNTAX run-in phase. Eur J Cardiothorac Surg. Apr. 2006;29(4):486-91. Other. [pmid: 16497510].
Kapur A, Malik IS, Bagger JP, et al. The Coronary Artery Revascularisation in Diabetes (CARDia) trial: background, aims, and design. Am Heart J. Jan. 2005;149(1):13-9. Other. [pmid: 15660030].
Kelsey SF. Patients with diabetes did better with coronary bypass graft surgery than with percutaneous transluminal coronary angioplasty: was this BARI finding real?. Am Heart J. 1999;138(5 Pt 1):S387-93. Not RCT. [pmid: 10539802].
King SB. The impact of performing a clinical trial on patient outcomes: lessons from the Emory Angioplasty vs. Surgery Trial. Trans Am Clin Climatol Assoc. 1995;107:68-77. Not RCT. [pmid: 8725561].
King SP 3rd. Coronary angioplasty: long-term survival compared with coronary bypass surgery. Trans Assoc Life Insur Med Dir Am. 1989;72:88-94. Not RCT. [pmid: 2525832].
Kip KE, Bourassa MG, Jacobs AK, et al. Influence of pre-PTCA strategy and initial PTCA result in patients with multivessel disease: the Bypass Angioplasty Revascularization Investigation (BARI). Circulation. Aug 31. 1999;100(9):910-7. Not CER. [pmid: 10468520].
Klinke P, Sullivan J. Revascularization strategies in patients with stable angina pectoris. Can J Cardiol. Dec. 1997;13(Suppl D):23D-9D. Not RCT.
Legrand VM, Serruys PW, Unger F. Trial finds stenting for multivessel disease is less costly than bypass grafting, but more likely to require repeat revascularisation. Evidence-Based Cardiovascular. Medicine. 2004;8(3):237-8. Not RCT.
Lewsey JD, Murray GD, Leyland AH, et al. Comparing outcomes of percutaneous transluminal coronary angioplasty with coronary artery bypass grafting; can routine health service data complement and enhance randomized controlled trials?. Eur Heart J. Dec. 1999;20(23):1731-5. Not RCT. [pmid: 10562481].
Little T, Lindsay J Jr. Percutaneous transluminal coronary angioplasty and coronary artery bypass graft surgery in octogenarians: Indications and outcome. Heart Dis Stroke. 1994;3(5):261-5. Not RCT. [pmid: 7820342].
Lombardero MS. Seven-year outcome in the bypass angioplasty revascularization investigation (BARI), by treatment and presence of diabetes. Cardiovasc Rev Rep. 2002;23(1):14-8. Not RCT.
Mark DB, Lam LC, Lee KL, et al. Effects of coronary angioplasty, coronary bypass surgery, and medical therapy on employment in patients with coronary artery disease. A prospective comparison study. Ann Intern Med. Jan 15. 1994;120(2):111-7. Not RCT. [pmid: 8256969].
Mock MB, Reeder GS, Schaff HV, et al. Percutaneous transluminal coronary angioplasty versus coronary artery bypass. Isn't it time for a randomized trial?. N Engl J Med. Apr 4. 1985;312(14):916-9. Not RCT. [pmid: 3156275].
Morguet AJ, Figulla HR, Ruschewski W, et al. Comparison of PTCA and coronary bypass operation (CABG-Op) in triple vessel disease (3-VD). Z Kardiol. 1992;81(1). Other
Parisi AF, Burtt DM. Revascularization procedures in the treatment of single-vessel coronary disease. Coron Artery Dis. Dec. 1993;4(12):1053-60. Not RCT. [pmid: 7909263].
Patil CV, Nikolsky E, Boulos M, et al. Multivessel coronary artery disease: current revascularization strategies. Eur Heart J. Jul. 2001;22(14):1183-97. Not RCT. [pmid: 11440491].
Pretre R, Turina MI. Choice of revascularization strategy for patients with coronary artery disease. JAMA. Feb 28. 2001;285(8):992-4. Not RCT. [pmid: 11209153].
Rankin JS, Harrell FE Jr. Measuring the therapeutic efficacy of coronary revascularization: Implications for future management.[comment]. J Thorac Cardiovasc Surg. May. 2006;131(5):944-8. Not RCT. [pmid: 16678572].
Rihal CS, Yusuf S. Chronic coronary artery disease: drugs, angioplasty, or surgery?. BMJ. Feb 3. 1996;312(7026):265-6. Not RCT. [pmid: 8611770].
Rodriguez A, Bernardi V, Navia J. Erratum: Argentine randomized study: Coronary angioplasty with stenting versus coronary bypass surgery in patients with multiple-vessel disease (ERACII): 30-Day and one-year follow-up results (Journal of the American College of Cardiology (2000) 37 (51–58)). J Am Coll Cardiol. 2001;37(3):973. Not RCT.
Rodriguez Alemparte A, Rodriguez M, Baldi J, et al. Survival may be similar in people with multiple vessel disease and significant proximal LAD stenosis receiving stents versus coronary artery bypass grafts. Evidence-Based Cardiovascular Medicine. 2003;7(2):73-4. Not RCT.
Rodriguez A. Argentine randomized study: coronary angioplasty with stenting vs coronary artery bypass surgery in patients with multiple vessel disease (eraci II): 30-day and long-term follow-up results. Am Heart J. 2000;139(2 Pt 1):362-3. Not RCT.
Rotman B, Eber B, Dusleag J, et al. Coronary revascularization: influence on ventricular arrhythmias. Clin Cardiol. 1990;13(1):11-3. Not RCT. [pmid: 2297953].
Runyan S, Dobie S. CABG compared with PTCA in heart disease. J Fam Pract. Feb. 1998;46(2):112-3. Not RCT. [pmid: 9487310].
Ryan TJ. Present-day PTCR versus CABG: a randomized comparison with a different focus and a new result.[comment]. J Am Coll Cardiol. Jan. 2001;37(1):59-62. Not RCT. [pmid: 11153773].
Schaff HV, Rosen AD, Shemin RJ, et al. Clinical and operative characteristics of patients randomized to coronary artery bypass surgery in the Bypass Angioplasty Revascularization Investigation (BARI). Am J Cardiol. 1995;75(9):18C-26C. Not CER. [pmid: 7801857].
Schofield PM. Indications for percutaneous and surgical revascularisation: how far does the evidence base guide us?. Heart. May. 2003;89(5):565-70. Not RCT. [pmid: 12695476].
Schwartz L, Kip KE, Frye RL, et al. Coronary bypass graft patency in patients with diabetes in the Bypass Angioplasty Revascularization Investigation (BARI). Circulation. Nov 19. 2002;106(21):2652-8. Not CER. [pmid: 12438289].
Smith D. The CARDia trial protocol. Heart. Oct. 2003;89(10):1125-6. Not RCT. [pmid: 12975392].
Spodick DH. Percutaneous transluminal coronary angioplasty versus coronary artery bypass. N Engl J Med. Sep 26. 1985;313(13):824-5. Not RCT. [pmid: 3162100].
Starkey IR. The RITA trial.[comment]. Lancet. Apr 17. 1993;341(8851):1020. Not RCT. [pmid: 8096894].
Szygula-Jurkewicz B, Wilczek K, Gorzkowska A, et al. g. Pol Arch Med Wewn. 2005 Jan;113(1):56–62. Other
Szygula-Jurkiewicz B, Zembala M, Wilczek K, et al. Health related quality of life after percutaneous coronary intervention versus coronary artery bypass graft surgery in patients with acute coronary syndromes without ST-segment elevation. 12-Month follow up. Eur J Cardiothorac Surg. 2005;27(5):882-6. Not RCT. [pmid: 15848330].
Taggart DP. The RITA trial.[comment]. Lancet. Apr 17. 1993;341(8851):1020. Not RCT. [pmid: 8096895].
Takagi H, Kato T, Matsuno Y, et al. Minimally invasive direct coronary artery bypass versus stenting. Eur J Cardiothorac Surg. 2006;29(4):632. Not RCT. [pmid: 16473513].
Tu JV, Naylor CD, Pashos CL, et al. Coronary angiography and revascularization after acute myocardial infarction: which rate is right?. Eur Heart J. Apr. 1998;19(4):529-30. Not RCT. [pmid: 9597394].
Vander Salm TJ, Kip KE, Jones RH, et al. What constitutes optimal surgical revascularization? Answers from the Bypass Angioplasty Revascularization Investigation (BARI). J Am Coll Cardiol. Feb 20. 2002;39(4):565-72. Not CER. [pmid: 11849852].
Vogt AR, Funk M, Remetz M. Comparison of symptoms, functional ability, and health perception of elderly patients with coronary artery disease managed with three different treatment modalities. Cardiovasc Nurs. Sep–Oct. 1994;30(5):33-8. Not RCT. [pmid: 7882409].
Wahrborg P. Percutaneous transluminal coronary angioplasty or coronary artery bypass grafting for coronary artery disease?. Scand Cardiovasc J. 1997;31(4):201-11. Not RCT. [pmid: 9291538].
Whitlow PL, Dimas AP, Bashore TM, et al. Relationship of extent of revascularization with angina at one year in the Bypass Angioplasty Revascularization Investigation (BARI). J Am Coll Cardiol. 1999;34(6):1750-9. Other. [pmid: 10577566].
Whitlow PL. The Bypass Angioplasty Revascularization Investigation (BARI) trial: implications for clinical practice. Cleve Clin J Med. Jan. 1997;64(1):17-20. Not RCT. [pmid: 9014379].
Willerson JT. First-year results of CABRI (Coronary Angioplasty versus Bypass Revascularization Investigation). Circulation. 1996;93(5):847. Not RCT. [pmid: 8598072].
Williams DO, Baim DS, Bates E, et al. Coronary anatomic and procedural characteristics of patients randomized to coronary angioplasty in the Bypass Angioplasty Revascularization Investigation (BARI). Am J Cardiol. Mar 23. 1995;75(9):27C-33C. Not CER.
Wilson JM. Stents or surgery: The case for stents. Tex Heart Inst J. 2005;32(3):331-8. Not RCT. [pmid: 16392213].
Yokoyama Y, Chaitman BR, Hardison RM, et al. Association between new electrocardiographic abnormalities after coronary revascularization and five-year cardiac mortality in BARI randomized and registry patients. Am J Cardiol. Oct 15. 2000;86(8):819-24. Not CER. [pmid: 11024394].
Zamorski M. Bypass surgery vs angioplasty in multivessel CAD. J Fam Pract. 1997;44(6):527-8. Not RCT. [pmid: 9191616].