# Search Strategies

DIALOG MEDLINE^®^/EMBASE Search. Run on August 3, 2006

TOTAL = 3080

MEDLINE^®^ = 1576

EMBASE = 1504 unique records

EMBASE terminology is in bold

s1

dt=randomized controlled trial OR randomized controlled trial/de OR randomized controlled trials/de OR random allocation/de

s2

(singl? or double? or trebl? or tripl?)(25n)(blind? or mask)/ti,ab

s3

single(w)blind(w)method/de or double(w)blind(w) method/de

s4

dt=clinical trial OR clinical trials! OR clin?(25n)trial?/ti,ab OR placebos/de OR placebo?/ti,ab OR random?/ti,ab OR research design/de OR clinical trial!

s5

s1 or s2 or s3 or s4

s6

(LT=animal OR animals/df) NOT (humans/df OR human/df)

S7

s5 NOT s6

s8

(angioplasty, balloon/de or balloon(w)angioplast?) or ((balloon(w)dilation OR balloon(w)dilitation) and coronary/ti,ab) OR atherectomy, coronary/de OR ((atherectom? OR atherectomy!) AND coronary)

S9

angioplasty, transluminal, percutaneous coronary/de OR (percutaneous AND coronary AND transluminal AND angioplast?)/ti,ab OR ptca/ti,ab

s10

transluminal coronary angioplasty/de OR pci/ti,ab or percutaneous(w)coronary(w)intervention?/ti,ab

s11

percutaneous coronary intervention! OR stents! OR stent! or stent/ti,ab OR stenting/ti,ab or stents/ti,ab

s12

s8 OR s9 OR s10 OR s11

s13

coronary artery bypass! OR coronary(4w)bypass OR cabg OR coronary artery bypass surgery/de OR coronary artery bypass graft/de

s14

s7 AND s12 AND s13

OVID In-Process & Other Non-Indexed Citations and Ovid MEDLINE^®^ Search. Formulated July 2006.

1 randomized controlled trial.pt.
2 controlled clinical trial.pt.
3 randomized controlled trials/
4 random allocation.de.
5 double blind method.de.
6 single blind method.de.
7 or/1–6
8 exp animal/ not human/
9 7 not 8
10 clinical trial.pt.
11 exp clinical trials/
12 (clin$ adj25 trial$).ti,ab.
13 placebos.de.
14 placebo$.ti,ab.
15 random$.ti,ab. OR ((singl$ or double$ or trebl$ or tripl$) adj25 (blind$ or mask$)).ti,ab.
16 research design.de.
17 or/10–16
18 17 not 8
19 18 not 9
20 exp coronary artery bypass/
21 (coronary adj4 bypass$).tw.
22 cabg.tw.
23 or/20–22
24 atherectomy, coronary.de. or (atherectom$ and coronary).mp.
25 (angioplasty, balloon.de. or “balloon angioplast$”.mp. or “balloon dilation”.mp.) and coronary.mp.
26 Angioplasty, Transluminal, Percutaneous Coronary.de. or (percutaneous and coronary and transluminal and angioplast$).ab,ti. or ptca.mp.
27 (pci or “percutaneous coronary intervention$”).mp.
28 stent.de. or stents.ab,ti. or stenting.ab,ti. or stent.ab,ti.
29 or/24–28
30 23 and 29
31 9 or 19
32 30 and 31

REVISION: September 1, 2006 — Added “internal mammary” to the CABG search (searches 20 – 22)

37 23 or “internal mammary”.mp.
38 37 and 29
39 9 or 19
40 38 and 39

Cochrane Central Register of Controlled Trials Search

1 exp coronary artery bypass/
2 (coronary adj4 bypass$).mp.
3 cabg.mp.
4 or/1–3
5 atherectomy, coronary.de. or (atherectom$ and coronary).mp.
6 (angioplasty, balloon.de. or “balloon angioplast$”.mp. or “balloon dilation”.mp.) and coronary.mp.
7 Angioplasty, Transluminal, Percutaneous Coronary.de. or (percutaneous and coronary and transluminal and angioplast$).ab,ti. or ptca.mp.
8 (pci or “percutaneous coronary intervention$”).mp.
9 stent.de. or stents.mp. or stenting.mp. or stent.mp.
10 or/5–9
11 4 and 10

Methodology for Registry Searches:

DIALOG MEDLINE^®^ Search. Run September 29 to October 6, 2006.

MEDLINE^®^=

OVID In-Process & Other Non-Indexed Citations and Ovid MEDLINE^®^ Search 9-29-06 to 10-6-06. Search One and Search Three were the main searches, and Search Two was to verify Search One's results. Likewise, Searches Four and Five were to verify and catch anything that Search Three missed. All search results were downloaded into an EndNote 9 Library (N= 8119), which was deduplicated (N=4813). All articles in languages other than English were removed (N=4163). Then, a thorough search of abstracts and titles were reviewed to identify possible pertinent articles that met inclusion criteria for applicable registers (N=106), a list of which were sent to Stanford, who selected the final articles for inclusion.

I. Search One

1 *Coronary Disease/ or *Coronary Artery Bypass/ or *Surgical Procedures, Minimally Invasive/ or CABG.mp. or *Coronary Arteriosclerosis/
2 stent$.mp. or *Stents/
3 (“registry” or “registries”).mp. [mp=ti, ot, ab, name of substance word, subject heading word]
4 1 or 2
5 3 and 4
6 limit 5 to english language

II. Search Two

1 coronary bypass.mp. [mp=ti, ot, ab, nm, hw]
2 (coronary adj4 bypas$).mp.
3 cabg.mp.
4 1 or 2 or 3
5 (atherectom$ and coronary).mp. [mp=ti, ot, ab, nm, hw]
6 (angioplast$ or balloon or dilation).mp.
7 coronary.mp.
8 6 and 7
9 (pci or “percutaneous coronary”).mp.
10 ptca.mp.
11 (stent or stents or stenting).mp. [mp=ti, ot, ab, nm, hw]
12 regist$.mp. [mp=ti, ot, ab, nm, hw]
13 4 or 5
14 8 or 9 or 10 or 12
16 12 and 13
17 12 and 14
18 16 and 17

III. Search Three

1 registr$.mp. [mp=ti, ot, ab, nm, hw]
2 Cabg.mp.
3 (bypass adj5 registr$).mp.
4 stent$.mp.
5 coronary.mp.
6 percutaneous.mp.
7 (percutaneous adj5 regist$).mp.
8 PTCA.mp.
9 PCI.mp.
10 (PTCA adj4 regist$).mp.
11 2 or 3 or 5
12 4 or 5 or 6 or 7 or 8 or 9 or 10
13 1 and 11
14 1 and 12
15 13 and 14
16 (duke adj5 registr$).mp. [mp=ti, ot, ab, nm, hw]
17 (emory adj5 regist$).mp.
18 (scott$ adj5 regist$).mp.
19 (northern adj3 “new england”).mp.
20 (cleveland adj5 regist$).mp.
21 (new york adj4 regist$).mp.
22 BARI.mp.
23 (east adj2 regist$).mp.
24 (awesome adj4 regist$).mp.
25 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24
26 15 or 25

IV. Search Four

1 (stent adj5 registr$).mp. [mp=ti, ot, ab, nm, hw]
2 (percutan$ adj5 regist$).mp.
3 (PTCA adj5 regist$).mp.
4 (PCI adj5 regist$).mp.
5 1 or 2 or 3 or 4
6 (CABG adj4 regist$).mp.
7 (bypass adj5 regist$).mp.
8 (surgery adj2 regist$).mp.
9 6 or 7 or 8
10 (emory adj4 registy).mp.
11 (york adj3 registry).mp.
12 (duke adj3 registy).mp.]
13 (awesome adj3 regist$).mp.
14 (england adj4 regist$).mp.
15 (cleveland adj4 regist$).mp.
16 10 or 11 or 12 or 13 or 14 or 15
17 5 or 9 or 16

V. Search Five

1 “duke registry”.mp. [mp=ti, ot, ab, nm, hw]
2 “new york registry”.mp.
3 “northern new england registry”.mp.
4 BARI.mp.
5 “Cleveland clinic registry”.mp.
6 “emory registry”.mp.
7 duke registry.mp.
8 cleveland clinic.mp.
9 cleveland clinic registry.mp.
10 stent regist$.ab,sh,ot,hw,tw,ti,kw,kf.
11 “coronary bypass regist$”.ab,sh,ot,hw,ti,kw,kf.
12 coronary bypass regist$.ab,sh,ot,hw,ti,kw,kf.
13 coronary regist$.ab,sh,ot,hw,ti,kw,kf.
14 CABG regist$.ab,sh,ot,hw,ti,kw,kf.
15 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10
16 11 or 12 or 13 or 14
17 15 or 16
18 limit 17 to english language
19 registry.mp. [mp=ti, ot, ab, nm, hw]
20 limit 19 to english language
21 limit 20 to humans
22 stent$.mp. [mp=ti, ot, ab, nm, hw]
23 21 and 22
24 18 or 23
25 limit 24 to humans