# References

1 DeFrances CJ, Podgornik MN. 2004 National Hospital Discharge Survey. Adv Data. May. 2006;4(371):1-19. [pmid: 16703980].
2 Kolessov VI. Mammary artery-coronary artery anastomosis as method of treatment for angina pectoris. J Thorac Cardiovasc Surg. Oct. 1967;54(4):535-44. [pmid: 6051440].
3 Favaloro RG. Landmarks in the development of coronary artery bypass surgery. Circulation. Aug 4. 1998;98(5):466-78. [pmid: 9714098].
4 Loop FD, Lytle BW, Cosgrove DM, et al. Influence of the internal-mammary-artery graft on 10-year survival and other cardiac events. N Engl J Med. Jan 2. 1986;314(1):1-6. [pmid: 3484393].
5 Martens TP, Argenziano M, Oz MC. New technology for surgical coronary revascularization. Circulation. Aug 8. 2006;114(6):606-14. [pmid: 16894050].
6 Gruntzig AR, Senning A, Siegenthaler WE. Nonoperative dilatation of coronary-artery stenosis: percutaneous transluminal coronary angioplasty. N Engl J Med. Jul 12. 1979;301(2):61-8. [pmid: 449946].
7 King SB 3rd. Angioplasty from bench to bedside to bench. Circulation. May 1. 1996;93(9):1621-9. [pmid: 8653865].
8 Brophy JM, Belisle P, Joseph L. Evidence for use of coronary stents. A hierarchical bayesian meta-analysis. Ann Intern Med. May 20. 2003;138(10):777-86. [pmid: 12755549].
9 Babapulle MN, Joseph L, Belisle P, et al. A hierarchical Bayesian meta-analysis of randomised clinical trials of drug-eluting stents. Lancet. Aug 14–20. 2004;364(9434):583-91. [pmid: 15313358].
10 McFadden EP, Stabile E, Regar E, et al. Late thrombosis in drug-eluting coronary stents after discontinuation of antiplatelet therapy. Lancet. Oct 23–29. 2004;364(9444):1519-21. [pmid: 15500897].
11 Katritsis DG, Ioannidis JP. Percutaneous coronary intervention versus conservative therapy in nonacute coronary artery disease: a meta-analysis. Circulation. Jun 7. 2005;111(22):2906-12. [pmid: 15927966].
12 Smith SC Jr, Feldman TE, Hirshfeld JW Jr, et al. ACC/AHA/SCAI 2005 guideline update for percutaneous coronary intervention: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines (ACC/AHA/SCAI Writing Committee to Update 2001 Guidelines for Percutaneous Coronary Intervention). Circulation. Feb 21. 2006;113(7):e166-286. [pmid: 16490830].
13 Yusuf S, Zucker D, Peduzzi P, et al. Effect of coronary artery bypass graft surgery on survival: overview of 10-year results from randomised trials by the Coronary Artery Bypass Graft Surgery Trialists Collaboration. Lancet. Aug 27. 1994;344(8922):563-70. [pmid: 7914958].
14 Eagle KA, Guyton RA, Davidoff R, et al. ACC/AHA 2004 guideline update for coronary artery bypass graft surgery: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines (Committee to Update the 1999 Guidelines for Coronary Artery Bypass Graft Surgery). Circulation. Oct 5. 2004;110(14):e340-437. [pmid: 15466654].
15 Sim I, Gupta M, McDonald K, et al. A meta-analysis of randomized trials comparing coronary artery bypass grafting with percutaneous transluminal coronary angioplasty in multivessel coronary artery disease. Am J Cardiol. Nov 15. 1995;76(14):1025-9. [pmid: 7484855].
16 Pocock SJ, Henderson RA, Rickards AF, et al. Meta-analysis of randomised trials comparing coronary angioplasty with bypass surgery. Lancet. Nov 4. 1995;346(8984):1184-9. [pmid: 7475657].
17 Mercado N, Wijns W, Serruys PW, et al. One-year outcomes of coronary artery bypass graft surgery versus percutaneous coronary intervention with multiple stenting for multisystem disease: a meta-analysis of individual patient data from randomized clinical trials. J Thorac Cardiovasc Surg. Aug. 2005;130(2):512-9. [pmid: 16077421].
18 Hoffman SN, TenBrook JA, Wolf MP, et al. A meta-analysis of randomized controlled trials comparing coronary artery bypass graft with percutaneous transluminal coronary angioplasty: one- to eight-year outcomes. J Am Coll Cardiol. Apr 16. 2003;41(8):1293-304. [pmid: 12706924].
19 DeMets DL, Califf RM. Lessons learned from recent cardiovascular clinical trials: Part I. Circulation. Aug 6. 2002;106(6):746-51. [pmid: 12163438].
20 Fibrinolytic Therapy Trialists' (FTT) Collaborative Group. Indications for fibrinolytic therapy in suspected acute myocardial infarction: collaborative overview of early mortality and major morbidity results from all randomised trials of more than 1000 patients. Lancet. Feb 5. 1994;343(8893):311-22. [pmid: 7905143].
21 Epstein AJ, Rathore SS, Volpp KG, et al. Hospital percutaneous coronary intervention volume and patient mortality, 1998 to 2000: does the evidence support current procedure volume minimums?. J Am Coll Cardiol. May 19. 2004;43(10):1755-62. [pmid: 15145095].
22 Kalant N, Shrier I. Volume and outcome of coronary artery bypass graft surgery: are more and less the same?. Can J Cardiol. Jan. 2004;20(1):81-6. [pmid: 14968146].
23 Sowden AJ, Deeks JJ, Sheldon TA. Volume and outcome in coronary artery bypass graft surgery: true association or artefact?. BMJ. Jul 15. 1995;311(6998):151-5. [pmid: 7613425].
24 Davies S, Geppert J, McClellan M, et al. Refinement of the HCUP Quality Indicators. Agency for Health Care Research and Quality EPCTM Evidence Report/Technology Assessment. Review #4. Internet Publication: December 2001. Agency for Healthcare Research and Quality, Rockville, MD. Available from: http://www.ahrq.gov/data/hcup/qirefine.htm.
25 Altman DG, Schulz KF, Moher D, et al. The revised CONSORT statement for reporting randomized trials: explanation and elaboration. Ann Intern Med. Apr 17. 2001;134(8):663-94. [pmid: 11304107].
26 Moher D, Schulz KF, Altman D. The CONSORT statement: revised recommendations for improving the quality of reports of parallel-group randomized trials. JAMA. Apr 18. 2001;285(15):1987-91. [pmid: 11308435].
27 Balk E, Raman G, Chung M, et al. Comparative Effectiveness of Management Strategies for Renal Artery Stenosis. Evidence Report/Technology Assessment No. 5. (Prepared by Tufts-New England Medical Center Evidence-Based Practice Center under Contract No.290-02-0022). Rockville, MD: Agency for Healthcare Research and Quality. Available from: www.effectivehealthcare.ahrq.gov/reports/final.cfm
28 Ip S, Bonis P, Tatsioni A, et al. Comparative Effectiveness of Management Strategies for Gastroesophageal Reflux Disease. Evidence Report/Technology Assessment No. 1. (Prepared by Tufts-New England Medical Center Evidence-based Practice Center under Contract No. 290-02-0022.) Rockville, MD: Agency for Healthcare Research and Quality. Available from: www.effectivehealthcare.ahrq.gov/reports/final.cfm. December 2005.
29 Guyatt G, Gutterman D, Baumann MH, et al. Grading strength of recommendations and quality of evidence in clinical guidelines: report from an american college of chest physicians task force. Chest. Jan. 2006;129(1):174-81. [pmid: 16424429].
30 Sutton A, Abrams K, Jones D, et al. Method for Meta-Analysis in Medical Research. New York: Wiley; 2000.
31 Cooper H, Hedges L. The Handbook of Research Synthesis. New York: Russell Sage Foundation; 1994.
32 Engels EA, Schmid CH, Terrin N, et al. Heterogeneity and statistical significance in meta-analysis: an empirical study of 125 meta-analyses. Stat Med. Jul 15. 2000;19(13):1707-28. [pmid: 10861773].
33 Review Manager (RevMan). Version 4.2 for Windows ed. Copenhagen: The Nordic Cochrane Center, The Cochrane Collaboration; 2003.
34 Hong SJ, Lim DS, Seo HS, et al. Percutaneous coronary intervention with drug-eluting stent implantation vs. minimally invasive direct coronary artery bypass (MIDCAB) in patients with left anterior descending coronary artery stenosis. Catheter Cardiovasc Interv. Jan. 2005;64(1):75-81. [pmid: 15619278].
35 Kim JW, Lim DS, Sun K, et al. Stenting or MIDCAB using ministernotomy for revascularization of proximal left anterior descending artery?. Int J Cardiol. Mar 30. 2005;99(3):437-41. [pmid: 15771925].
36 Reeves BC, Angelini GD, Bryan AJ, et al. A multi-centre randomised controlled trial of minimally invasive direct coronary bypass grafting versus percutaneous transluminal coronary angioplasty with stenting for proximal stenosis of the left anterior descending coronary artery. Health Technol Assess. Apr. 2004;8(16):1-43. [pmid: 15080865].
37 Serruys PW, Unger F, Sousa JE, et al. Comparison of coronary-artery bypass surgery and stenting for the treatment of multivessel disease. N Engl J Med. Apr 12. 2001;344(15):1117-24. [pmid: 11297702].
38 Abizaid A, Costa MA, Centemero M, et al. Clinical and economic impact of diabetes mellitus on percutaneous and surgical treatment of multivessel coronary disease patients: insights from the Arterial Revascularization Therapy Study (ARTS) trial. Circulation. Jul 31. 2001;104(5):533-8. [pmid: 11479249].
39 Aoki J, Ong ATL, Arampatzis CA, et al. Comparison of three-year outcomes after coronary stenting versus coronary artery bypass grafting in patients with multivessel coronary disease, including involvement of the left anterior descending coronary artery proximally (a subanalysis of the arterial revascularization therapies study trial). Am J Cardiol. 2004;94(5):627-31. [pmid: 15342295].
40 Aoki J, Ong ATL, Hoye A, et al. Five year clinical effect of coronary stenting and coronary artery bypass grafting in renal insufficient patients with multivessel coronary artery disease: insights from ARTS trial. Eur Heart J. Aug. 2005;26(15):1488-93. [pmid: 15860519].
41 de Feyter PJ, Serruys PW, Unger F, et al. Bypass surgery versus stenting for the treatment of multivessel disease in patients with unstable angina compared with stable angina. Circulation. May 21. 2002;105(20):2367-72. [pmid: 12021222].
42 Gruberg L, Mercado N, Milo S, et al. Impact of body mass index on the outcome of patients with multivessel disease randomized to either coronary artery bypass grafting or stenting in the ARTS trial: The obesity paradox II?. Am J Cardiol. Feb 15. 2005;95(4):439-44. [pmid: 15695125].
43 Ix JH, Mercado N, Shlipak MG, et al. Association of chronic kidney disease with clinical outcomes after coronary revascularization: the Arterial Revascularization Therapies Study (ARTS). Am Heart J. 2005;149(3):512-9. [pmid: 15864241].
44 Legrand VMG, Serruys PW, Unger F, et al. Three-year outcome after coronary stenting versus bypass surgery for the treatment of multivessel disease. Circulation. Mar 9. 2004;109(9):1114-20. [pmid: 14993134].
45 Serruys PW, Ong ATL, van Herwerden LA, et al. Five-year outcomes after coronary stenting versus bypass surgery for the treatment of multivessel disease: the final analysis of the Arterial Revascularization Therapies Study (ARTS) randomized trial. J Am Coll Cardiol. Aug 16. 2005;46(4):575-81. [pmid: 16098418].
46 Serruys PW, Unger F, van Hout BA, et al. The ARTS study (Arterial Revascularization Therapies Study). Semin Interv Cardiol. 1999;4(4):209-19. [pmid: 10738354].
47 Serruys PW, Unger F, Van Hout BA, et al. The ARTS (Arterial Revascularization Therapies Study): Background, goals and methods. Int J Cardiovasc Intervent. 1999;2(1):41-50. [pmid: 12623386].
48 Unger F, Serruys PW, Yacoub MH, et al. Revascularization in multivessel disease: comparison between two-year outcomes of coronary bypass surgery and stenting. J Thorac Cardiovasc Surg. 2003;125(4):809-20. [pmid: 12698143].
49 van den Brand MJBM, Rensing BJWM, Morel MaM, et al. The effect of completeness of revascularization on event-free survival at one year in the ARTS trial. J Am Coll Cardiol. Feb 20. 2002;39(4):559-64. [pmid: 11849851].
50 Morrison DA, Sethi G, Sacks J, et al. Percutaneous coronary intervention versus coronary artery bypass graft surgery for patients with medically refractory myocardial ischemia and risk factors for adverse outcomes with bypass: a multicenter, randomized trial. Investigators of the Department of Veterans Affairs Cooperative Study #385, the Angina With Extremely Serious Operative Mortality Evaluation (AWESOME). J Am Coll Cardiol. Jul. 2001;38(1):143-9. [pmid: 11451264].
51 Morrison DA, Sethi G, Sacks J, et al. A multicenter, randomized trial of percutaneous coronary intervention versus bypass surgery in high-risk unstable angina patients. The AWESOME (Veterans Affairs Cooperative Study #385, angina with extremely serious operative mortality evaluation) investigators from the Cooperative Studies Program of the Department of Veterans Affairs. Control Clin Trials. 1999;20(6):601-19. [pmid: 10588300].
52 Morrison DA, Sethi G, Sacks J, et al. Percutaneous coronary intervention versus repeat bypass surgery for patients with medically refractory myocardial ischemia: AWESOME randomized trial and registry experience with post-CABG patients. J Am Coll Cardiol. Dec 4. 2002;40(11):1951-4. [pmid: 12475454].
53 Ramanathan KB, Weiman DS, Sacks J, et al. Percutaneous intervention versus coronary bypass surgery for patients older than 70 years of age with high-risk unstable angina. Ann Thorac Surg. Oct. 2005;80(4):1340-6. [pmid: 16181866].
54 Rumsfeld JS, Magid DJ, Plomondon ME, et al. Health-related quality of life after percutaneous coronary intervention versus coronary bypass surgery in high-risk patients with medically refractory ischemia. J Am Coll Cardiol. May 21. 2003;41(10):1732-8. [pmid: 12767656].
55 Sedlis SP, Morrison DA, Lorin JD, et al. Percutaneous coronary intervention versus coronary bypass graft surgery for diabetic patients with unstable angina and risk factors for adverse outcomes with bypass: outcome of diabetic patients in the AWESOME randomized trial and registry. J Am Coll Cardiol. Nov 6. 2002;40(9):1555-66. [pmid: 12427406].
56 Sedlis SP, Ramanathan KB, Morrison DA, et al. Outcome of percutaneous coronary intervention versus coronary bypass grafting for patients with low left ventricular ejection fractions, unstable angina pectoris, and risk factors for adverse outcomes with bypass (the AWESOME Randomized Trial and Registry). Am J Cardiol. Jul 1. 2004;94(1):118-20. [pmid: 15219521].
57 Stroupe KT, Morrison DA, Hlatky MA, et al. Cost-Effectiveness of Coronary Artery Bypass Grafts Versus Percutaneous Coronary Intervention for Revascularization of High-Risk Patients. Circulation. 2006 Sep 11.
58 The Bypass Angioplasty Revascularization Investigation (BARI) Investigators. Comparison of coronary bypass surgery with angioplasty in patients with multivessel disease.[erratum appears in N Engl J Med 1997 Jan 9;336(2):147]. N Engl J Med. Jul 25. 1996;335(4):217-25. [pmid: 8657237].
59 Protocol for the Bypass Angioplasty Revascularization Investigation. Suppl Circulation. 1991 December 1991;86(6):V1–27.
60 Influence of diabetes on 5-year mortality and morbidity in a randomized trial comparing CABG and PTCA in patients with multivessel disease: the Bypass Angioplasty Revascularization Investigation (BARI). Circulation. 1997 Sep 16;96(6):1761–9.
61 Seven-year outcome in the Bypass Angioplasty Revascularization Investigation (BARI) by treatment and diabetic status. J Am Coll Cardiol. 2000 Apr;35(5):1122–9.
62 Alderman EL, Kip KE, Whitlow PL, et al. Native coronary disease progression exceeds failed revascularization as cause of angina after five years in the Bypass Angioplasty Revascularization Investigation (BARI). J Am Coll Cardiol. Aug 18. 2004;44(4):766-74. [pmid: 15312856].
63 Berger PB, Velianou JL, Aslanidou Vlachos H, et al. Survival following coronary angioplasty versus coronary artery bypass surgery in anatomic subsets in which coronary artery bypass surgery improves survival compared with medical therapy. Results from the Bypass Angioplasty Revascularization Investigation (BARI). J Am Coll Cardiol. Nov 1. 2001;38(5):1440-9. [pmid: 11691521].
64 Bittner V, Hardison R, Kelsey SF, et al. Non-high-density lipoprotein cholesterol levels predict five-year outcome in the Bypass Angioplasty Revascularization Investigation (BARI). Circulation. Nov 12. 2002;106(20):2537-42. [pmid: 12427648].
65 Bourassa MG, Kip KE, Jacobs AK, et al. Is a strategy of intended incomplete percutaneous transluminal coronary angioplasty revascularization acceptable in nondiabetic patients who are candidates for coronary artery bypass graft surgery? The Bypass Angioplasty Revascularization Investigation (BARI). J Am Coll Cardiol. 1999;33(6):1627-36. [pmid: 10334434].
66 Bourassa MG, Roubin GS, Detre KM, et al. Bypass Angioplasty Revascularization Investigation: patient screening, selection, and recruitment. Am J Cardiol. 1995;75(9):3C-8C.
67 Brooks MM, Detre KM. The design, patient population and outcomes from the Bypass Angioplasty Revascularization Investigation (BARI) randomized trial and registries. Semin Interv Cardiol. 1999;4(4):191-9. [pmid: 10738352].
68 Brooks MM, Jones RH, Bach RG, et al. Predictors of mortality and mortality from cardiac causes in the bypass angioplasty revascularization investigation (BARI) randomized trial and registry. For the BARI Investigators. Circulation. 2000;101(23):2682-9. [pmid: 10851204].
69 Chaitman BR, Rosen AD, Williams DO, et al. Myocardial infarction and cardiac mortality in the Bypass Angioplasty Revascularization Investigation (BARI) randomized trial. Circulation. Oct 7. 1997;96(7):2162-70. [pmid: 9337185].
70 Detre KM, Guo P, Holubkov R, et al. Coronary revascularization in diabetic patients: a comparison of the randomized and observational components of the Aypass Angioplasty Revascularization Investigation (BARI). Circulation. 1999;99(5):633-40. [pmid: 9950660].
71 Gibbons RJ, Miller DD, Liu P, et al. Similarity of ventricular function in patients alive 5 years after randomization to surgery or angioplasty in the BARI trial. Circulation. 2001;103(8):1076-82. [pmid: 11222469].
72 Gurm HS, Whitlow PL, Kip KE, et al. The impact of body mass index on short- and long-term outcomes inpatients undergoing coronary revascularization. Insights from the bypass angioplasty revascularization investigation (BARI). J Am Coll Cardiol. Mar 6. 2002;39(5):834-40. [pmid: 11869849].
73 Hlatky MA, Bacon C, Boothroyd D, et al. Cognitive function 5 years after randomization to coronary angioplasty or coronary artery bypass graft surgery. Circulation. 1997;96(9 Suppl):II-11–4; discussion II-5.
74 Hlatky MA, Boothroyd D, Horine S, et al. Employment after coronary angioplasty or coronary bypass surgery in patients employed at the time of revascularization. Ann Intern Med. 1998;129(7):543-7. [pmid: 9758574].
75 Hlatky MA, Boothroyd DB, Melsop KA, et al. Medical costs and quality of life 10 to 12 years after randomization to angioplasty or bypass surgery for multivessel coronary artery disease. Circulation. Oct 5. 2004;110(14):1960-6. [pmid: 15451795].
76 Hlatky MA, Charles ED, Nobrega F, et al. Initial functional and economic status of patients with multivessel coronary artery disease randomized in the Bypass Angioplasty Revascularization Investigation (BARI). Am J Cardiol. Mar 23. 1995;75(9):34C-41C. [pmid: 7801861].
77 Hlatky MA, Rogers WJ, Johnstone I, et al. Medical care costs and quality of life after randomization to coronary angioplasty or coronary bypass surgery. Bypass Angioplasty Revascularization Investigation (BARI) Investigators. N Engl J Med. Jan 9. 1997;336(2):92-9. [pmid: 8988886].
78 Jacobs AK, Kelsey SF, Brooks MM, et al. Better outcome for women compared with men undergoing coronary revascularization: a report from the bypass angioplasty revascularization investigation (BARI). Circulation. Sep 29. 1998;98(13):1279-85. [pmid: 9751675].
79 Kip KE, Alderman EL, Bourassa MG, et al. Differential influence of diabetes mellitus on increased jeopardized myocardium after initial angioplasty or bypass surgery: bypass angioplasty revascularization investigation. Circulation. 2002;105(16):1914-20. [pmid: 11997277].
80 Mullany CJ, Mock MB, Brooks MM, et al. Effect of age in the Bypass Angioplasty Revascularization Investigation (BARI) randomized trial. Ann Thorac Surg. 1999;67(2):396-403. [pmid: 10197660].
81 Rihal CS, Sutton-Tyrrell K, Guo P, et al. Increased incidence of periprocedural complications among patients with peripheral vascular disease undergoing myocardial revascularization in the bypass angioplasty revascularization investigation. Circulation. 1999;100(2):171-7. [pmid: 10402447].
82 Rogers WJ, Alderman EL, Chaitman BR, et al. Bypass Angioplasty Revascularization Investigation (BARI): baseline clinical and angiographic data. Am J Cardiol. Mar 23. 1995;75(9):9C-17C.
83 Sutton-Tyrrell K, Rihal C, Sellers MA, et al. Long-term prognostic value of clinically evident noncoronary vascular disease in patients undergoing coronary revascularization in the Bypass Angioplasty Revascularization Investigation (BARI). Am J Cardiol. 1998;81(4):375-81. [pmid: 9485122].
84 Szczech LA, Best PJ, Crowley E, et al. Outcomes of patients with chronic renal insufficiency in the bypass angioplasty revascularization investigation. Circulation. May 14. 2002;105(19):2253-8. [pmid: 12010906].
85 The Bypass Angioplasty Revascularization Investigation (BARI) Investigators. The Final 10-Year Follow-Up. Results from the BARI Randomized Trial. J Am Coll Cardiol. 2007;49(15):1600-6. [pmid: 17433949].
86 Writing Group for the Bypass Angioplasty Revascularization Investigation (BARI) Investigators. Five-year clinical and functional outcome comparing bypass surgery and angioplasty in patients with multivessel coronary disease. A multicenter randomized trial. JAMA. Mar 5. 1997;277(9):715-21. [pmid: 9042843].
87 CABRI Trial Participants. First-year results of CABRI (Coronary Angioplasty versus Bypass Revascularisation Investigation). Lancet. Nov 4. 1995;346(8984):1179-84. [pmid: 7475656].
88 Kurbaan AS, Bowker TJ, Ilsley CD, et al. The effect of adjusting for baseline risk factors and post revascularisation coronary disease on comparisons between coronary angioplasty and bypass surgery. Int J Cardiol. Feb. 2001;77(23):207-14. [pmid: 11182184].
89 Kurbaan AS, Bowker TJ, Ilsley CD, et al. Difference in the mortality of the CABRI diabetic and nondiabetic populations and its relation to coronary artery disease and the revascularization mode. Am J Cardiol. Apr 15. 2001;87(8):947-50. A3. [pmid: 11305983].
90 Kurbaan AS, Bowker TJ, Ilsley CDJ, et al. Impact of postangioplasty restenosis on comparisons of outcome between angioplasty and bypass grafting. Am J Cardiol. 1998;82(3):272-6. [pmid: 9708652].
91 Kurbaan AS, Bowker TJ, Rickards AF. Differential restenosis rate of individual coronary artery sites after multivessel angioplasty: implications for revascularization strategy. CABRI Investigators. Coronary Angioplasty versus Bypass Revascularisation Investigation. Am Heart J. 1998;135(4):703-8. [pmid: 9539489].
92 Kurbaan AS, Bowker TJ, Rickards AF. Trials of angioplasty and surgery: CABRI. Semin Interv Cardiol. 1999;4(4):179-84. [pmid: 10738350].
93 Wahrborg P. Quality of life after coronary angioplasty or bypass surgery. 1-year follow-up in the Coronary Angioplasty versus Bypass Revascularization investigation (CABRI) trial. Eur Heart J. May. 1999;20(9):653-8. [pmid: 10208785].
94 King SB 3rd, Lembo NJ, Weintraub WS, et al. A randomized trial comparing coronary angioplasty with coronary bypass surgery. Emory Angioplasty versus Surgery Trial (EAST). N Engl J Med. Oct 20. 1994;331(16):1044-50. [pmid: 8090163].
95 Alazraki NP, Krawczynska EG, Kosinski AS, et al. Prognostic value of thallium-201 single-photon emission computed tomography for patients with multivessel coronary artery disease after revascularization (the Emory Angioplasty versus Surgery Trial [EAST]). Am J Cardiol. 1999;84(12):1369-74. [pmid: 10606106].
96 Becker ER, Mauldin PD, Culler SD, et al. Applying the resource-based relative value scale to the Emory angioplasty versus surgery trial. Am J Cardiol. 2000;85(6):685-91. [pmid: 12004793].
97 King SB, Lembo NJ, Weintraub WS, et al. Emory Angioplasty Versus Surgery Trial (EAST): design, recruitment, and baseline description of patients. Am J Cardiol. 1995;75(9):42C-59C.
98 Weintraub WS, Mauldin PD, Becker E, et al. A comparison of the costs of and quality of life after coronary angioplasty or coronary surgery for multivessel coronary artery disease. Results from the Emory Angioplasty Versus Surgery Trial (EAST). Circulation. 1995;92(10):2831-40. [pmid: 7586249].
99 Weintraub WS, Becker ER, Mauldin PD, et al. Costs of revascularization over eight years in the randomized and eligible patients in the Emory Angioplasty versus Surgery Trial (EAST). Am J Cardiol. 2000;86(7):747-52. [pmid: 11018194].
100 Zhao XQ, Brown BG, Stewart DK, et al. Effectiveness of revascularization in the Emory angioplasty versus surgery trial. A randomized comparison of coronary angioplasty with bypass surgery. Circulation. 1996;93(11):1954-62. [pmid: 8640968].
101 King SB 3rd. The Emory Angioplasty vs Surgery Trial (EAST). Semin Interv Cardiol. Dec. 1999;4(4):185-90. [pmid: 10738351].
102 King SB 3rd, Kosinski AS, Guyton RA, et al. Eight-year mortality in the Emory Angioplasty versus Surgery Trial (EAST). J Am Coll Cardiol. Apr. 2000;35(5):1116-21. [pmid: 10758949].
103 Zhao XQ, Kosinski AS, Barnhart HX, et al. Prediction of native coronary artery disease progression following PTCA or CABG in the Emory Angioplasty Versus Surgery Trial. Med Sci Monit. Feb. 2003;9(2):CR48-54. [pmid: 12601286].
104 Rodriguez A, Boullon F, Perez-Balino N, et al. Argentine randomized trial of percutaneous transluminal coronary angioplasty versus coronary artery bypass surgery in multivessel disease (ERACI): in-hospital results and 1-year follow-up. ERACI Group. J Am Coll Cardiol. 1993;22(4):1060-7. [pmid: 8409041].
105 Rodriguez A, Mele E, Peyregne E, et al. Three-year follow-up of the Argentine Randomized Trial of Percutaneous Transluminal Coronary Angioplasty Versus Coronary Artery Bypass Surgery in Multivessel Disease (ERACI). J Am Coll Cardiol. 1996;27(5):1178-84. [pmid: 8609339].
106 Rodriguez A, Bernardi V, Navia J, et al. Argentine Randomized Study: Coronary Angioplasty with Stenting versus Coronary Bypass Surgery in patients with Multiple-Vessel Disease (ERACI II): 30-day and one-year follow-up results. ERACI II Investigators.[erratum appears in J Am Coll Cardiol 2001 Mar 1;37(3):973–4]. J Am Coll Cardiol. Jan. 2001;37(1):51-8. [pmid: 11153772].
107 Rodriguez A, Rodriguez Alemparte M, Baldi J, et al. Coronary stenting versus coronary bypass surgery in patients with multiple vessel disease and significant proximal LAD stenosis: results from the ERACI II study. Heart (British Cardiac Society). 2003;89(2):184-8. [pmid: 12527674].
108 Rodriguez AE, Baldi J, Fernandez Pereira C, et al. Five-year follow-up of the Argentine randomized trial of coronary angioplasty with stenting versus coronary bypass surgery in patients with multiple vessel disease (ERACI II). J Am Coll Cardiol. Aug 16. 2005;46(4):582-8. [pmid: 16098419].
109 Hamm CW, Reimers J, Ischinger T, et al. A randomized study of coronary angioplasty compared with bypass surgery in patients with symptomatic multivessel coronary disease. German Angioplasty Bypass Surgery Investigation (GABI). N Engl J Med. Oct 20. 1994;331(16):1037-43. [pmid: 8090162].
110 Kaehler J, Koester R, Billmann W, et al. 13-year follow-up of the German angioplasty bypass surgery investigation. Eur Heart J. Oct. 2005;26(20):2148-53. [pmid: 15975991].
111 Rupprecht HJ, Hamm C, Ischinger T, et al. Angiographic follow-up results of a randomized study on angioplasty versus bypass surgery (GABI trial). GABI Study Group. Eur Heart J. Aug. 1996;17(8):1192-8. [pmid: 8869860].
112 Drenth DJ, Veeger NJGM, Winter JB, et al. A prospective randomized trial comparing stenting with off-pump coronary surgery for high-grade stenosis in the proximal left anterior descending coronary artery: three-year follow-up. J Am Coll Cardiol. Dec 4. 2002;40(11):1955-60. [pmid: 12475455].
113 Drenth DJ, Veeger NJGM, Grandjean JG, et al. Isolated high-grade lesion of the proximal LAD: a stent or off-pump LIMA?. Eur J Cardiothorac Surg. Apr. 2004;25(4):567-71. [pmid: 15037273].
114 Drenth DJ, Veeger NJGM, Middel B, et al. Comparison of late (four years) functional health status between percutaneous transluminal angioplasty intervention and off-pump left internal mammary artery bypass grafting for isolated high-grade narrowing of the proximal left anterior descending coronary artery. Am J Cardiol. Dec 1. 2004;94(11):1414-7. [pmid: 15566914].
115 Drenth DJ, Winter JB, Veeger NJGM, et al. Minimally invasive coronary artery bypass grafting versus percutaneous transluminal coronary angioplasty with stenting in isolated high-grade stenosis of the proximal left anterior descending coronary artery: six months' angiographic and clinical follow-up of a prospective randomized study. J Thorac Cardiovasc Surg. Jul. 2002;124(1):130-5. [pmid: 12091818].
116 Goy JJ, Eeckhout E, Burnand B, et al. Coronary angioplasty versus left internal mammary artery grafting for isolated proximal left anterior descending artery stenosis. Lancet. 1994;343(8911):1449-53. [pmid: 7911175].
117 Goy JJ, Eeckhout E, Moret C, et al. Five-year outcome in patients with isolated proximal left anterior descending coronary artery stenosis treated by angioplasty or left internal mammary artery grafting. A prospective trial. Circulation. 1999;99(25):3255-9. [pmid: 10385499].
118 Diegeler A, Thiele H, Falk V, et al. Comparison of stenting with minimally invasive bypass surgery for stenosis of the left anterior descending coronary artery. N Engl J Med. Aug 22. 2002;347(8):561-6. [pmid: 12192015].
119 Diegeler A, Spyrantis N, Matin M, et al. The revival of surgical treatment for isolated proximal high grade LAD lesions by minimally invasive coronary artery bypass grafting. Eur J Cardiothorac Surg. 2000;17(5):501-4. [pmid: 10814909].
120 Thiele H, Oettel S, Jacobs S, et al. Comparison of bare-metal stenting with minimally invasive bypass surgery for stenosis of the left anterior descending coronary artery: a 5-year follow-up. Circulation. 2005;112(22):3445-50. [pmid: 16316966].
121 Hueb WA, Bellotti G, de Oliveira SA, et al. The Medicine, Angioplasty or Surgery Study (MASS): a prospective, randomized trial of medical therapy, balloon angioplasty or bypass surgery for single proximal left anterior descending artery stenoses. J Am Coll Cardiol. 1995;26(7):1600-5. [pmid: 7594092].
122 Hueb WA, Soares PR, Almeida De Oliveira S, et al. Five-year follow-op of the medicine, angioplasty, or surgery study (MASS): A prospective, randomized trial of medical therapy, balloon angioplasty, or bypass surgery for single proximal left anterior descending coronary artery stenosis. Circulation. 1999;100(19 Suppl):II107-13. [pmid: 10567287].
123 Hueb W, Soares PR, Gersh BJ, et al. The medicine, angioplasty, or surgery study (MASS-II): a randomized, controlled clinical trial of three therapeutic strategies for multivessel coronary artery disease: one-year results. J Am Coll Cardiol. May 19. 2004;43(10):1743-51. [pmid: 15145093].
124 Favarato D, Hueb W, Gersh BJ, et al. Relative cost comparison of treatments for coronary artery disease: the First Year Follow-Up of MASS II Study. Circulation. Sep 9. 2003;108(Suppl 1):II21-3. [pmid: 12970202].
125 Soares PR, Hueb WA, Lemos PA, et al. Coronary Revascularization (Surgical or Percutaneous) Decreases Mortality After the First Year in Diabetic Subjects but not in Nondiabetic Subjects With Multivessel Disease: An Analysis From the Medicine, Angioplasty, or Surgery Study (MASS II). Circulation. 2006 July 4, 2006;114:I-420-I-4.
126 Pohl T, Giehrl W, Reichart B, et al. Retroinfusion-supported stenting in high-risk patients for percutaneous intervention and bypass surgery: results of the prospective randomized myoprotect I study. Catheter Cardiovasc Interv. 2004;62(3):323-30. [pmid: 15224298].
127 Eefting F, Nathoe H, van Dijk D, et al. Randomized comparison between stenting and off-pump bypass surgery in patients referred for angioplasty. Circulation. Dec 9. 2003;108(23):2870-6. [pmid: 14656913].
128 Nathoe HM, Van Dijk D, Jansen EWL, et al. Off-pump coronary artery bypass surgery compared with stent implantation and on-pump bypass surgery: Clinical outcome and cost-effectiveness at one year. Neth Heart J. 2005;13(78):259-68. [pmid: 25696506].
129 van Dijk D, Nierich AP, Eefting FD, et al. The Octopus Study: rationale and design of two randomized trials on medical effectiveness, safety, and cost-effectiveness of bypass surgery on the beating heart. Control Clin Trials. 2000;21(6):595-609. [pmid: 11146152].
130 Cisowski M, Drzewiecki J, Drzewiecka-Gerber A, et al. Primary stenting versus MIDCAB: preliminary report-comparision of two methods of revascularization in single left anterior descending coronary artery stenosis. Ann Thorac Surg. 2002;74(4):S1334-9. [pmid: 12400812].
131 Cisowski M, Drzewiecka-Gerber A, Ulczok R, et al. Primary direct stenting versus endoscopic atraumatic coronary artery bypass surgery in patients with proximal stenosis of the left anterior descending coronary artery—a prospective, randomised study. Kardiol Pol. 2004;61(9):253-61. discussion 62–4. [pmid: 15531937].
132 Henderson RA, Pocock SJ, Sharp SJ, et al. Long-term results of RITA-1 trial: clinical and cost comparisons of coronary angioplasty and coronary-artery bypass grafting. Randomised Intervention Treatment of Angina. Lancet. Oct 31. 1998;352(9138):1419-25. [pmid: 9807988].
133 Coronary angioplasty versus coronary artery bypass surgery: the Randomized Intervention Treatment of Angina (RITA) trial. Lancet. 1993 Mar 6;341(8845):573–80.
134 Hampton JR. Rita. Semin Interv Cardiol. Dec. 1999;4(4):169-77. [pmid: 10738349].
135 Henderson RA. The Randomised Intervention Treatment of Angina (RITA) Trial protocol: a long term study of coronary angioplasty and coronary artery bypass surgery in patients with angina. Br Heart J. Nov. 1989;62(5):411-4. [pmid: 2486557].
136 Pocock SJ, Henderson RA, Seed P, et al. Quality of life, employment status, and anginal symptoms after coronary angioplasty or bypass surgery. 3-year follow-up in the Randomized Intervention Treatment of Angina (RITA) Trial. Circulation. 1996;94(2):135-42. [pmid: 8674171].
137 Sculpher MJ, Seed P, Henderson RA, et al. Health service costs of coronary angioplasty and coronary artery bypass surgery: the Randomised Intervention Treatment of Angina (RITA) trial. Lancet. Oct 1. 1994;344(8927):927-30. [pmid: 7934351].
138 Goy JJ, Kaufmann U, Goy-Eggenberger D, et al. A prospective randomized trial comparing stenting to internal mammary artery grafting for proximal, isolated de novo left anterior coronary artery stenosis: The SIMA trial. Mayo Clin Proc. 2000;75(11):1116-23. [pmid: 11075740].
139 SoS Investigators. Coronary artery bypass surgery versus percutaneous coronary intervention with stent implantation in patients with multivessel coronary artery disease (the Stent or Surgery trial): a randomised controlled trial. Lancet. Sep 28. 2002;360(9338):965-70. [pmid: 12383664].
140 Stables RH. Design of the ‘Stent or Surgery’ trial (SoS): a randomized controlled trial to compare coronary artery bypass grafting with percutaneous transluminal coronary angioplasty and primary stent implantation in patients with multi-vessel coronary artery disease. Semin Interv Cardiol. 1999;4(4):201-7. [pmid: 10738353].
141 Wahrborg P, Booth JE, Clayton T, et al. Neuropsychological outcome after percutaneous coronary intervention or coronary artery bypass grafting: results from the Stent or Surgery (SoS) Trial. Circulation. Nov 30. 2004;110(22):3411-7. [pmid: 15557380].
142 Weintraub WS, Mahoney EM, Zhang Z, et al. One year comparison of costs of coronary surgery versus percutaneous coronary intervention in the stent or surgery trial. Heart (British Cardiac Society). 2004;90(7):782-8. [pmid: 15201249].
143 Zhang Z, Mahoney EM, Stables RH, et al. Disease-specific health status after stent-assisted percutaneous coronary intervention and coronary artery bypass surgery: one-year results from the Stent or Surgery trial. Circulation. 2003;108(14):1694-700. [pmid: 12975252].
144 Zhang Z, Spertus JA, Mahoney EM, et al. The impact of acute coronary syndrome on clinical, economic, and cardiac-specific health status after coronary artery bypass surgery versus stent-assisted percutaneous coronary intervention: 1-year results from the stent or surgery (SoS) trial. Am Heart J. 2005;150(1):175-81. [pmid: 16084166].
145 Zhang Z, Weintraub WS, Mahoney EM, et al. Relative benefit of coronary artery bypass grafting versus stent-assisted percutaneous coronary intervention for angina pectoris and multivessel coronary disease in women versus men (one-year results from the Stent or Surgery trial). Am J Cardiol. 2004;93(4):404-9. [pmid: 14969611].
146 Carrie D, Elbaz M, Puel J, et al. Five-year outcome after coronary angioplasty versus bypass surgery in multivessel coronary artery disease: results from the French Monocentric Study. Circulation. 1997;96(9 Suppl):II-1-6.
147 Dzavik V, Ghali WA, Norris C, et al. Long-term survival in 11,661 patients with multivessel coronary artery disease in the era of stenting: a report from the Alberta Provincial Project for Outcome Assessment in Coronary Heart Disease (APPROACH) Investigators. Am Heart J. Jul. 2001;142(1):119-26. [pmid: 11431667].
148 ACC/AHA/SCAI 2005 guideline update for percutaneous coronary intervention. A report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines (ACC/AHA/SCAI Writing Committee to update the 2001 guidelines for percutaneous coronary intervention). [cited December 6, 2006]; Available from: http://www.guideline.gov/summary/summary.aspx?doc_id=8343&nbr=004670&string=PCI
149 Smith SC Jr, Feldman T, Hirshfeld JJ, et al. ACC/AHA/SCAI 2005 guideline update for percutaneous coronary intervention: a report of the American College of Cardiology/American Heart Assoc Task Force on Practice Guidelines (ACC/AHA/SCAI Writing Committee to update the 2001 guidelines for PCI). Bethesda (MD): American College of Cardiology Foundation (ACCF); 2005. 122 p. [926 references].
150 Eagle KA, Guyton RA, Davidoff R, et al. ACC/AHA 2004 Guideline Update for Coronary Artery Bypass Graft Surgery. A Report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines (Committee to Update the 1999 Guidelines for Coronary Artery Bypass Graft Surgery). Developed in Collaboration With the American Association for Thoracic Surgery and the Society of Thoracic Surgeons. p 274. [cited December 6, 2006]; Available from: http://www.acc.org/qualityandscience/clinical/guidelines/
151 Morrison DA, Sethi G, Sacks J, et al. Percutaneous coronary intervention versus coronary bypass graft surgery for patients with medically refractory myocardial ischemia and risk factors for adverse outcomes with bypass: The VA AWESOME multicenter registry: comparison with the randomized clinical trial. J Am Coll Cardiol. Jan 16. 2002;39(2):266-73. [pmid: 11788218].
152 Feit F, Brooks MM, Sopko G, et al. Long-term clinical outcome in the Bypass Angioplasty Revascularization Investigation Registry: comparison with the randomized trial. BARI Investigators. Circulation. Jun 20. 2000;101(24):2795-802. [pmid: 10859284].
153 Brener SJ, Lytle BW, Casserly IP, et al. Propensity Analysis of Long-Term Survival After Surgical or Percutaneous Revascularization in Patients With Multivessel Coronary Artery Disease and High-Risk Features. Circulation. 2004;109(19):2290-5. [pmid: 15117846].
154 Brener SJ, Lytle BW, Casserly IP, et al. Predictors of revascularization method and long-term outcome of percutaneous coronary intervention or repeat coronary bypass surgery in patients with multivessel coronary disease and previous coronary bypass surgery. Eur Heart J. 2006;27(4):413-8. [pmid: 16272211].
155 Brener S, Loop FD, Lytle BW, et al. A Profile of Candidates for Repeat Myocardial Revascularization: Implications for Selection of Treatment. J Thorac Cardiovasc Surg. 1997;114(2):153-61. [pmid: 9270630].
156 Mark DB, Nelson CL, Califf RM, et al. Coronary Heart Disease/Myocardial Infarction: Continuing Evolution of Therapy for Coronary Artery Disease: Initial Results From the Era of Coronary Angioplasty. Circulation. 1994;89(5):2015-25. [pmid: 8181125].
157 Jones RH, Kesler K, Phillips HR 3rd, et al. Long-term survival benefits of coronary artery bypass grafting and percutaneous transluminal angioplasty in patients with coronary artery disease. J Thorac Cardiovasc Surg. May. 1996;111(5):1013-25. [pmid: 8622299].
158 Califf RM, Harrell FE Jr, Lee KL, et al. The evolution of medical and surgical therapy for coronary artery disease. A 15-year perspective. JAMA. Apr 14. 1989;261(14):2077-86. [pmid: 2784512].
159 Smith PK, Califf RM, Tuttle RH, et al. Selection of surgical or percutaneous coronary intervention provides differential longevity benefit. Ann Thorac Surg. Oct. 2006;82(4):1420-8. discussion 8–9. [pmid: 16996946].
160 Weintraub WS, Clements SD Jr, Crisco LVT, et al. Twenty-year survival after coronary artery surgery: an institutional perspective from Emory University. Circulation. Mar 11. 2003;107(9):1271-7. [pmid: 12628947].
161 Weintraub WS, King SB 3rd, Jones EL, et al. Coronary surgery and coronary angioplasty in patients with two-vessel coronary artery disease. Am J Cardiol. Mar 1. 1993;71(7):511-7. [pmid: 8438735].
162 Craver JM, Hodakowski GT, Shen Y, et al. Third-time coronary artery bypass operations: surgical strategy and results. Ann Thorac Surg. Dec. 1996;62(6):1801-7. [pmid: 8957390].
163 Weintraub WS, Ghazzal ZM, Douglas JS Jr, et al. Initial management and long-term clinical outcome of restenosis after initially successful percutaneous transluminal coronary angioplasty. Am J Cardiol. Jul 1. 1992;70(1):47-55. [pmid: 1615869].
164 Weintraub WS, Jones EL, Craver JM, et al. In-hospital and long-term outcome after reoperative coronary artery bypass graft surgery. Circulation. Nov 1. 1995;92(9 Suppl):II50-7. [pmid: 7586461].
165 Weintraub WS, Jones EL, Craver JM, et al. Frequency of repeat coronary bypass or coronary angioplasty after coronary artery bypass surgery using saphenous venous grafts. Am J Cardiol. Jan 15. 1994;73(2):103-12. [pmid: 8296729].
166 Weintraub WS, Jones EL, Morris DC, et al. Outcome of reoperative coronary bypass surgery versus coronary angioplasty after previous bypass surgery. Circulation. Feb 18. 1997;95(4):868-77. [pmid: 9054744].
167 King SB 3rd, Barnhart HX, Kosinski AS, et al. Angioplasty or surgery for multivessel coronary artery disease: comparison of eligible registry and randomized patients in the EAST trial and influence of treatment selection on outcomes. Emory Angioplasty versus Surgery Trial Investigators. Am J Cardiol. Jun 1. 1997;79(11):1453-9. [pmid: 9185632].
168 Mack MJ, Brown PP, Kugelmass AD, et al. Current status and outcomes of coronary revascularization 1999 to 2002: 148,396 surgical and percutaneous procedures. Ann Thorac Surg. Mar. 2004;77(3):761-6. discussion 6–8. [pmid: 14992867].
169 Stephan WJ, O'Keefe JH Jr, Piehler JM, et al. Coronary angioplasty versus repeat coronary artery bypass grafting for patients with previous bypass surgery. J Am Coll Cardiol. Nov 1. 1996;28(5):1140-6. [pmid: 8890807].
170 Harris WO, Mock MB, Orszulak TA, et al. Use of coronary artery bypass surgical procedure and coronary angioplasty in treatment of coronary artery disease: changes during a 10-year period at Mayo Clinic Rochester. Mayo Clin Proc. Oct. 1996;71(10):927-35. [pmid: 8820766].
171 Rosen AK, Geraci JM, Ash AS, et al. Postoperative adverse events of common surgical procedures in the Medicare population. Med Care. Sep. 1992;30(9):753-65. [pmid: 1518309].
172 Geraci JM, Rosen AK, Ash AS, et al. Predicting the occurrence of adverse events after coronary artery bypass surgery. Ann Intern Med. Jan 1. 1993;118(1):18-24. [pmid: 8416153].
173 Rosen AK, Ash AS, McNiff KJ, et al. The importance of severity of illness adjustment in predicting adverse outcomes in the Medicare population. J Clin Epidemiol. May. 1995;48(5):631-43. [pmid: 7730920].
174 Peterson ED, Jollis JG, Bebchuk JD, et al. Changes in mortality after myocardial revascularization in the elderly. The national Medicare experience. Ann Intern Med. Dec 15. 1994;121(12):919-27. [pmid: 7978717].
175 Hartz AJ, Kuhn EM, Pryor DB, et al. Mortality after coronary angioplasty and coronary artery bypass surgery (the national Medicare experience). Am J Cardiol. Jul 15. 1992;70(2):179-85. [pmid: 1626504].
176 Venkatappa S, Murray CK, Bratzler DW. Coronary artery bypass grafting surgery in Oklahoma: processes and outcomes of care. J Okla State Med Assoc. Feb. 2003;96(2):63-9. [pmid: 12674906].
177 Birkmeyer JD, Siewers AE, Finlayson EV, et al. Hospital volume and surgical mortality in the United States. N Engl J Med. Apr 11. 2002;346(15):1128-37. [pmid: 11948273].
178 Birkmeyer JD, Stukel TA, Siewers AE, et al. Surgeon volume and operative mortality in the United States. N Engl J Med. Nov 27. 2003;349(22):2117-27. [pmid: 14645640].
179 Jollis JG, Peterson ED, DeLong ER, et al. The relation between the volume of coronary angioplasty procedures at hospitals treating Medicare beneficiaries and short-term mortality. N Engl J Med. Dec 15. 1994;331(24):1625-9. [pmid: 7969344].
180 Jollis JG, Peterson ED, Nelson CL, et al. Relationship between physician and hospital coronary angioplasty volume and outcome in elderly patients. Circulation. Jun 3. 1997;95(11):2485-91. [pmid: 9184578].
181 Maynard C, Every NR, Chapko MK, et al. Outcomes of coronary angioplasty procedures performed in rural hospitals. Am J Med. Jun 15. 2000;108(9):710-3. [pmid: 10924647].
182 McGrath PD, Wennberg DE, Dickens JD Jr, et al. Relation between operator and hospital volume and outcomes following percutaneous coronary interventions in the era of the coronary stent. JAMA. Dec 27. 2000;284(24):3139-44. [pmid: 11135777].
183 Riley G, Lubitz J. Outcomes of surgery among the Medicare aged: surgical volume and mortality. Health Care Financ Rev. Fall. 1985;7(1):37-47. [pmid: 10317676].
184 Ritchie JL, Maynard C, Every NR, et al. Coronary artery stent outcomes in a Medicare population: less emergency bypass surgery and lower mortality rates in patients with stents. Am Heart J. Sep. 1999;138(3 Pt 1):437-40. [pmid: 10467192].
185 Welke KF, Barnett MJ, Sarrazin MS, et al. Limitations of hospital volume as a measure of quality of care for coronary artery bypass graft surgery. Ann Thorac Surg. Dec. 2005;80(6):2114-9. [pmid: 16305854].
186 Hannan EL, Arani DT, Johnson LW, et al. Percutaneous transluminal coronary angioplasty in New York State. Risk factors and outcomes. JAMA. Dec 2. 1992;268(21):3092-7. [pmid: 1433740].
187 Hannan EL, Racz MJ, McCallister BD, et al. A comparison of three-year survival after coronary artery bypass graft surgery and percutaneous transluminal coronary angioplasty. J Am Coll Cardiol. Jan. 1999;33(1):63-72. [pmid: 9935010].
188 Hannan EL, Racz MJ, Walford G, et al. Long-term outcomes of coronary-artery bypass grafting versus stent implantation. N Engl J Med. May 26. 2005;352(21):2174-83. [pmid: 15917382].
189 Glance LG, Dick AW, Osler TM, et al. The relation between surgeon volume and outcome following off-pump vs on-pump coronary artery bypass graft surgery. Chest. Aug. 2005;128(2):829-37. [pmid: 16100175].
190 Hannan EL, Kilburn H Jr, Racz M, et al. Improving the outcomes of coronary artery bypass surgery in New York State. JAMA. Mar 9. 1994;271(10):761-6. [pmid: 8114213].
191 Wu C, Hannan EL, Ryan TJ, et al. Is the impact of hospital and surgeon volumes on the in-hospital mortality rate for coronary artery bypass graft surgery limited to patients at high risk?. Circulation. Aug 17. 2004;110(7):784-9. [pmid: 15302792].
192 Rosenthal GE, Vaughan Sarrazin M, Hannan EL. In-hospital mortality following coronary artery bypass graft surgery in Veterans Health Administration and private sector hospitals. Med Care. Apr. 2003;41(4):522-35. [pmid: 12665716].
193 Hannan EL, Wu C, Walford G, et al. Volume-outcome relationships for percutaneous coronary interventions in the stent era. Circulation. Aug 23. 2005;112(8):1171-9. [pmid: 16103238].
194 Hannan EL, Wu C, Ryan TJ, et al. Do hospitals and surgeons with higher coronary artery bypass graft surgery volumes still have lower risk-adjusted mortality rates?. Circulation. Aug 19. 2003;108(7):795-801. [pmid: 12885743].
195 Hannan EL, Siu AL, Kumar D, et al. The decline in coronary artery bypass graft surgery mortality in New York State. The role of surgeon volume. JAMA. Jan 18. 1995;273(3):209-13. [pmid: 7807659].
196 Hannan EL, Racz M, Ryan TJ, et al. Coronary angioplasty volume-outcome relationships for hospitals and cardiologists. JAMA. Mar 19. 1997;277(11):892-8. [pmid: 9062327].
197 Hannan EL, O'Donnell JF, Kilburn H Jr, et al. Investigation of the relationship between volume and mortality for surgical procedures performed in New York State hospitals. JAMA. Jul 28. 1989;262(4):503-10. [pmid: 2491412].
198 Hannan EL, Kilburn H Jr, Bernard H, et al. Coronary artery bypass surgery: the relationship between inhospital mortality rate and surgical volume after controlling for clinical risk factors. Med Care. Nov. 1991;29(11):1094-107. [pmid: 1943270].
199 Hannan EL, Kilburn H Jr, O'Donnell JF, et al. Adult open heart surgery in New York State. An analysis of risk factors and hospital mortality rates. JAMA. Dec 5. 1990;264(21):2768-74. [pmid: 2232064].
200 Sollano JA, Gelijns AC, Moskowitz AJ, et al. Volume-outcome relationships in cardiovascular operations: New York State, 1990-1995. J Thorac Cardiovasc Surg. Mar. 1999;117(3):419-28. discussion 28–30. [pmid: 10047643].
201 Malenka DJ, Leavitt BJ, Hearne MJ, et al. Comparing long-term survival of patients with multivessel coronary disease after CABG or PCI: analysis of BARI-like patients in northern New England. Circulation. Aug 30. 2005;112(9 Suppl):I371-6. [pmid: 16159849].
202 Likosky DS, Nugent WC, Clough RA, et al. Comparison of three measurements of cardiac surgery mortality for the Northern New England Cardiovascular Disease Study Group. Ann Thorac Surg. Apr. 2006;81(4):1393-5. [pmid: 16564278].
203 McGrath PD, Malenka DJ, Wennberg DE, et al. Changing outcomes in percutaneous coronary interventions: a study of 34,752 procedures in northern New England, 1990 to 1997. Northern New England Cardiovascular Disease Study Group. J Am Coll Cardiol. Sep. 1999;34(3):674-80. [pmid: 10483947].
204 Malenka DJ, McGrath PD, Wennberg DE, et al. The relationship between operator volume and outcomes after percutaneous coronary interventions in high volume hospitals in 1994-1996: the northern New England experience. Northern New England Cardiovascular Disease Study Group. J Am Coll Cardiol. Nov 1. 1999;34(5):1471-80. [pmid: 10551694].
205 McGrath PD, Wennberg DE, Malenka DJ, et al. Operator volume and outcomes in 12,998 percutaneous coronary interventions. Northern New England Cardiovascular Disease Study Group. J Am Coll Cardiol. Mar 1. 1998;31(3):570-6. [pmid: 9502637].
206 Pell JP, Walsh D, Norrie J, et al. Outcomes following coronary artery bypass grafting and percutaneous transluminal coronary angioplasty in the stent era: a prospective study of all 9890 consecutive patients operated on in Scotland over a two year period. Heart. Jun. 2001;85(6):662-6. [pmid: 11359748].
207 Burton KR, Slack R, Oldroyd KG, et al. Hospital volume of throughput and periprocedural and medium-term adverse events after percutaneous coronary intervention: retrospective cohort study of all 17 417 procedures undertaken in Scotland, 1997-2003. Heart. 2006;92(11):1667-72. [pmid: 16709693].
208 Steinbrook R. Public report cards—cardiac surgery and beyond. N Engl J Med. Nov 2. 2006;355(18):1847-9. [pmid: 17079758].
209 Ferguson TB Jr, Hammill BG, Peterson ED, et al. A decade of change—risk profiles and outcomes for isolated coronary artery bypass grafting procedures, 1990-1999: a report from the STS National Database Committee and the Duke Clinical Research Institute. Society of Thoracic Surgeons. Ann Thorac Surg. Feb. 2002;73(2):480-9. discussion 9–90. [pmid: 11845863].
210 Peterson ED, Coombs LP, DeLong ER, et al. Procedural volume as a marker of quality for CABG surgery. JAMA. Jan 14. 2004;291(2):195-201. [pmid: 14722145].
211 Clark RE. Outcome as a function of annual coronary artery bypass graft volume. The Ad Hoc Committee on Cardiac Surgery Credentialing of The Society of Thoracic Surgeons. Ann Thorac Surg. Jan. 1996;61(1):21-6. [pmid: 8561556].
212 Carey JS, Danielsen B, Gold JP, et al. Procedure rates and outcomes of coronary revascularization procedures in California and New York. J Thorac Cardiovasc Surg. 2005;129(6):1276-82. [pmid: 15942567].
213 Whitlow PL, Dimas AP, Bashore TM, et al. Relationship of extent of revascularization with angina at one year in the Bypass Angioplasty Revascularization Investigation (BARI). J Am Coll Cardiol. 1999;34(6):1750-9. [pmid: 10577566].
214 Kapur A, Malik IS, Bagger JP, et al. The Coronary Artery Revascularisation in Diabetes (CARDia) trial: background, aims, and design. Am Heart J. Jan. 2005;149(1):13-9. [pmid: 15660030].
215 Guru V, Omura J, Alghamdi AA, et al. Is blood superior to crystalloid cardioplegia? A meta-analysis of randomized clinical trials. Circulation. Jul 4. 2006;114(1 Suppl):I331-8. [pmid: 16820596].
216 Liao L, Sarria-Santamera A, Matchar DB, et al. Meta-analysis of survival and relief of angina pectoris after transmyocardial revascularization. Am J Cardiol. May 15. 2005;95(10):1243-5. [pmid: 15878002].
217 Kong DF, Hasselblad V, Harrington RA, et al. Meta-analysis of survival with platelet glycoprotein IIb/IIIa antagonists for percutaneous coronary interventions. Am J Cardiol. Sep 15. 2003;92(6):651-5. [pmid: 12972100].
218 Newby LK, LaPointe NM, Chen AY, et al. Long-term adherence to evidence-based secondary prevention therapies in coronary artery disease. Circulation. Jan 17. 2006;113(2):203-12. [pmid: 16401776].
219 Halm EA, Lee C, Chassin MR. Is volume related to outcome in health care? A systematic review and methodologic critique of the literature. Ann Intern Med. Sep 17. 2002;137(6):511-20. [pmid: 12230353].
220 Luft HS, Garnick DW, Mark DH, et al. Hospital Volume, Physician Volume, and Patient Outcomes. Ann Arbor: Health Administration Press; 1990.
221 Dudley RA, Johansen KL, Brand R, et al. Selective referral to high-volume hospitals: estimating potentially avoidable deaths. JAMA. Mar 1. 2000;283(9):1159-66. [pmid: 10703778].
222 EHR Scoring. What does a hospital's overall score mean? [cited November 24, 2006]; Available from: http://leapfroggroup.org/for_cosumers/ehr_scoring
223 Shahian DM. Improving cardiac surgery quality—volume, outcome, process?. JAMA. Jan 14. 2004;291(2):246-8. [pmid: 14722153].
224 Shahian DM, Normand SL. The volume-outcome relationship: from Luft to Leapfrog. Ann Thorac Surg. Mar. 2003;75(3):1048-58. [pmid: 12645752].
225 Luft HS, Bunker JP, Enthoven AC. Should operations be regionalized? The empirical relation between surgical volume and mortality. N Engl J Med. Dec 20. 1979;301(25):1364-9. [pmid: 503167].
226 Maerki SC, Luft HS, Hunt SS. Selecting categories of patients for regionalization. Implications of the relationship between volume and outcome. Med Care. Feb. 1986;24(2):148-58. [pmid: 3080647].
227 Birkmeyer JD, Dimick JB. Potential benefits of the new Leapfrog standards: effect of process and outcomes measures. Surgery. Jun. 2004;135(6):569-75. [pmid: 15179361].
228 Epstein AJ, Rathore SS, Krumholz HM, et al. Volume-based referral for cardiovascular procedures in the United States: a cross-sectional regression analysis. BMC Health Serv Res. Jun 3. 2005;5(1):42. [pmid: 15935099].
229 Cheng DC, Bainbridge D, Martin JE, et al. Does off-pump coronary artery bypass reduce mortality, morbidity, and resource utilization when compared with conventional coronary artery bypass? A meta-analysis of randomized trials. Anesthesiology. Jan. 2005;102(1):188-203. [pmid: 15618803].
230 Sellke FW, DiMaio JM, Caplan LR, et al. Comparing on-pump and off-pump coronary artery bypass grafting: numerous studies but few conclusions: a scientific statement from the American Heart Association council on cardiovascular surgery and anesthesia in collaboration with the interdisciplinary working group on quality of care and outcomes research. Circulation. May 31. 2005;111(21):2858-64. [pmid: 15927994].
231 Luft HS. The relation between surgical volume and mortality: an exploration of causal factors and alternative models. Med Care. Sep. 1980;18(9):940-59. [pmid: 7432019].
232 Sloan FA, Perrin JM, Valvona J. In-hospital mortality of surgical patients: is there an empiric basis for standard setting?. Surgery. Apr. 1986;99(4):446-54. [pmid: 3485314].
233 Hughes RG, Hunt SS, Luft HS. Effects of surgeon volume and hospital volume on quality of care in hospitals. Med Care. Jun. 1987;25(6):489-503. [pmid: 3695658].
234 Kelly JV, Hellinger FJ. Heart disease and hospital deaths: an empirical study. Health Serv Res. Aug. 1987;22(3):369-95. [pmid: 3500151].
235 Luft HS, Hunt SS, Maerki SC. The volume-outcome relationship: practice-makes-perfect or selective-referral patterns?. Health Serv Res. Jun. 1987;22(2):157-82. [pmid: 3112042].
236 Rosenfeld K, Luft HS, Garnick DW, et al. Changes in patient characteristics and surgical outcomes for coronary artery bypass surgery 1972-82. Am J Public Health. Apr. 1987;77(4):498-500. [pmid: 3493710].
237 Showstack JA, Rosenfeld KE, Garnick DW, et al. Association of volume with outcome of coronary artery bypass graft surgery. Scheduled vs nonscheduled operations. JAMA. Feb 13. 1987;257(6):785-9. [pmid: 3492614].
238 Williams SV, Nash DB, Goldfarb N. Differences in mortality from coronary artery bypass graft surgery at five teaching hospitals. JAMA. Aug 14. 1991;266(6):810-5. [pmid: 1907670].
239 Zelen J, Bilfinger TV, Anagnostopoulos CE. Coronary artery bypass grafting. The relationship of surgical volume, hospital location, and outcome. N Y State J Med. Jul. 1991;91(7):290-2. [pmid: 1876313].
240 Farley DE, Ozminkowski RJ. Volume-outcome relationships and in-hospital mortality: the effect of changes in volume over time. Med Care. Jan. 1992;30(1):77-94. [pmid: 1729589].
241 Grumbach K, Anderson GM, Luft HS, et al. Regionalization of cardiac surgery in the United States and Canada. Geographic access, choice, and outcomes. JAMA. Oct 25. 1995;274(16):1282-8. [pmid: 7563533].
242 Shroyer AL, Marshall G, Warner BA, et al. No continuous relationship between Veterans Affairs hospital coronary artery bypass grafting surgical volume and operative mortality. Ann Thorac Surg. Jan. 1996;61(1):17-20. [pmid: 8561546].
243 Ghali WA, Quan H, Brant R. Coronary artery bypass grafting in Canada: hospital mortality rates, 1992-1995. CMAJ. Oct 20. 1998;159(8):926-30. [pmid: 9834717].
244 Brown PP, Mack MJ, Simon AW, et al. Comparing clinical outcomes in high-volume and low-volume off-pump coronary bypass operation programs. Ann Thorac Surg. Sep. 2001;72(3):S1009-15. [pmid: 11565717].
245 Nallamothu BK, Saint S, Ramsey SD, et al. The role of hospital volume in coronary artery bypass grafting: is more always better?. J Am Coll Cardiol. Dec. 2001;38(7):1923-30. [pmid: 11738295].
246 Rathore SS, Epstein AJ, Volpp KG, et al. Hospital coronary artery bypass graft surgery volume and patient mortality, 1998-2000. Ann Surg. Jan. 2004;239(1):110-7. [pmid: 14685108].
247 Ritchie JL, Phillips KA, Luft HS. Coronary angioplasty. Statewide experience in California. Circulation. Dec. 1993;88(6):2735-43. [pmid: 8252686].
248 Kimmel SE, Berlin JA, Laskey WK. The relationship between coronary angioplasty procedure volume and major complications. JAMA. Oct 11. 1995;274(14):1137-42. [pmid: 7563484].
249 Phillips KA, Luft HS, Ritchie JL. The association of hospital volumes of percutaneous transluminal coronary angioplasty with adverse outcomes, length of stay, and charges in California. Med Care. May. 1995;33(5):502-14. [pmid: 7739274].
250 Ellis SG, Omoigui N, Bittl JA, et al. Analysis and comparison of operator-specific outcomes in interventional cardiology. From a multicenter database of 4860 quality-controlled procedures. Circulation. Feb 1. 1996;93(3):431-9. [pmid: 8565159].
251 Ellis SG, Weintraub W, Holmes D, et al. Relation of operator volume and experience to procedural outcome of percutaneous coronary revascularization at hospitals with high interventional volumes. Circulation. Jun 3. 1997;95(11):2479-84. [pmid: 9184577].
252 Kastrati A, Neumann FJ, Schomig A. Operator volume and outcome of patients undergoing coronary stent placement. J Am Coll Cardiol. Oct. 1998;32(4):970-6. [pmid: 9768719].
253 Maynard C, Every NR, Chapko MK, et al. Institutional volumes and coronary angioplasty outcomes before and after the introduction of stenting. Eff Clin Pract. May–Jun. 1999;2(3):108-13. [pmid: 10538258].
254 Ritchie JL, Maynard C, Chapko MK, et al. Association between percutaneous transluminal coronary angioplasty volumes and outcomes in the Healthcare Cost and Utilization Project 1993-1994. Am J Cardiol. Feb 15. 1999;83(4):493-7. [pmid: 10073849].
255 Ho V. Evolution of the volume-outcome relation for hospitals performing coronary angioplasty. Circulation. Apr 18. 2000;101(15):1806-11. [pmid: 10769281].
256 Ho V. Learning and the evolution of medical technologies: the diffusion of coronary angioplasty. J Health Econ. Sep. 2002;21(5):873-85. [pmid: 12349886].
257 Kimmel SE, Sauer WH, Brensinger C, et al. Relationship between coronary angioplasty laboratory volume and outcomes after hospital discharge. Am Heart J. May. 2002;143(5):833-40. [pmid: 12040345].
258 Watanabe CT, Maynard C, Ritchie JL. Short-term outcomes after percutaneous coronary intervention: effects of stenting and institutional volume shifts. Am Heart J. Aug. 2002;144(2):310-4. [pmid: 12177650].
259 Brown DL. Analysis of the institutional volume-outcome relations for balloon angioplasty and stenting in the stent era in California. Am Heart J. Dec. 2003;146(6):1071-6. [pmid: 14661001].
260 Harjai KJ, Berman AD, Grines CL, et al. Impact of interventionalist volume, experience, and board certification on coronary angioplasty outcomes in the era of stenting. Am J Cardiol. Aug 15. 2004;94(4):421-6. [pmid: 15325922].
261 Moscucci M, Share D, Smith D, et al. Relationship between operator volume and adverse outcome in contemporary percutaneous coronary intervention practice: an analysis of a quality-controlled multicenter percutaneous coronary intervention clinical database. J Am Coll Cardiol. Aug 16. 2005;46(4):625-32. [pmid: 16098426].
262 Birkmeyer JD, Finlayson EV, Birkmeyer CM. Volume standards for high-risk surgical procedures: potential benefits of the Leapfrog initiative. Surgery. Sep. 2001;130(3):415-22. [pmid: 11562662].