# Results

## Introduction

This chapter presents the results of the literature searches, followed by results for each key question (KQ). KQ 1 presents evidence on mental and behavioral health, caregiver-child relationship, and developmental outcomes (no study addressed school functioning). KQ 2 presents evidence for outcomes relevant to the child welfare system: safety, placement stability, and permanency. KQ 3 (on intervention characteristics) and KQ 4 (on subgroups of the population) are cross-cutting questions that draw upon available evidence from KQ 1 and KQ 2. KQ 5 presents evidence on how interventions compare on treatment engagement (that is, motivation or readiness to engage in an intervention and treatment adherence). KQ 6 presents evidence on harms.

At the start of each KQ section, we describe how the section is organized; however, all KQ sections include the following elements:

- Key points and the strength of evidence (SOE) grade for each outcome relevant to the KQ in question, referring to the specific constructs measured to which the evidence pertains.
- A detailed synthesis which briefly summarizes the results of each comparison and also provides: (a) a table describing the study characteristics of each trial, including the risk of bias rating (see Risk of Bias Assessment in the Methods chapter); (b) a results table presenting the between-group differences in changes and differences at study endpoint with benefit denoted using a greater sign (“>“) and statistically significant within-group changes for each study denoted as improvement (“+”), detriment (“−”), or nonsignificant change (“ns”) for studies that provided these data; and (c) a table presenting the SOE by grading domain (risk of bias, consistency, directness, and precision).
- A summary table presenting overall findings for each outcome relevant to the KQ in question. We order the results in the summary tables alphabetically.
- We report magnitude of effect data provided by authors in the studies reviewed. We did not perform additional effect size calculations with the exception of one study that provided effect sizes in the form of relative risk reduction without the significance level.130 Effect sizes were not reported universally across all studies included in this review and confidence intervals and mean differences were rarely reported.

## Results of the Literature Searches

The results of literature searches are presented in Figure 2. Our initial universe of articles (unduplicated) totaled 6,282; we excluded 5,782 at the title and abstract review stage. For the 497 articles reviewed at the full-text stage, we eliminated 428 for a variety of reasons. We recorded the reason for excluding full-text publications; Appendix C lists these, organized by reason for exclusion. The most common reasons for exclusion at the full-text level were (1) the study included children outside of the target age range (0 to 14) or the study’s focus was on children at risk for maltreatment based on sociodemographic characteristics (e.g., living in poverty, first-time parents) (wrong population), (2) systems- or service-delivery level approaches (wrong intervention), or (3) a lack of a comparison group (wrong comparison). After assessing risk of bias for 69 included articles (before data abstraction), we eliminated 16 articles including outcomes that we rated high risk of bias. This left a total of 25 studies, reported in 53 articles, which included outcomes that were assessed as either medium or low risk of bias. The majority (N=23) of these studies were randomized controlled trials (RCTs), one was a nonrandomized controlled trial, and one was a nonconcurrent cohort study.

Figure 2 Results of literature searches on interventions for child maltreatment

* we were unable to access the FT of three articles

Abbreviations: I/E = inclusion/exclusion; NCT = nonrandomized controlled trial; RCT – randomized controlled trial

From: Moher D, Liberati A, Tetzlaff J, Altman DG, The PRISMA Group (2009). Preferred Reporting Items for Systematic Reviews and Meta-Analyses: The PRISMA Statement. PLoS Med 6(6): e1000097. doi:10.1371/journal.pmed1000097

For more information, visit www.prisma-statement.org.

Figure 2. PRISMA. Figure 2 depicts the results of the literature search strategy. After duplicated were removed, 6,282 records remained. During title and abstract review, 5,782 records were excluded. We were unable to access three full text articles, leaving 497 articles for full text review. Of these, 428 were excluded because they did not match PICOTS elements defining the scope of the review or were rated high risk of bias (n = 16). Fifty-three articles (24 trials and 1 cohort study) were included in the qualitative analysis.

## Overall Description of Studies

### Population

Populations targeted by the studies in this comparative evidence review included children ranging from 0 to 14 years old who had been exposed to maltreatment or were involved with the child welfare system. Many of the studies empirically assess an intervention within a population subgroup. Population subgroups include children in particular age groups (early childhood, middle childhood, or early adolescence), children exposed to specific types of maltreatment (neglect, physical or sexual abuse), or children with trauma symptoms or other special health care needs. Caregiver subgroups were also particularly salient (i.e., trials that assessed interventions for the biological [maltreating] parent or targeting foster parents).

### Intervention

We identified 20 unique interventions (Table 10) that were assessed with the included population. We categorized the interventions as parenting interventions (N=9), trauma-focused treatments (N=6), or enhanced foster care interventions (N=5). One intervention was designed to promote treatment engagement and retention (N=1). Each of the interventions included in this review is described in Tables 1, 2, and 3 in the Introduction. Many of the interventions included components directed at the biological or foster parent, either with or without the child’s participation. In addition to the parenting interventions, 3 (57%) of the trauma-focused and 4 (80%) of the enhanced foster care interventions include a caregiver component. Only 3 interventions were solely child-focused.

Table 10 Total number of studies (trials and cohort studies)

Intervention | Trials | KQ 1 | KQ 2 | KQ 3 | KQ 4 | KQ 5 | KQ 6
Parenting Interventions | Total = 13 | 10 | 5 | 2 | 10 | - | -
Attachment and Biobehavioral Catch-up | 3 | 3 | - | 2 | 3 | - | -
Attachment-based Intervention | 1 | 1 | - | - | 1 | - | -
Child-Parent Psychotherapy | 2 | 2 | - | - | 2 | - | -
Incredible Years CoParenting Adaptation | 1 | 1 | - | - | - | - | -
Keeping Foster and Kinship Parents Trained and Supported | 1 | 1 | 1 | - | 1 | - | -
Nurse-Home Visitation | 1 | 1 | 1 | - | - | - | -
Parent-Child Interaction Therapy Adaptation Package | 2 | - | 2 | - | 2 | - | -
SafeCare | 1 | - | 1 | - | 1 | - | -
Videotape Intervention | 1 | 1 | - | - | - | - | -
Trauma-Focused Treatments | Total = 7 | 7 | - | 1 | 5 | - | 1
Combined Parent-Child Cognitive Behavioral Therapy | 1 | 1 | - | - | 1 | - | -
Eye Movement Desensitization and Reprocessing | 1 | 1 | - | - | - | - | -
Group Psychotherapy for Sexually-Abused Girls | 1 | 1 | - | - | 1 | - | -
Group Treatment Program for Sexual Abuse | 1 | 1 | - | - | 1 | - | -
Trauma-Focused Cognitive Behavioral Therapy | 2 | 2 | - | 1 | 2 | - | 1
Trauma-Focused Cognitive Behavioral Therapy Group Adaptation | 1 | 1 | - | - | - | - | -
Enhanced Foster Care Interventions | Total = 5 | 4 | 4 | - | 5 | - | -
Bucharest Early Intervention Project | 1 | 1 | - | - | 1 | - | -
Fostering Healthy Futures | 1 | 1 | 1 | - | 1 | - | -
Middle School Success | 1 | 1 | 1 | - | 1
Multidimensional Treatment Foster Care-Preschoolers | 1 | 1 | 1 | - | 1 | - | -
New Orleans Intervention | 1^a^ | - | 1^a^ | - | 1^a^ | - | -
Treatment Engagement Interventions | Total = 1 | - | - | - | - | 1 | -
Motivational Intervention | 1^b^ | - | - | - | - | 1 | -
Total Unique Studies | 25

a Cohort study

b Motivational Intervention was assessed as part of a trial testing the Parent-Child Interaction Therapy Adaptation Package.

Abbreviation: KQ = key question

### Comparator

The most common comparator in the included studies was usual care (N=13 studies), followed by active (N=10 trials) and inactive (N=4 trials) control groups. We categorized the active comparators as either interventions representative of conventional practices in the field (family, child-centered, or supportive group therapy) (used in 3 trials), or derived approaches. The derived comparators were either (a) modified versions of an intervention model in which the degree of fidelity to the original model was not specified by the authors (used in 5 trials), or (b) developed by the study authors to control for nonspecific aspects of the experimental intervention (2 trials).

### Outcomes

Of the unique outcome domains reported in KQ 1, the most commonly assessed was children’s mental and behavioral health (N=20 trials), followed by healthy caregiver-child relationship outcomes (N= 15 trials). Very few trials reported developmental outcomes such as cognitive or language development (N=3 trials) and none reported on school-based functioning. Fewer trials reported child welfare (KQ2) outcomes. Five examined safety (i.e., maltreatment recurrence), four examined placement stability, and four examined permanency outcomes. Treatment engagement (KQ5) was the focus of only one trial, for one of the included interventions. Adverse events (KQ6) were sparsely reported, with active surveillance of harms described for only one trial.

No new outcomes are reported in KQs 3 or 4 as these questions summarize the evidence for KQs 1 and 2 by intervention characteristic (KQ 3) and population subgroup (KQ 4).

### Timing

Most studies assessed outcomes immediately postintervention or shortly thereafter. Few studies assessed long-term outcomes.

### Setting

The vast majority of the studies were conducted in the United States. Several studies were conducted in other high-income countries, specifically Canada (N=2) and the United Kingdom (N=1). Two studies were conducted in countries with substantial cultural differences compared with the United States, specifically Iran (N=1) and Romania (N=1).

## Key Question 1 Comparative Effectiveness of Interventions for Improving Child Well-Being Outcomes

### Organization

We organize key question (KQ) 1 by intervention type (parenting, trauma-focused, and enhanced foster care approaches), as described in Tables 1 through 3. We begin this section with a description of included studies and an accompanying table presenting the number of trials and articles investigating child welfare outcomes by intervention type. Next, for each subsection, we begin with an overview of key features of the evidence base for the intervention type and then present the findings for each intervention. Findings include very brief key points presenting the main findings for KQ outcomes and the corresponding strength of evidence (SOE) grade. Immediately following the key points is a detailed synthesis of the findings for each intervention, providing information about study characteristics, the specific results (including magnitude of effect, if provided by study authors), and the SOE by grading domain (risk of bias, consistency, directness, and precision). Please refer to the Strength of Evidence Grading section in the Methods chapter for further detail about the SOE grading criteria. Finally, we close each section with a summary table presenting overall findings for each outcome relevant to the KQ in question, organized alphabetically by intervention name.

We remind the reader that benefit is denoted in the results tables using a greater (“>“) sign (e.g., Group 1 > Group 2). Also, the results tables present within-group changes denoted as improvement (“+”), detriment (“−”), or nonsignificant change (“ns”) for studies that provided these data.

### Parenting Interventions

#### Description of Included Studies

Table 11 presents the 10 trials (15 articles) evaluating parenting interventions included in KQ 1.^77–83,85–89,91,93,101^

Table 11 Numbers of trials and articles investigating child well-being outcomes: Parenting interventions

Intervention | Trials
Attachment and Biobehavioral Catch-up77–83,85 | 3^a^
Attachment-based Intervention86 | 1
Child-Parent Psychotherapy87,88 | 2
Incredible Years CoParenting Adaptation89 | 1
Keeping Foster and Kinship Parents Trained and Supported91 | 1
Nurse Home Visitation Intervention93 | 1
Videotape Intervention101 | 1
Total | 10

a Reported in 8 articles.

Below we provide an overview of the key features in the body of evidence for parenting interventions.

- All 10 trials were randomized controlled trials (RCTs).
- Two studies met the criteria for an effectiveness trial.91,93
- Five trials targeted maltreating parents81–83,86–88,93
- One trial targeted the nonoffending mother of children undergoing forensic evaluation for sexual abuse.101
- Three trials targeted foster parents.77–80,85,91
- One trial was directed at foster and biological parents together.89
- Five trials focused on early childhood.77–79,81–83,85–88
- Six trials compared the experimental intervention with a usual care condition.86–89,91,93
- One trial used a wait-list control group.80
- Four trials employed active control group comparators that were derived approaches.77–79,81–83,85,87,88
- Eight trials reported mental and behavioral health outcomes.77,78,80,82,83,86,89,91,93,101
- Nine of 10 trials reported caregiver-child relationship outcomes.11–83,85–89,91,93
  ○ Seven trials reported on indirect indicators of the caregiver-child relationship (e.g., caregiver attitudes towards parenting; parenting practices, including the use of positive discipline; caregiver report of child attachment behavior; caregiver stress and emotional distress).80,86–89,91,93,101
  ○ Four trials reported on direct indicators (i.e., objective observational assessment) of parent interactional behavior or of child attachment behavior.79,81,86,87
- One trial assessed developmental outcomes.85
- No trials assessed school-based functioning outcomes.

#### Attachment and Biobehavioral Catch-up

We identified two RCTs, reported in 8 articles, comparing Attachment and Biobehavioral Catch-up (ABC), a low-intensity home-based relational intervention, with an active control. The comparator was a home-based intervention focused on children’s cognitive and linguistic development derived from the Abecedarian early intervention program.174,175 We also identified one RCT, reported in 1 article, comparing ABC with wait-list control (Table 12). One trial targeted foster parents caring for infants and toddlers77–79,85 and the other targeted biological parents.81–83 The ABC trial with a wait-list control targeted foster parents caring for children birth to 6 years.80

Table 12 Attachment and biobehavioral catch-up: Study characteristics

First Author et al., Year Country | Sample Description (Age Group) | Study Design and Duration | Comparison Groups | Baseline N | Risk of Bias
Dozier et al., 2006;^77^ Dozier et al., 2008;^78^ Dozier et al., 2009;^79^ Lewis-Morrarty et al, 2012^85^ United States | Foster parents and young children in their care (3.6 to 39.4 months) | RCT 14 weeks^a^ | G1: ABC G2: Active control | G1: 46 G2: 47 Overall N=93^a^ | Medium
Bernard et al. 2012;^81^ Dozier et al., unpublished study A;83 Dozier et al., unpublished study B82 United States | Parents involved with CPS (diversion program) and their young children (1.7 to 21.4 months; mean = 10.1 (6.0)) | RCT 14 weeks^a^ | G1: ABC G2: Active control | G1: 60 G2: 60 Overall N=120^b^ | Medium
Sprang et al., 2009^80^ United States | Foster parents and young children in their care (0 to 6 years; mean age = 42.5 months) | RCT 10 weeks | G1: ABC G2: Wait list | G1: 29 G2: 29 | Medium

a Dozier et al., 2009: timing of assessment not specified and N = 46; Dozier et al., 2008: timing of assessment not specified and N = 60; Lewis-Morrarty et al., 2012: follow-up assessment at child age 4 to 6 years and N = 37.

b Dozier et al. unpublished A: N = 114.

Abbreviations: ABC = Attachment and Biobehavioral Catch-up; CPS = Child Protective Services; G = group; N = number; RCT = randomized controlled trial.

##### Key Points

- Mental and behavioral health:
  ○ Compared with an active control, children whose caregivers participated in ABC exhibited significantly more normative diurnal cortisol regulation (foster and biological parents) and less negative emotionality (biological parents); however, no significant difference in efficacy was found for ABC for parent report of child behavioral problems (low SOE of benefit).77,78,82,83
  ○ Compared with a wait-list control, foster parents who participated in ABC reported significantly greater improvement in child internalizing and externalizing behavior (low SOE of benefit).80
- Healthy caregiver-child relationship:
  ○ Compared with an active control, children whose caregivers (foster or biological) participated in ABC exhibited significantly more positive attachment behaviors (low SOE of benefit).79,81
  ○ Compared with a wait-list control, foster parents who participated in ABC had greater improvement in parent attitudes and greater reductions in parent stress (low SOE of benefit).80
- Healthy development:
  ○ Compared with an active control, children whose foster parents participated in ABC exhibited higher levels of cognitive functioning (low SOE of benefit).85

##### Detailed Synthesis

Table 13 presents the results for the two ABC trials; additional study details are provided in the evidence tables (Appendix E).77–79,85 An initial article reporting findings from the first trial, targeting foster parents, examined children’s diurnal production of cortisol and parent report of children’s problem behaviors (child age 3 months to approximately 3 years). The authors measured cortisol, as neuroendocrine dysregulation is one of the primary targets of ABC (the other is the caregiver-child attachment relationship). Cortisol is an indicator of neurobiological response to stress and serves as a proxy indicator of regulation and functioning of the hypothalamic-pituitary-adrenal (HPA) axis, itself activated by physical and psychological stressors. Children in the ABC group exhibited more normative cortisol regulation than children in the control condition, although the timing of assessment was not specified and baseline cortisol measures were not reported. No significant differences were found for parent report of children’s behavioral problems.

Table 13 Results: Attachment and biobehavioral catch-up versus active control

First Author et al., Year | Comparison Groups | Mental and Behavioral Health | Healthy Caregiver-Child Relationship | Healthy Development
Dozier et al, 2006^77^ | G1: ABC G2: Active control | Lower cortisol levels G1>G2, p<0.001 Behavioral problems (parent daily report) No differences between G1 and G2, p=0.71 | NA | NA
Dozier et al, 2008^78^ | G1: ABC G2: Active control | Lower cortisol levels G1>G2, p<0.05 Change in cortisol before and after strange situation No differences between G1 and G2, p=NS (NR) | NA | NA
Dozier et al, 2009^79^ | G1: ABC G2: Active control | NA | Fewer reports of avoidant attachment behavior (parent attachment diary) G1>G2, p=0.030 Secure attachment behavior (parent attachment diary) No differences between G1 and G2, p=0.379 | NA
Lewis-Morrarty et al., in press85 | G1: ABC G2: Active control | NA | NA | Cognitive flexibility (dimensional change card sort) G1>G2, p=.008 Theory of mind (penny hiding task) G1>G2, p=.01
Bernard et al., 2012^81^ | G1: ABC G2: Active control | NA | Decreased proportion with disorganized attachment (strange situation) G1>G2, p < .01 Increased proportion with secure attachment (strange situation) G1>G2, p<.05
Dozier et al., unpublished A83 | G1: ABC G2: Active control | Negative emotional expressivity (the tool task) G1>G2, p<.05 | NA | NA
Dozier et al., unpublished B82 | G1: ABC G2: Active control | More normalized patterns of cortisol production G1>G2, p=sig (NR) | NA | NA

Note: Greater comparative benefit is denoted using a greater (“>“) sign.

Abbreviations: ABC = Attachment and Biobehavioral Catch-up; G = group; N = number; NR = not reported; NS = not specified; RCT = randomized controlled trial.

A second article reporting findings from the trial with foster parents examined cortisol outcomes on a subset of children, age 15 to 24 months.78 As in the previous article, children who participated in ABC exhibited more normative patterns of cortisol regulation compared with the control condition.78 The authors also examined changes in cortisol levels after a stressful separation-reunion procedure but found no significant differences for cortisol values in response to the stressful procedure by study arm. A third article79 reporting findings from this same trial examined parent reports of children’s attachment behavior. Foster parents who participated reported that children exhibited less avoidant attachment behavior compared with the active control; however, there were no significant differences in efficacy of the intervention on children’s secure attachment behavior. Finally, a fourth study examined cognitive development outcomes at age 4 to 6 years among children who had participated in the ABC intervention compared with the control group. This study found that children in the ABC condition exhibited significantly greater cognitive flexibility and theory of mind skills compared with children who had participated in the control condition.85

Three articles report findings from a second trial which used the same comparator as in the previously described trial but targeted biological parents. In one paper, the authors found a significantly lower proportion of disorganized attachments and increased proportion of secure attachment among children in the ABC group following the intervention.81 Another article found that ABC children expressed less angry feelings following a series of challenging tasks.83 In a third paper, the authors indicated that ABC children exhibited significantly more normalized patterns of cortisol production than control children.82

Table 14 presents the results of the ABC trial with foster parents compared with wait-list control; additional study details are provided in the evidence tables (Appendix E).80 The authors describe the study as combining elements of efficacy and effectiveness studies by applying specific components of an RCT to a clinic-based setting with a “naturally occurring treatment-seeking population.”80^,p82^ The study explicitly focused on children who had experienced severe maltreatment resulting in termination of parental rights and disruptions in their primary attachment relationships. An eligibility criterion for inclusion in the study was treatment readiness (families were prescreened for readiness prior to randomization). The authors examined child internalizing and externalizing behavior problems, parenting attitudes reflective of child abuse potential, and parenting stress with widely used and highly validated measures. A detailed summary of the results is provided in Appendix E. Compared with foster parents in the wait-list condition, participants in ABC reported significant improvements in child internalizing and externalizing problems (low and medium effect sizes, respectively) and reduction in negative parenting attitudes, practices associated with child abuse (large effect size), and parenting stress (medium effect size).

Table 14 Results: Attachment and biobehavioral catch-up versus wait list

First Author et al., Year | Comparison Groups | Mental and Behavioral Health | Healthy Caregiver-Child Relationship
Sprang et al., 2009^80,a^ | G1: ABC G2: Wait list | Improvements in internalizing behavior (Child Behavior Checklist-Internalizing subscale) G1^+^>G2^+^, p=0.01, partial eta squared =0.436 Improvements in externalizing behavior (Child Behavior Checklist-Externalizing subscale) G1^+^>G2^+^, p=0.001, partial eta squared =0.511 | Improvements in self-reported risk factors for child abuse (Child Abuse Potential Inventory) G1^+^> G2^+^, p=0.001, partial eta squared =0.791 Improvements in parent stress (Parent Stress Inventory) G1^+^> G2^+^, p=0.01, partial eta squared =0.59

a intention-to-treat (ITT) analysis.

Note:Greater comparative benefit is denoted using a greater (“>“) sign. We use the interpretation of partial eta squared effect sizes provided in Sprang et al., 2009.

Abbreviations: ABC = Attachment and Biobehavioral Catch-up; G = group;

Although the ABC trials yielded promising results, we graded the SOE as low for both mental and behavioral health and caregiver-child relationship outcomes due to the presence of only two trials (Table 15). As explained previously (see Methods), when evidence supporting an intervention is sparse (i.e., ≤2 studies) the body of evidence is graded as low. We graded the SOE in the study comparing ABC with wait-list control as low due to the presence of the single, small, quasi-effectiveness study.

Table 15 Detailed strength of evidence grading table: Attachment and biobehavioral catch-up

Intervention and Comparator | Outcome | Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | SOE Grade; Magnitude of Effect
ABC vs. Active Control^a^ | Mental and behavioral health | 2 RCTs77,78,82,83; 213 | M | Consistent | Direct | Precise | Low; NR
ABC vs. Active Control^a^ | Healthy caregiver-child relationship | 2 RCTs79,81; 166 | M | Unknown, single study | Indirect | Precise | Low; NR
ABC vs. Active Control^a^ | Healthy development | 1 RCT85; 37 | M | Unknown, single study | Indirect | Precise | Low; NR
ABC vs. Wait list | Mental and behavioral health | 1 RCT80; 58 | M | Unknown, single study | Direct | Precise | Low; medium (partial eta squared=0.436 or 0.511)
ABC vs. Wait list | Healthy caregiver-child relationship | 1 RCT80; 58 | M | Unknown, single study | Indirect | Precise | Low; medium or large (partial eta squared=0.59 or 0.791)

a Active comparator is an approach derived from an intervention wherein the degree to which core components of the original model are implemented is unclear and/or core components are omitted or substantively modified.

Note: All results are G1>G2 unless otherwise noted. For estimation of the magnitude of effect, we include only the statistically significant (p<0.05) effect sizes provided by study authors and do not calculate effect sizes as part of our analysis. We use the interpretation of partial eta squared effect sizes provided in Sprang et al., 2009.^80^ We include an effect size range when more than two effect sizes are reported.

Abbreviations: M = medium; NR = not reported; RCT = randomized controlled trial; SOE = strength of evidence.

#### Attachment-Based Intervention

We identified one RCT comparing another low-intensity, home-based intervention with usual care, referred to here as an “Attachment-based Intervention”86 (Table 16). The authors describe this intervention as being loosely based on Attachment and Biohavioral Catch-up along with other attachment-oriented approaches described in the literature. The study spanned infants to preschool-aged children and their biological mothers or fathers. The study assessed children’s internalizing and externalizing behavior, maternal sensitivity, and attachment behavior using direct measures.

Table 16 Attachment-based intervention: Study characteristics

First Author et al., Year Country | Sample Description (Age Group) | Study Design and Duration | Comparison Groups | Baseline N | Risk of Bias
Moss et al., 2011^86^ Canada | Maltreated children ages 12 to 71 months and either their biological mother or father | RCT 8 weeks | G1: Attachment-based Intervention G2: Usual care | G1: 40 G2: 39 Overall N=79 | Medium

Abbreviations: G = group; N = number; RCT = randomized controlled trial.

##### Key Points

- Mental and behavioral health: There were no significant differences in efficacy of the intervention on child internalizing or externalizing behavior (insufficient SOE).86
- Healthy caregiver-child relationship: Participants in the Attachment-based Intervention demonstrated significant improvements in maternal sensitivity and secure attachment behavior compared with usual care (low SOE of benefit).86

##### Detailed Synthesis

Table 17 presents the results for the one RCT evaluating this intervention; additional study details are provided in the evidence tables. The study found no statistically significant difference in child internalizing or externalizing behavior problems by study arm. However, the intervention did demonstrate efficacy in maternal sensitivity and child attachment outcomes, reporting small to medium effect sizes.

Table 17 Results: Attachment-based intervention versus usual care

First Author et al., Year | Comparison Groups | Mental and Behavioral Health | Healthy Caregiver-Child Relationship
Moss et al., 2011^86^ | G1: Attachment-based Intervention G2: Usual care | Improvement in internalizing problems (Child Behavior Checklist-Internalizing subscale) No difference between G1 and G2, p=NS Improvement in externalizing problems (Child Behavior Checklist -Externalizing subscale) No difference between G1 and G2, p=NS | Improvements in maternal sensitivity (Maternal Behavior Q-set) G1>G2, p<0.05, d=0.47 Proportionally more changes from insecure to secure attachments (strange situation) G1>G2, p<0.05, r=0.36 Proportionally more changes from disorganized to organized attachments (strange situation) G1>G2, p<0.05, r=0.37

Note: Greater comparative benefit is denoted using a greater (“>“) sign. Cohen’s d effect size index of the difference between groups means: 0.20 = small; 0.50 = medium; 0.80 = large. The correlational coefficient r is an effect size index measure of association; we refer to Cohen’s suggested guidelines for interpreting magnitude of effect: 0.10 = small; 0.30 = medium, 0.50 = large.176

Abbreviations: G = group; NS = not significant

We graded the SOE as insufficient for mental and behavioral health outcomes due to lack of statistical significance (Table 18). We graded the SOE as low for caregiver-child relationship outcomes because of the presence of a single study.

Table 18 Detailed strength of evidence grading table: Attachment-based intervention

Intervention and Comparator | Outcome | Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | SOE Grade; Magnitude of Effect
Attachment-based Intervention vs. Usual Care | Mental and behavioral health | 1 RCT;86 79 | M | Unknown, single study | Direct | Imprecise | Insufficient
Attachment-based Intervention vs. Usual Care | Healthy caregiver-child relationship | 1 RCT,86 79 | M | Unknown, single study | Direct | Precise | Low; small to medium (d=0.47, r=0.36 or 0.37)

a All results are G1>G2 unless otherwise noted. For estimation of the magnitude of effect, we include only the statistically significant (p<0.05) effect sizes provided by study authors and do not calculate effect sizes as part of our analysis. Interpretation of the effect size as small, medium, or large is defined as: Cohen’s d = 0.20, 0.50, and 0.80 and correlation coefficient r = 0.10, 0.30, and 0.50.^176^

Abbreviations: M = medium; RCT = randomized controlled trial; SOE = strength of evidence.

#### Child-Parent Psychotherapy

We identified two RCTs that compared CPP, a high-intensity home-based intervention, with an active control and also with usual care (Table 19).87,88 One RCT targeted 12-month-old infants and mothers; the other trial targeted 4-year-old children and mothers. The results of these two RCTs pertain to Cicchetti and colleagues’ variant of CPP. Both studies used the same active comparator, a psychoeducational intervention derived from Olds and colleagues’ nurse home visitation model.94

Table 19 Child-parent psychotherapy: Study characteristics

First Author et al., Year Country | Sample Description (Age Group) | Study Design and Duration | Comparison Groups | Baseline N | Risk of Bias
Toth et al., 2002^88^ United States | Children ages 4 years in maltreating families | RCT 1 year (child age 5 years) | G1: CPP G2: Active control G3: Usual care | G1: 23 G2: 34 G3: 30 Overall N=87 | Medium
Cicchetti et al., 2006^87^ United States | Infants ages 12 months in maltreating families (mean age 13.1 months, SD=0.81) | RCT Approximately 13 months (child age 26 months) | G1: CPP G2: Active control G3: Usual care | G1: 53 G2: 49 G3: 35 Overall N=137 | Medium

Abbreviations: CPP = Child=Parent Psychotherapy; G = group; N = number; RCT = randomized controlled trial; SD = standard deviation.

##### Key Points

- Healthy caregiver-child relationship:
  ○ Preschool-age children who participated in CPP reported significantly fewer negative attachment representations compared with an active control88; however, for younger children, there were no significant differences in efficacy of the intervention on secure attachment behavior (insufficient SOE).87
  ○ When compared with usual care, infants who participated in CPP demonstrated significantly greater improvements in secure attachment behavior and preschool-age children reported significantly fewer negative attachment representations (low SOE of benefit).87,88

##### Detailed Synthesis

Based on the comparisons, we graded the SOE as insufficient for caregiver-child relationship outcomes due to nonsignificant findings in one study and inconsistent findings across the two studies (Table 20). Based on the inactive control comparisons, we graded the SOE as low for caregiver-child relationship outcomes due to the presence of only two trials, one of which used an indirect measure with most subscales showing nonsignificant differences.

Table 20 Results: Child-parent psychotherapy versus active control versus usual care

First Author et al., Year | Comparison Groups | Healthy Caregiver-Child Relationship
Toth et al, 2002^88^ | G1: CPP G2: Active control G3: Usual care | Greater decline in negative self-representations (MacArthur Story Stem Battery; Narrative Coding Manual-Rochester Revision) G1^+^>G2^ns^, p<0.01 G1^+^>G3^ns^, p<0.01 Trend towards greater increase in positive self-representations (MacArthur Story Stem Battery; Narrative Coding Manual-Rochester Revision) G1^+^ >G2^ns^, p<0.10, trend Trend towards greater decrease in maladaptive maternal representations (MacArthur Story Stem Battery; Narrative Coding Manual-Rochester Revision) G1^+^ >G3^ns^, p<0.10, trend Changes in adaptive maternal representation and false self-representation (MacArthur Story Stem Battery; Narrative Coding Manual-Rochester Revision) No differences between G1, G2, and G3 p=NR (ns)
Cicchetti et al, 2006^87^ | G1: CPP G2: Active control G3: Usual care | Higher rates of secure attachment^*^ (strange situation) G1>G3, p=<0.01 G2>G3, p=<0.01 both, h=1.16 to 1.39 No difference between G1 and G2 p=NR (ns) Higher rates of becoming securely attached^*^ (strange situation) G1>G3, p<0.01, h=1.34 G2>G3, p<0.01, h=1.16 No difference between G1 and G2, p=ns (NR) Lower rates of stable disorganized attachment^*^ (strange situation) G1>G3, p=0.01, h=0.83 G2>G3, p=0.025, h=0.64 No difference between G1 and G2, p=NR (ns) Change in maternal variables (Perceptions of Adult Attachment Scale; Maternal Behavior Q-Set; Adult-Adolescent Parenting Inventory; Social Support Behaviors Scale; Parenting Stress Index) No difference between G1 and G2; all p=ns (NR)

a intention-to-treat (ITT) analysis

Note: Greater comparative benefit is denoted using a greater (“>“) sign. Cohen’s h is an effect size index of the difference between proportions: 0.20 = small; 0.50 = medium; 0.80 = large.176

Abbreviations: CPP = Child-Parent Psychotherapy; G = group; NR = not reported; NS = not significant; SOE = strength of evidence.

Table 20 presents the results for the two CPP trials; additional study details are provided in the evidence tables (Appendix E). In the initial trial with preschool-age children and their mothers,88 the authors examined child mental representations of the child-parent attachment relationship. Children’s mental representations were predominantly maladaptive and negative at baseline across study conditions. The study found a significant decline in children’s negative mental representations in the CPP group compared with the active control. However, only trends or nonsignificant differences were found for the other subscales of the outcome measure. The authors did not report effect sizes. The other trial, conducted with mother-infant pairs,87 found no significant differences in efficacy of the intervention on children’s secure attachment by study arm; the nonsignificant difference was based on a direct measure of attachment. This study also found nonsignificant differences between the CPP and active control group on a direct measure of maternal sensitivity and several self-report measures of parenting (e.g., parenting attitudes, child-rearing stress, and social support).

In the Toth et al. trial with preschoolers,88 comparisons between CPP and the usual care study arm demonstrated significant improvement in children’s negative mental representations but, again, no other significant differences for the other subscales on the measure. The second study87 found significant improvements in secure child attachment in the CPP group compared with usual care, with predominantly large effect sizes. The study did not report comparisons between CPP and usual care on maternal measures.

Based on the comparisons, we graded the SOE as insufficient for caregiver-child relationship outcomes due to nonsignificant findings in one study and inconsistent findings across the two studies (Table 21). Based on the inactive control comparisons, we graded the SOE as low for caregiver-child relationship outcomes due to the presence of only two trials, one of which used an indirect measure with most subscales showing nonsignificant differences.

Table 21 Detailed strength of evidence grading table: Child-parent psychotherapy

Intervention and Comparator | Outcome | Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | SOE Grade; Magnitude of Effect
CPP vs. Active Control^a^ | Healthy caregiver-child relationship | 2 RCTs87,88; 159 | M | Inconsistent | Direct | Imprecise | Insufficient
CPP vs. Usual care | Healthy caregiver-child relationship | 2 RCTs87,88; 141 | M | Consistent | Direct | Precise | Low; medium to large (h=0.64 to 1.34)

a Active comparator is an approach derived from an intervention wherein the degree to which core components of the original model are implemented is unclear and/or core components are omitted or substantively modified.

Note: All results are G1>G2 unless otherwise noted. For estimation of the magnitude of effect, we include only the statistically significant (p<0.05) effect sizes provided by study authors and do not calculate effect sizes as part of our analysis. Interpretation of the effect size as small, medium, or large is defined as Cohen’s h = 0.20, 0.50, and 0.80.^176^ We include an effect size range when more than two effect sizes are reported.

Abbreviations: M = medium; RCT = randomized controlled trial; SOE = strength of evidence.

#### Incredible Years Adaptation

One RCT (Table 22) tested a co-parenting adaptation of the Incredible Years (IY) program, modified for use with biological and foster parent pairs and their children, age 3 to 10 years, compared with usual care.89 The number of sessions for standard IY varies by age of child; the number of sessions is 18 to 20 for parents of preschool-age children and 12 to 16 for parents of early school-age to preadolescent children. The included trial reduced the number of sessions to a lower intensity approach (12 sessions).

Table 22 Incredible years adaptation: Study characteristics

First Author et al., Year, Country | Sample Description (Age Group) | Study Design and Duration | Comparison Groups | Baseline N | Risk of Bias
Linares et al., 2006^89^; United States | Children in foster care, ages 3 to 10 years, and their biological and foster caregivers | RCT T1: 12 weeks post-baseline T2: 12 weeks after intervention end | G1: IY Adaptation G2: Usual care | G1: 80 caregivers (40 biological/foster pairs), 40 children G2: 48 parents (24 biological/foster pairs), 24 children Overall N=128 caregivers; 64 children | Medium

Abbreviations: G = group; N = number; RCT = randomized controlled trial; T = time.

##### Key Points

- Mental and behavioral health: There were no significant differences in efficacy of the IY Adaptation with parents (biological and foster) on child internalizing or externalizing problems (insufficient SOE).89
- Healthy caregiver-child relationship: Parents (biological and foster) who participated in the IY Adaptation reported a significant increase in the endorsement/use of positive parenting practices compared with usual care (low SOE of benefit).89

##### Detailed Synthesis

Table 23 presents the results of the study by Linares et al. testing an adaptation of IY89; additional study details are provided in the evidence tables (Appendix E). In this study, the authors examined changes in caregiver-reported discipline practices as well as caregiver and teacher report of child behavioral problems. The study found no significant differences for caregiver report or teacher report of child behavioral problems at postintervention or at 3-month followup. However, IY participants were significantly more likely to endorse positive discipline practices at both postintervention and follow-up (small to medium effect sizes), and a significant group difference emerged at followup in reporting of setting clear expectations for the child (medium effect size). The authors also reported that biological caregivers were significantly more likely to retain improvements in self-reported positive discipline practices through followup compared with foster parents. Regarding coparenting outcomes, the trial demonstrated a benefit for some but not all dimensions assessed at postintervention (flexibility and problem-solving but not mutual social support; small to medium effect sizes); however, these group differences faded by followup.

Table 23 Results: Incredible years adaptation versus usual care

First Author et al., Year | Comparison Groups | Mental and Behavioral Health | Healthy Caregiver-Child Relationship
Linares et al, 2006^89^ | G1: IY Adaptation G2: Usual care | Caregiver perception of child behavioral problems^*^ (Child Behavior Checklist -Externalizing score) No difference between groups at T1, T2, p=NS (NR) Caregiver perception of child behavioral and conduct problems^*^ (Eyberg Child Behavior Inventory) No difference between groups at T1, T2, p=NS (NR) Teacher report of disruptive classroom behaviors^*^(Sutter-Eyberg Student Behavior Inventory-Revised) No difference between groups at T1, T2, p=NS (NR) | Parenting behavior:^*^ Greater reporting of positive discipline strategies (Parenting Practices Interview Subscale) T1: G1>G2, p<0.05, d=0.40 T2: G1>G2, p<0.01, d=0.59 Appropriate discipline strategies (Parenting Practices Interview Subscale) T1, T2: No difference between groups, p=NS (NR) Greater reporting of setting clear expectations for child (Parenting Practices Interview Subscale) T1: No difference between groups, p=ns (NR) T2: G1>G2, p<0.05, d=0.54 Reporting of harsh discipline (Parenting Practices Interview Subscale) T1, T2: No difference between groups, p=NS (NR) Collaborative coparenting behavior:^*^ Greater reporting of flexibility (Family Functioning Style Subscale) T1: G1>G2, p<0.05, d=0.4 T2: No difference between groups, p=NS (NR) Greater reporting of mutual social support (Family Functioning Style Subscale) T1, T2: No difference between groups, p=NS (NR) Greater reporting of problem solving (Family Functioning Style Subscale) T1: G1>G2, p<0.05, d=0.52 T2, No difference between groups p=NS (NR) Total coparenting score (Family Functioning Style Subscale) T1: G1>G2, p<0.05, d=0.48 T2: No difference between groups, p=NS (NR)

Note: Greater comparative benefit is denoted using a greater (“>“) sign. Cohen’s d effect size index of the difference between groups means: 0.20 = small; 0.50 = medium; 0.80 = large.176

Abbreviations: G = group; IY = Incredible Years; NS = not sufficient; NR = not reported; T = time;

* =ITT analysis

For the trial testing an adaptation of IY compared with usual care, we graded the SOE as insufficient for mental and behavioral health outcomes due to nonsignificant findings and graded the SOE as low for caregiver-child relationship outcomes due to the presence of a single study (Table 24).

Table 24 Detailed strength of evidence grading table: Incredible years adaptation

Intervention and Comparator | Outcome | Studies; subjects | Risk of Bias | Consistency | Directness | Precision | SOE Grade; Magnitude of effect
IY Adaptation vs. Usual Care | Mental and behavioral health | 1;^89^ 64 | M | Unknown, single study | Direct | Imprecise | Insufficient
IY Adaptation vs. Usual Care | Healthy caregiver-child relationship | 1;^89^ 64 | M | Unknown, single study | Indirect | Imprecise | Low; small to medium (d=0.40 or 0.59)

Note: All results are G1>G2 unless otherwise noted. For estimation of the magnitude of effect, we include only the statistically significant (p<0.05) effect sizes provided by study authors and do not calculate effect sizes as part of our analysis. Interpretation of the effect size as small, medium, or large is defined as: Cohen’s d = 0.20, 0.50, and 0.80.^176^ When authors use Eta effect sizes we use the interpretation that the authors provide.177 We include an effect size range when more than two effect sizes are reported.

Abbreviations: M = medium; RCT = randomized controlled trial; SOE = strength of evidence.

#### Keeping Foster and Kinship Parents Trained and Supported

We identified one large effectiveness trial eligible for inclusion evaluating the low-intensity intervention, Keeping Foster and Kinship Parents Trained and Supported (KEEP), compared with usual care.91 The study targeted foster or kin caregivers of high-risk foster children ages 5 to 12 years (Table 25).

Table 25 Keeping foster and kinship parents trained and supported: Study characteristics

First Author et al., Year Country | Sample Description (Age Group) | Study Design and Duration | Comparison Groups | Baseline N | Risk of Bias
Chamberlain 2008^91^ United States | Foster children ages 5 to 12 years. Placed >30 days | RCT 5 months | G1: KEEP G2: Usual care | G1: 359 G2: 341 | Medium

Abbreviations: G = group; KEEP = Keeping Foster and Kinship Parents Trained and Supported; RCT = randomized controlled trial.

##### Key Points

- Mental and behavioral health: Participants in KEEP reported significantly greater improvement in child externalizing behavior compared with usual care (moderate SOE of benefit).91
- Healthy caregiver-child relationship: Participants in KEEP reported significantly increased use of positive discipline practices compared with usual care (moderate SOE of benefit).91

##### Detailed Synthesis

Table 26 presents the results of the KEEP RCT; additional study details are provided in the evidence tables (Appendix E). The authors examined parent daily report of child problem behaviors and use of positive reinforcement, assessed 5 months postbaseline. Proportion of positive reinforcement (R+) was calculated as a ratio of R+; discipline behaviors were aggregated from the parent report data and an intensive, 2-hour interview with the foster parent. Results controlled for baseline scores and indicated significant improvement in problem behaviors for the KEEP group relative to routine foster care, as well as an increase in positive reinforcement as a proportion of total foster parent discipline; the study reports small effect sizes for both outcomes. The intervention effect was greatest among foster parents who reported more than six child behavior problems at baseline.

Table 26 Results: Keeping foster and kinship parents trained and supported versus usual care

First Author et al., Year | Comparison Groups | Mental and Behavioral Health | Healthy Caregiver-Child Relationship
Chamberlain, 2008^91^ | G1: KEEP G2: Usual care | Improvement in problem behaviors at endpoint (parent daily report) G1>G2, p=NR (sig), d=0.26 | Increased proportion positive reinforcement at endpoint (parent daily report) G1>G2, p=NR (sig), d=0.29

Note: Greater comparative benefit is denoted using a greater (“>“) sign. Interpretation of the effect size as small, medium, or large is defined as: Cohen’s d = 0.20, 0.50, and 0.80^176^

Abbreviations: G = group; KEEP = Keeping Foster and Kinship Parents Trained and Supported; NR = not reported; sig = significant.

Although the body of evidence is limited to a single study for KEEP, we graded the SOE as moderate for both child mental and behavioral health outcomes and caregiver-child relationship outcomes due to the size of the study and because it was an effectiveness trial (Table 27).

Table 27 Detailed strength of evidence grading table: Keeping foster parents trained and supported

Intervention and Comparator | Outcome | Studies; subjects | Risk of Bias | Consistency | Directness | Precision | SOE Grade; Magnitude of effect
KEEP vs. Usual Care | Mental and behavioral health | 1 RCT91; 700 | M | Unknown, single study | Direct | Precise | Moderate; small (d=0.26)
KEEP vs. Usual Care | Healthy caregiver-child relationship | 1 RCT91; 700 | M | Unknown, single study | Indirect | Precise | Moderate; small (d=0.29)

Note: All results are G1>G2 unless otherwise noted. For estimation of the magnitude of effect, we include only the statistically significant (p<0.05) effect sizes provided by study authors and do not calculate effect sizes as part of our analysis. Interpretation of the effect size as small, medium, or large is defined as: Cohen’s d = 0.20, 0.50, and 0.80.^176^

Abbreviations: M = medium; RCT = randomized controlled trial; SOE = strength of evidence.

#### Nurse Home Visitation Intervention

We identified one effectiveness trial (RCT), reported in one article,93 comparing a high-intensity nurse home visitation intervention with usual care (Table 28). The intervention was loosely derived from Olds and colleagues’ model.178 The study targeted children 13 years and younger with a recent history of physical abuse or neglect and their mothers.

Table 28 Nurse home visitation intervention: Study characteristics

First Author et al., Year Country | Sample Description (Age Group) | Study Design and Duration | Comparison Groups | Baseline N | Risk of Bias
MacMillan et al., 2005^93^ Canada | Physically abused or neglected children ages 13 years and younger and their families | RCT T1: 1 year postbaseline T2: 2 years postbaseline T3: 3 years postbaseline | G1: Nurse home visitation G2: Usual care | G1: 89 G2: 74 Overall N=163 | Low

Abbreviations: N = number; RCT = randomized controlled trial; T = time.

##### Key Points

- Mental and behavioral health: There were no significant differences in efficacy of the intervention on child internalizing or externalizing behavior (insufficient SOE).93
- Healthy caregiver-child relationship: There were no significant differences in efficacy of the intervention parent attitudes, parenting practices associated with child abuse, family functioning, or the home environment (insufficient SOE).93

##### Detailed Synthesis

Table 29 presents the results of the nurse home visitation trial;93 additional study details are provided in the evidence tables (Appendix E). The authors examined child behavior problems, parental self-report of risk factors for child abuse, parental attitudes towards parenting, developmentally supportive home environment, and family functioning. No significant were found on any outcome across 3 assessment timepoints (up to 3 years postbaseline).

Table 29 Results: Nurse Home visitation intervention versus usual care

First Author et al., Year | Comparison Groups | Mental and Behavioral Health | Healthy Caregiver-Child Relationship
MacMillan et al., 2005^93^ | G1: Nurse home visitation G2: Usual care | Improvement in child behavioral problems^a^ (Revised Behavioral Problems Checklist) Subscales: [underlined: Attentional problems] No difference between G1 and G2, p=NS [underlined: Anxiety/withdrawal] No difference between G1 and G2, p=NS [underlined: Psychotic behavior] No difference between G1 and G2, p=NS [underlined: Conduct disorder symptoms] No difference between G1 and G2, p=NS [underlined: Socialized aggression] No difference between G1 and G2, p=NS [underlined: Excessive motor tension] No difference between G1 and G2, p=NS | Improvements in self-reported risk factors for child abuse^a^ (Child Abuse Potential Inventory) No difference between G1 and G2, p=NS Improvement in child rearing attitudes^*^ (Adult Adolescent Parenting Inventory) No difference between G1 and G2, p=NS Improvements in the quality of the child’s environment^*^ (HOME) No difference between G1 and G2, p=NS Improvements in family functioning^*^ (McMaster Family Functioning-General Functioning Scale) No difference between G1 and G2, p=NS

a intention-to-treat (ITT) analysis

Abbreviations: G = group; HOME = Home Observation for Measure of the Environment; NS = not significant; SOE = strength of evidence.

We graded the SOE as insufficient for mental and behavioral health and caregiver-child relationship outcomes due to nonsignificant findings (Table 30).

Table 30 Detailed strength of evidence grading table: Nurse home visitation intervention

Intervention and Comparator | Outcome | Studies; subjects | Risk of Bias | Consistency | Directness | Precision | SOE Grade; Magnitude of effect
Nurse home visitation vs. usual care | Mental health outcomes | 1 RCT;93 163 | L | Unknown, Single Study | Direct | Imprecise | Insufficient
Nurse home visitation vs. usual care | Healthy child-caregiver-outcomes | 1 RCT,93 163 | L | Unknown, Single Study | Direct | Imprecise | Insufficient

Abbreviations: M = medium; RCT = randomized controlled trial; SOE = strength of evidence.

#### Videotape Intervention

We identified one RCT (one article)101 comparing a low-intensity videotape intervention designed to improve caregiver supportive behavior towards a sexually abused child; the control group viewed a neutral videotape (Table 31).The study targeted mothers and their children, between the ages of 4 and 12.

Table 31 Videotape intervention: Study characteristics

First Author et al., Year | Sample Description (Age Group) | Study Design and Duration | Comparison Groups | Baseline N | Risk of Bias
Jinich and Litrownik, 1999^101^ | Sexually abused children (ages 4–12) and their mothers | RCT 22-minute videotape; 1 week follow-up to complete questionnaires | G1: VI G2: CV | Mothers G1: 32 G2: 32 Overall N = 64 Children ages 8–12 G1: 15 G2: 15 Overall N=30 | Medium

Abbreviations: CV=control videotape group, G=group, RCT=randomized clinical trial, VI=videotape intervention.

##### Key Points

- Mental and behavioral health: There were no significant differences in efficacy of the intervention on mental and behavioral health outcomes (insufficient SOE).101

##### Detailed Synthesis

Table 32 presents the results of a trial evaluating a videotape intervention;101 additional study details are provided in the evidence tables (Appendix E). The study was set in the waiting room of a clinic and conducted before and after the child’s forensic evaluation to confirm the suspected sexual abuse. The authors examined several outcomes relevant to KQ 1; however, most measures were developed by the study authors and without established validity. Thus, we include here only outcomes from the one valid measure, a child self-report measure of the impact of the traumatic experience. There were no significant differences between groups regarding child-reported problems related to the sexual abuse (e.g., social support, self-blame, negative reactions to others, and empowerment).

Table 32 Results: Videotape Intervention versus control videotape

First Author et al., Year | Comparison Groups | Mental Health | Healthy Child-Caregiver Relationship
Jinich and Litrownik, 1999^101^ | G1: VI G2: CV | Improvement in child self-blame (Children’s Impact of Traumatic Events Scale-Revised) No difference between G1 and G2, p=NS Improvements in child negative reactions to others (Children’s Impact of Traumatic Events Scale-Revised) No difference between G1 and G2, p=NS Improvements in child empowerment (Children’s Impact of Traumatic Events Scale-Revised) No difference between G1 and G2, p=NS | Improvement in child perception of social support (Children’s Impact of Traumatic Events Scale-Revised) No difference between G1 and G2, p=NS

Abbreviations: CV=control videotape group, G=group, NS=VI=videotape intervention.

We graded the SOE as insufficient due to nonsignificant findings (Table 33).

Table 33 Detailed strength of evidence grading table: Videotape intervention

Intervention and Comparator | Outcome | Studies; subjects | Risk of Bias | Consistency | Directness | Precision | SOE Grade; Magnitude of Effect
Videotape Intervention vs. Inactive Control | Mental health outcomes | 1 RCT101; 30 | M | Unknown | Direct | Imprecise | Insufficient
Videotape Intervention vs. Inactive Control

Abbreviations: M = medium; RCT = randomized controlled trial; SOE = strength of evidence.

#### Parenting Interventions, Summary of Strength of Evidence Grades

We summarize the SOE grade for all parenting interventions in Table 34.

Table 34 Parenting interventions: Summary strength of evidence for child well-being outcomes

Intervention (G1) | Comparison (G2) | Outcome | N Trials, Participants | Strength of Evidence; Magnitude of Effect
Attachment and Biobehavioral Catch-up | Active control^a^ | Mental and behavioral health | 2^77,78,82,83^; 213 | Low; NR
Attachment and Biobehavioral Catch-up | Active control^a^ | Healthy caregiver-child relationship | 2^79,81^; 166 | Low; NR
Attachment and Biobehavioral Catch-up | Active control^a^ | Healthy development | 1^85^; 37 | Low; NR
Attachment and Biobehavioral Catch-up | Wait list | Mental and behavioral health | 1^80^; 58 | Low; medium (partial eta squared=0.436 or 0.511)
Attachment and Biobehavioral Catch-up | Wait list | Healthy caregiver-child relationship | 1^80^; 58 | Low; medium or large (partial eta squared=0.59 or 0.791)
Attachment-based Intervention | Usual care | Mental and behavioral health | 1^86^; 79 | Insufficient
Attachment-based Intervention | Usual care | Healthy caregiver-child relationship | 1^86^; 79 | Low; small to medium (d=0.47, r=0.36 or 0.37)
Child-Parent Psychotherapy^b^ | Active control^a^ | Healthy caregiver-child relationship | 2^87,88^; 159 | Insufficient
Child-Parent Psychotherapy^b^ | Usual care | Healthy caregiver-child relationship | 2^87,88^; 141 | Low; medium to large (h=0.64 to 1.34)
Incredible Years Adaptation | Usual care | Mental and behavioral health | 1^89^; 64 | Insufficient
Incredible Years Adaptation | Usual care | Healthy caregiver-child relationship | 1^89^; 64 | Low; small to medium (d=0.40 or 0.59)
Keeping Foster and Kinship Parents Trained and Supported | Usual care | Mental and behavioral health | 1^91^; 700 | Moderate; small (d=0.26)
Keeping Foster and Kinship Parents Trained and Supported | Usual care | Healthy caregiver-child relationship | 1^91^; 700 | Moderate; small (d=0.29)
Nurse-Home Visitation Intervention | Usual care | Mental and behavioral health | 1^93^; 163 | Insufficient
Nurse-Home Visitation Intervention | Usual care | Healthy caregiver-child relationship | 1^93^; 163 | Insufficient
Videotape Intervention | Control videotape | Mental and behavioral health | ;1^101^; 30 | Insufficient
Videotape Intervention | Control videotape | Healthy caregiver-child relationship | 1^101^; 30 | Insufficient

a Active comparator is an approach derived from an intervention wherein the degree to which core components of the original model are implemented is unclear and/or core components are omitted or substantively modified.

b Intervention is a variant of relationship-based dyadic psychotherapy as developed and manualized by Cicchetti and colleagues.87,88

Note: Table is organized alphabetically by intervention name. All results are G1>G2 unless otherwise noted. For estimation of the magnitude of effect, we include only the statistically significant (p<0.05) effect sizes provided by study authors and do not calculate effect sizes as part of our analysis. Interpretation of the effect size as small, medium, or large is defined as: Cohen’s d = 0.20, 0.50, and 0.80; Cohen’s h = 0.20, 0.50, and 0.80; and correlation coefficient r = 0.10, 0.30, and 0.50.^176^ When authors use eta or partial eta squared effect sizes we use the interpretation that the authors provide.80,177 We include an effect size range when more than two effect sizes are reported.

Abbreviations: G = group; NR = not reported.

### Trauma-Focused Treatments

#### Description of Included Studies

Table 35 presents the 7 trials, reported in 7 articles, evaluating trauma-focused treatments included in KQ 1.

Table 35 Numbers of trials and articles investigating child well-being outcomes: Trauma-focused treatments

Intervention | Trials
Combined Parent-Child Cognitive Behavioral Therapy107 | 1
Eye Movement Desensitization and Reprocessing112 | 1
Group Psychotherapy for Sexually Abused Girls113 | 1
Group Treatment Program for Sexual Abuse114 | 1
Trauma-Focused Cognitive Behavioral Therapy108,115 | 2
Trauma-Focused Cognitive Behavioral Therapy Group Adaptation116 | 1
Total | 7

Below we provide an overview of the key features in the body of evidence for parenting interventions.

- Six of the trials were RCTs107,108,112,113,115,116 and one was a nonrandomized controlled trial.114
- All studies were efficacy trials (i.e., none of the studies self-identified as an effectiveness trial or did not meet the criteria for an effectiveness trial).
- All interventions included a child component.
- One trial also targeted a caregiver who had physically abused their child.107
- Four trials, all focused on children exposed to sexual abuse, also included components directed at the nonmaltreating caregiver.108,113,115,116
- One trial targeted children in early adolescence.112
- One trial compared the experimental intervention with an inactive control group (e.g., wait list).114
- Six trials used active control groups.
  ○ Three trials employed active control comparators representative of conventional practices in the field.108,113,116
  ○ Three trials employed active control comparators that were derived approaches.107,112,115
- All seven trials reported mental and behavioral health outcomes.
- Three trials reported on caregiver-child relationship outcomes.107,108,116
- No trials assessed developmental or school-based functioning outcomes.

#### Combined Parent-Child Cognitive Behavioral Therapy

We identified one RCT (one article)107 comparing a medium-intensity group-based approach, Combined Parent-Child Cognitive Behavioral Therapy (CPC-CBT), with an active comparator described by the authors as similar to but more comprehensive than usual parenting services offered in the community (Table 36).107 The study targeted physically abusive parents (defined as a substantiated allegation of child physical abuse in the past 4 months or who endorsed physical punishment on a standardized measure). To be eligible for the study, children (age 7 to 13) had to meet trauma symptom criteria of either endorsement of four post-traumatic stress disorder symptoms or elevated externalizing behavior scores on standardized measures.

Table 36 Combined parent-child cognitive behavioral therapy: Study characteristics

First Author et al., Year Country | Sample Description (Age Group) | Study Design and Duration | Comparison Groups | Baseline N | Risk of Bias
Runyon et al., 2010^107^ United States | Children ages 7 to 13 years and physically abusive parent | RCT T1: intervention end; approximately 16–20 weeks postbaseline T2: 12 weeks after intervention end^a^ | G1: CPC-CBT G2: Active control | G1: 40 children G2: 35 children Overall N=75 | Medium

a Results at T2 are not included due to high overall attrition.

Abbreviations: CPC-CBT = Combined Parent-Child Cognitive Behavioral Therapy; G = group; N = number; RCT = randomized controlled trial; SD = standard deviation; T = time.

##### Key Points

- Mental and behavioral health: Compared with an active control, participants in CPC-CBT had a significantly greater reduction in trauma symptoms; however, there was no significant difference in efficacy of the intervention on child internalizing or externalizing behavior problems (low SOE of benefit).107
- Healthy caregiver-child relationship: Compared with an active control, parents in CPC-CBT reported significantly greater increases in positive parenting practices; however, the control group reported significantly lower use of corporal punishment compared with participants in CPC-CBT. Based on child report, there were no significant differences in efficacy of the intervention on positive parenting practices or use of corporal punishment (insufficient SOE).107

##### Detailed Synthesis

Table 37 presents the results of the CPC-CBT trial;107 additional study details are provided in the evidence tables (Appendix E). The authors examined child trauma symptoms and behavioral problems as well as child and parent reports of positive parenting skills and use of corporal punishment. Parents in both study arms reported significant reductions in child PTSD symptoms and internalizing problems, with no statistically significant difference between treatment groups at either followup. The difference between groups was also nonsignificant for externalizing behavior problems. At postintervention, parents who participated in CPC-CBT reported a significantly greater increase in positive parenting practices compared with the active control (medium effect size). However, the control group reported significantly lower use of corporal punishment compared with participants in CPC-CBT (medium effect size). The authors also reported results at 3-month follow-up but the attrition rates at this time point were beyond our threshold for inclusion. The authors also reported that two families had new substantiated abuse allegations at followup but did not indicate the condition in which the families participated.

Table 37 Results: Combined parent-child cognitive behavioral therapy versus active control

First Author et al., Year | Comparison Groups | Mental and Behavioral Health | Healthy Caregiver-Child Relationship
Runyon et al., 2010^107^ | G1: CPC-CBT G2: Active control | Parent and child report of trauma symptoms (Schedule for Affective Disorders and Schizophrenia for School-Aged Children Present and Lifetime Version) G1^+^>G2^+^, p<.05, d=0.61 Parent report of child internalizing behavior problems (Child Behavior Checklist-Internalizing) No difference between G1^+^ and G2^+^, p=NS (NR) Parent report of child externalizing behavior problems (Child Behavior Checklist-Externalizing) No difference between G1^ns^ and G2^+^, p=NS (NR) | Child report of positive parenting (Alabama Parenting Questionnaire-Child) No difference between G1^ns^ and G2^ns^, p=NS (NR) Child report of reduction in parents’ use of corporal punishment (Alabama Parenting Questionnaire-Child) No difference between G1^+^ and G2^+^, p=NS (NR) Parent report of positive parenting (Alabama Parenting Questionnaire-Parent) G1^+^>G2^ns^, p<0.05, d=0.59 Parent report of reduction in use of corporal punishment (Alabama Parenting Questionnaire-Parent) G1^+^<G2^+^, p<0.05, d=0.57

Note: Greater comparative benefit is denoted using a greater (“>“) sign. Cohen’s d effect size index of the difference between groups means: 0.20 = small; 0.50 = medium; 0.80 = large.176

Abbreviations: CPC-CBT = Combined Parent-Child Cognitive Behavioral Therapy; G = group; NR = not reported; NS = not significant; T = time.

We graded the SOE for mental and behavioral health outcomes as low, based on the significant finding for reduced trauma symptoms in a single study (Table 38). We graded the SOE for caregiver-child relationship outcomes as insufficient due to nonsignificant and conflicting findings.

Table 38 Detailed strength of evidence grading table: Combined parent-child cognitive behavioral therapy

Intervention and Comparator | Outcome | Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | SOE Grade; Magnitude of Effect
CPC-CBT vs. active control^a^ | Mental and behavioral health | 1 RCT107; 75 | M | Unknown, single study | Direct | Precise | Low; medium (d=0.61)
CPC-CBT vs. active control^a^ | Healthy caregiver-child relationship | 1 RCT107; 75 | M | Unknown, single study | Indirect | Imprecise | Insufficient

a Active comparator is an approach derived from an intervention wherein the degree to which core components of the original model are implemented is unclear and/or core components are omitted or substantively modified.

Note: All results are G1>G2 unless otherwise noted. For estimation of the magnitude of effect, we include only the statistically significant (p<0.05) effect sizes provided by study authors and do not calculate effect sizes as part of our analysis. Interpretation of the effect size as small, medium, or large is defined as: Cohen’s d = 0.20, 0.50, and 0.80.^176^

Abbreviations: CPC-CBT = Combined Parent-Child Cognitive Behavioral Therapy; M = medium; RCT = randomized controlled trial; SOE = strength of evidence.

#### Eye Movement Desensitization and Reprocessing

We identified one RCT (one article)112 eligible for the review comparing Eye Movement Desensitization and Reprocessing (EMDR) (low-intensity intervention) with an active control group. The comparator was a substantively modified version of Trauma Focused-Cognitive Behavioral Therapy (TF-CBT) in that only the child component was retained from the original model (the standard version includes components that involve the caregiver; see Table 1 in the Introduction chapter for a description of standard TF-CBT). Additionally, it is not clear the extent to which other core components of TF-CBT were implemented with fidelity in this trial. The study targeted 12- to 13-year-old girls who reported sexual abuse victimization within the past 6 months (but not ongoing); a clinically significant level of trauma symptoms was required for participation in the study. The study was conducted in Iran (Table 39).

Table 39 Eye movement desensitization and reprocessing: Study characteristics

First Author et al., Year Country | Sample Description (Age Group) | Study Design and Duration | Comparison Groups | Baseline N | Risk of Bias
Jaberghaderi et al., 2004^112^ Iran | Iranian girls ages 12 to 13 years | RCT 8 months | G1: EDMR G2: Active control | G1: 7 G2: 7 Overall N=14 | Medium

Abbreviations: EDMR = Eye Movement Desensitization and Reprocessing; G = group; N = number; RCT = randomized controlled trial.

##### Key Points

- Mental and behavioral health outcomes: There was no significant difference in efficacy of the intervention on child trauma symptoms and child externalizing behaviors (insufficient SOE).112

##### Detailed Synthesis

Table 40 presents the results of the EMDR trial;112 additional study details are provided in the evidence tables (Appendix E). EMDR is a low-intensity treatment, with an active control (N=7). The authors examined parent and child report of child trauma symptoms and teacher report of child behavior problems. Youth who participated in the EMDR condition reported a significant reduction in post-traumatic stress symptoms at treatment end whereas participants in the control group did not show significant declines in symptoms. However, the difference between groups did not reach statistical significance. Parent report of child trauma symptoms significantly declined from pre- to post-test for both the EMDR condition (p<0.05) and the control group. Again, the difference between groups was not significant. Similarly, teacher report of child problem behaviors declined for both the EMDR and control conditions; however, there was no difference between groups. The use of the substantively modified comparative intervention makes it difficult to interpret the findings; additionally, the setting (Iran) limits the generalizability of the findings.

Table 40 Results: Eye movement desensitization and reprocessing versus active control

First Author et al., Year | Comparison Groups | Mental and Behavioral Health
Jaberghaderi et al., 2004^112^ | G1: EMDR G2: Active control | Child report of trauma symptoms (Child Report of Post-traumatic Symptoms) No difference between G1^+^ and G2^ns^, p=0.15 Parent report of trauma symptoms (Parent Report of Post-traumatic Symptoms) No difference between G1^+^ and G2^+^, p=0.96 Teacher report of problem behaviors (Rutter Teacher Scale) No difference between G1^+^ and G2^+^, p=0.42

Abbreviations: EDMR = Eye Movement Desensitization and Reprocessing; G = group; NS = not significant; SOE = strength of evidence.

We graded the SOE as insufficient, due to the nonsignificant findings in a single study with few subjects (Table 41).

Table 41 Detailed strength of evidence grading table: Eye movement desensitization and reprocessing

Intervention and Comparator | Outcome | Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | SOE Grade; Magnitude of Effect
EMDR vs. Active Control | Mental and behavioral health | 1 RCT112; 14 | M | Unknown, Single Study | Direct | Imprecise | Insufficient

Abbreviations: EDMR = Eye Movement Desensitization and Reprocessing; M = medium; RCT = randomized controlled trial; SOE = strength of evidence.

#### Group Psychotherapy for Sexually Abused Girls

We identified one RCT (one article)113 evaluating a medium-intensity, psychoeducational and psychotherapeutic group treatment for sexually abused girls compared with an active control (Table 42). The control treatment was conventional psychoanalytic individual therapy (high intensity; up to 30 weekly 50-minute sessions). Both the experimental and control treatments shared generic and abuse-specific components including maintaining the therapeutic alliance, managing anxieties, and appropriately handling postabuse and current concerns. The two conditions also included a caregiver-directed component comprising social work support (delivered in either a group or individual mode aligned with that of the child-directed component). The study targeted girls between the ages of 6 and 14 years of age and was conducted in London. Nearly three-quarters of the sample had a DSM-IV diagnosis of PTSD (73%); the other main DSM-IV diagnoses in the sample were separation anxiety disorder (58%), major depressive disorder (57%), and general anxiety disorder (37%).

Table 42 Group psychotherapy for sexually abused girls: Study characteristics

First Author et al., Year Country | Sample Description (Age Group) | Study Design and Duration | Comparison Groups | Baseline N | Risk of Bias
Trowell et al., 2002^113^ England | Symptomatic sexually abused girls ages 6 to 14 years | RCT T1: 1 year after start of therapy T2: 2 years after start of therapy | G1: Group Psychotherapy for Sexually Abused Girls G2: Active control | G1: 36 G2: 35 Overall N=71 | Medium

Abbreviations: G = group; N = number; RCT = randomized controlled trial; SOE = strength of evidence; T = time.

##### Key Points

- Mental and behavioral health: Girls who participated in the group therapy treatment had significantly worse outcomes in trauma symptoms compared with an active control. There was no significant difference in efficacy of the group psychotherapy treatment on trauma symptoms or functional impairment (low SOE of greater benefit for active control).113

##### Detailed Synthesis

Table 43 presents the results of the group psychotherapy treatment;113 additional study details are provided in the evidence tables (Appendix E). The authors examined trauma and other symptoms of emotional or behavioral disturbance. The authors set a criterion of medium to large effect sizes (≥0.5) for reporting findings. At the first followup, 1 year after baseline (start of therapy), children who participated in the control condition exhibited significantly greater improvements in PTSD symptomatology compared with those in group psychotherapy: re-experiencing of traumatic events (medium effect size) and persistent avoidance of stimuli dimensions (medium effect size). These group-difference findings were sustained at the second followup (2 years postentry into treatment) for re-experiencing symptoms (borderline large effect size) and persistent avoidance of stimuli (small effect size), again with greater improvements exhibited by children who participated in the control condition. No significant between-group differences were found for the PTSD dimension of “persistent symptoms of increased arousal” or for the Kiddie Global Assessment Scale impairment index.

Table 43 Results: Group psychotherapy for sexually abused girls versus active control

First Author et al., Year | Comparison Groups | Mental and Behavioral Health
Trowell et al., 2002^113^ | G1: Group Psychotherapy for Sexually Abused Girls G2: Active control | Re-experience of traumatic events scale (Orvaschel PTSD Scale) G1 < G2 T1: p=NR (sig), d=0.60 T2: p=NR (sig), d=0.79 Persistent avoidance of stimuli (Orvaschel PTSD Scale) G1 < G2 T1: p=NR (sig), d=0.66 T2: p=NR (sig), d=0.36 Persistent symptoms of increased arousal (Orvaschel PTSD Scale) No difference between G1 and G2 T1 and T2: p=NS (NR) Impairment index (Kiddie Global Assessment Scale) No difference between G1 and G2 T1 and T2: p=NS (NR)

Note: Greater comparative benefit is denoted using a greater (“>”) sign.Cohen’s d effect size index of the difference between groups means: 0.20 = small; 0.50 = medium; 0.80 = large.

Abbreviations: G = group; NR = not reported; NS = not significant; PTSD = post-traumatic stress disorder; SOE = strength of evidence; T = time.

We graded the SOE as low for mental and behavioral health outcomes for the active control (conventional psychoanalytic therapy), based on the significant finding for reduced trauma symptoms in a single study (Table 44).

Table 44 Detailed strength of evidence grading table: Group psychotherapy for sexually abused girls

Intervention and Comparator | Outcome | Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | SOE Grade; Magnitude of Effect
Group Psychotherapy for Sexually Abused Girls vs. Active control^a^ | Mental and behavioral health | 1 RCT113; 71 | M | Unknown, Single Study | Direct | Precise | Low (G1<G2); small to medium (d=0.36 to 0.79)

a Active comparator is an approach representative of a conventional practice in the field.

Note: For estimation of the magnitude of effect, we include only the statistically significant (p<0.05) effect sizes provided by study authors and do not calculate effect sizes as part of our analysis. Interpretation of the effect size as small, medium, or large is defined as: Cohen’s d = 0.20, 0.50, and 0.80^176^

Abbreviations: M = medium; RCT = randomized controlled trial; SOE = strength of evidence.

#### Group Treatment Program for Sexual Abuse

We identified one nonrandomized controlled trial (Table 45) comparing a high-intensity psychoeducational and psychotherapeutic group treatment for sexual abuse victims with a wait-list control group. The study targeted sexually abused girls between the ages of 9 and 12 years, referred from CPS or other sources, including self-referral. In describing the intervention, the authors briefly list its components and also characterize it as “similar to hundreds of treatment programs provided to children who have been sexually abused.”

Table 45 Group treatment program for sexual abuse: Study characteristics

First Author et al., Year | Sample Description (Age Group) | Study Design and Duration | Comparison Groups | Baseline N | Risk of Bias
McGain and McKinzey, 1995^114^ | Sexually abused girls (ages 9–12) | Nonrandomized controlled trial 24 sessions over 6 months | G1: Group Treatment Program for Sexual Abuse G2: wait list | G1: 15 G2: 15 Overall N = 30 | Medium

Abbreviation: G = group.

##### Key Points

- Mental and behavioral health: Compared with a wait-list control, girls who participated in a group treatment program had significantly greater improvements in behavioral problems (including conduct problems, socialized aggression, attention problems, motor excess, intensity) (low SOE of benefit).114

##### Detailed Synthesis

Table 46 presents the results of a nonrandomized controlled trial of a group treatment program for sexual abuse victims;114 additional study details are provided in the evidence tables (Appendix E). The authors examined participants’ emotional and behavioral adjustment following the abuse. Participants in the group treatment had significantly greater reductions in conduct problems. Comparing post-test means across study arms, the study found significant differences in improvement across numerous subscales of a behavioral measure. However, these findings must be interpreted with caution in light of the nonrandomized design and very small sample size.

Table 46 KQ 1 results: Group treatment for sexual abuse versus wait list control

First Author et al., Year | Comparison Groups | Mental and Behavioral Health
McGain and McKinzey, 1995 | G1: Group Treatment Program for Sexual Abuse G2: wait list | Improvements in symptoms of conduct disorder (Quay Revised Behavior Problems Checklist) G1>G2, p<0.0001 Improvements in symptoms of socialized aggression (Quay Revised Behavior Problems Checklist) G1>G2, p<0.0001 Decreases in attention problems/immaturity (Quay Revised Behavior Problems Checklist) G1>G2, p<0.0001 Improvements in anxiety/withdrawal (Quay Revised Behavior Problems Checklist) G1>G2, p<0.0001 Improvements in motor excess (Quay Revised Behavior Problems Checklist) G1>G2, p<0.0001 Overall improvements in the intensity of behavior problems (Quay Revised Behavior Problems Checklist) G1>G2, p<0.0001 Overall improvements in the number of behavior problems G1>G2, p=0.001

Note: Greater comparative benefit is denoted using a greater (“>”) sign.

Abbreviation: G = group.

We graded the SOE as low due to the presence of a single study (Table 47).

Table 47 Detailed strength of evidence grading table: Group treatment program for sexual abuse

Intervention and Comparator | Outcome | Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | SOE Grade; Magnitude of Effect
Group Treatment Program for Sexual Abuse vs. Inactive Control | Mental and behavioral health | 1^114^; 30 | M | Unknown, single study | Direct | Precise | Low; NR

Note: All results are G1>G2 unless otherwise noted. For estimation of the magnitude of effect, we include only the statistically significant (p<0.05) effect sizes provided by study authors and do not calculate effect sizes as part of our analysis.

Abbreviations: G = group; M = medium; NR == not reported; SOE = strength of evidence.

#### Trauma-Focused Cognitive Behavioral Therapy

We identified three RCTs evaluating the efficacy of Trauma-Focused Cognitive Behavioral Therapy (TF-CBT), a low- to medium-intensity (12 to 16 weekly sessions) treatment (Table 48). Two trials compared TF-CBT with active controls developed by the study authors. The initial trial,115 conducted with children age 2 to 7 years, used a derived comparator designed to control for nonspecific aspects of the experimental intervention (focused on reducing isolation and hopelessness while improving emotion identification; no explicit focus on the sexual abuse). A second trial,108 conducted with children age 8 to 14 years, used conventional child-centered therapy focused on developing a trusting therapeutic alliance and allowed therapy goals to be directed by child and parent (2 sessions directed towards processing the sexual abuse if the clients did not spontaneously talk about the abuse). A third trial,116 conducted with children age 2 to 8 years, compared a group adaptation of TF-CBT with a conventional supportive parent group developed by the authors. The control treatment focused on topics individual group members selected with an emphasis on active listening, unconditional positive regard, and reflecting feelings. The authors describe the experimental and control treatments as being similar in content but differing in the methods used to deliver information and skills, with the former using an interactive behavioral therapy format and the latter using a didactic format.

Table 48 Trauma-focused cognitive behavioral therapy: Study characteristics

First Author et al., Year Country | Sample Description (Age Group) | Study Design and Duration | Comparison Groups | Baseline N | Risk of Bias
Cohen et al, 1996^115^ United States | Sexually abused preschoolers (ages 2.11 to 7.1 years; mean age=4.68) | RCT 12 to 16 weeks | G1: TF-CBT G2: Active control | G1: NR G2: NR Overall N=86 | Medium
Cohen et al, 2004^108^ United States | Sexually abused children (ages 8 to 14.11 years; mean age=10.76) | RCT 12 weeks | G1=TF-CBT G2=Active control | G1=114 G2=115 Overall N=229 | Low
Deblinger et al, 2001^116^ United States | Sexually abused young children (ages 2 to 8 years; mean age 5.45) | RCT 11 weeks Followup: 3 months | G1=TF-CBT Group Adaptation G2= Active control | G1=22 G2=22 Overall N=44 | Medium

Abbreviations: G = group; N = number; NR = not reported; RCT = randomized controlled trial; TF-CBT = Trauma-Focused Cognitive-Behavioral Therapy.

##### Key Points

- Mental and behavioral health:
  ○ Compared with active controls, participants in TF-CBT had significantly greater improvements in trauma symptoms; however, findings were inconsistent across the two trials for internalizing sexual behavior problems (low SOE of benefit).108,115
  ○ There were no significant differences in efficacy of the TF-CBT Group Adaptation compared with an active control on trauma symptoms or behavioral problems, including sexual behavior (insufficient SOE).116
- Healthy caregiver-child relationship:
  ○ Compared with an active control, parents who participated in TF-CBT had significantly greater reductions in depression and increased use of positive parenting practices (low SOE of benefit).108
  ○ Compared with an active control, mothers who participated in TF-CBT Group Adaptation had significantly greater declines in intrusive thoughts; however, there were no significant differences in efficacy of TF-CBT on mother’s avoidant thoughts, trauma symptoms, or parenting practices (insufficient SOE).116

##### Detailed Synthesis

Table 49 presents the results of the standard TF-CBT trials;108,115 additional study details are provided in the evidence tables (Appendix E). In the initial trial,115 the authors examined young children’s social competence, internalizing symptoms, and externalizing behavior including sexual behavior. Participants in TF-CBT had significantly greater improvements on an overall measure of problem behavior, including a subscale on internalizing symptoms; however, there was no difference in efficacy of TF-CBT on the externalizing or social competence scales of the same measure. TF-CBT also resulted in improvements in sexual behavior as measured using a sexual behavior inventory. A second trial108 with older children examined trauma symptoms, internalizing problems (using several measures), externalizing behaviors including sexual behavior problems, and social competence. This study also included parent depression and parenting practices outcomes. Participants in TF-CBT had significantly greater reductions in trauma symptoms compared with the control group: re-experiencing of the abuse (borderline medium effect size), decreases in avoidance of reminders of the abuse (medium-to-large effect size), and decreased hypervigilance (medium effect size). TF-CBT participants also experienced significant reductions in depression symptoms (medium effect size). However, there were no significant differences in efficacy of TF-CBT on internalizing problems including anxiety and no group differences in externalizing problems, sexual behavior problems, or social competence. A statistically significant between-group difference was found for the total score on the Child Behavior Checklist, although the low T-scores (< 40) call into question the clinical significance of the finding. Parents who participated in TF-CBT reported significant reductions in depressive symptoms (small effect size) and increased use of positive parenting practices (medium effect size) compared with the active control.

Table 49 Results: Trauma-focused cognitive behavioral therapy versus active control

First Author et al., Year | Comparison Groups | Mental and Behavioral Health | Healthy Caregiver-Child Relationship
Cohen et al, 1996^115^ | G1: TF-CBT G2: Active control | Improvements in social competence (Child Behavior Checklist Social Competence) No differences between G1^ns^ and G2^ns^, p=NS, NR Improvements in behavior (Child Behavior Checklist Behavioral Profile-Total) G1^+^>G2^ns^, p<0.01 Improvements in internalizing symptoms (Child Behavior Checklist - Internalizing) G1^+^>G2^ns^, p<0.002 Improvements in externalizing symptoms (Child Behavior Checklist Externalizing) No differences between G1^+^ and G2^ns^, p=NS, NR Improvements in sexual behaviors (Child Sexual Behavior Inventory) G1^+^>G2^ns^, p<0.05 | NA
Cohen et al, 2004^108^ | G1:TF-CBT G2: Active control | Decrease in re-experiencing of traumatic event (Schedule for Affective Disorders and Schizophrenia for School-Aged Children Present and Lifetime Version – Re-experiencing) G1>G2, p<0.01, d=0.49 Decrease in avoidance of reminders of traumatic event (Schedule for Affective Disorders and Schizophrenia for School-Aged Children Present and Lifetime Version-Avoidance) G1>G2, p<0.001, d=0.70 Decrease in hypervigilance (Schedule for Affective Disorders and Schizophrenia for School-Aged Children Present and Lifetime Version- Hypervigilance) G1>G2, p<0.01, d=0.40 Improvements in behavior (Child Behavior Checklist Total) G1>G2, p<0.05, d=0.33 Improvements in social competence (Child Behavior Checklist Competence) No differences between G1 and G2, p=NS, NR Improvements in internalizing problems (Child Behavior Checklist Internalizing) No differences between G1 and G2, p=NS Improvements in externalizing (Child Behavior Checklist Externalizing) No differences between G1 and G2, p=NS Improvements in depression (Children’s Depression Inventory) G1>G2, p<0.05, d=0.30 Improvements in sexual behaviors (Children’s Depression Inventory) No differences between G1 and G2, p=NS, NR Improvements in proneness to anxiety (State-Trait Anxiety Inventory for Children Trait) No differences between G1 and G2, p=NS, NR Improvements in fleeting anxiety (State-Trait Anxiety Inventory for Children State) No differences between G1 and G2, p=NS, NR | Parent self-report of depression (Becks Depression Inventory) G1>G2, p<0.05, d=0.38 Improved parenting practices (Parenting Practices Questionnaire) G1>G2, p<0.001, d=0.57

Note: Greater comparative benefit is denoted using a greater (“>”) sign. Cohen’s d effect size index of the difference between groups means: 0.20 = small; 0.50 = medium; 0.80 = large.176

Abbreviations: G = group; NA = not applicable; NR = not reported; NS = not significant; SOE = strength of evidence; TF-CBT = Trauma-Focused Cognitive-Behavioral Therapy.

Table 50 presents the results of the trial using the TF-CBT Group Adaptation;116 additional study details are provided in the evidence tables (Appendix E). The authors examined trauma symptoms, behavior problems, and sexual behavior problems outcomes as well as maternal emotional well-being outcomes (trauma symptoms and maternal distress) and parenting practices. The study found no significant differences between groups in children’s PTSD symptoms, behavior problems, or sexual behavior problems. The parents in the TF-CBT group reported significantly fewer intrusive thoughts about the abuse at the conclusion of the treatment but there were no significant differences in maternal PTSD symptoms, improved parenting practices, or maternal avoidant thoughts about the abuse across parent group conditions.

Table 50 Results: Trauma-focused cognitive behavioral therapy group adaptation versus active control

First Author et al., Year | Comparison Groups | Mental and Behavioral Health Outcomes | Healthy Caregiver-Child Relationship Outcomes
Deblinger et al, 2001^116^ | G1=TF-CBT Group Adaptation G2= Supportive Groups | Changes in PTSD symptoms No differences between G1 and G2^a^, p=NS, NR Changes in behavior (Child Behavior Checklist) No differences between G1 and G2^a^, p=NS, NR Changes in sexual behaviors (Child Sexual Behavior Inventory) No differences between G1 and G2^a^, p=NS, NR | Maternal PTSD symptoms (Symptom Checklist-90-Revised) No differences between G1 and G2^a^, p=NS, NR Improved parenting practices (Parenting Practices Questionnaire) No differences between G1 and G2^a^, p=NS, NR Maternal distress-intrusive thoughts (Impact of Events Scale) G1>G2^a^, p<0.05 Maternal distress-avoidant thoughts (Impact of Events Scale) No differences between G1 and G2^a^, p=NS, NR

a Repeated measures MANOVA, with pooled standard deviations across study groups, showed a significant improvement at p < 0.001.

Note: Greater comparative benefit is denoted using a greater (“>”) sign.

Abbreviations: G = group; NR = not reported; NS = not significant; PTSD = post-traumatic stress disorder; TF-CBT = Trauma-Focused Cognitive-Behavioral Therapy.

For the trials comparing standard TF-CBT with active controls, we graded the SOE as low for both mental and behavioral health and caregiver-child relationship outcomes (Table 51). Although the sample size was relatively large for one of the trials, the SOE is limited by number of trials and the inconsistent findings. For the trial testing the TF-CBT Group Adaptation against an active control, we graded the SOE as insufficient for mental and behavioral health outcomes due to nonsignificant findings.

Table 51 Detailed strength of evidence grading table: Trauma-focused cognitive behavioral therapy

Intervention and Comparator | Outcome | Studies; subjects | Risk of Bias | Consistency | Directness | Precision | SOE Grade; Magnitude of effect
TF-CBT vs. Active Control^a^ | Mental and behavioral health | 2 RCTs108,115; 315 | L/M | Consistent | Direct | Precise | Low; small to medium (d=0.30 to 0.70)
TF-CBT vs. Active Control^a^ | Healthy caregiver-child relationship | 1 RCT108; 229 | L/ | Unknown, single study | Indirect | Precise | Low; small to medium (d=0.38 or 0.57)
TF-CBT Group Adaptation vs. Active Control^b^ | Mental and behavioral health | 1 RCT116; 44 | M | Unknown, single study | Direct | Imprecise | Insufficient
TF-CBT Group Adaptation vs. Active Control^b^ | Healthy caregiver-child relationship | 1 RCT116; 44 | M | Unknown, single study | Indirect | Imprecise | Insufficient

a One comparator is a conventional approach, the other a derived approach.

b Active comparator is an approach representative of a conventional practice in the field.

Note: All results are G1>G2 unless otherwise noted. For estimation of the magnitude of effect, we include only the statistically significant (p<0.05) effect sizes provided by study authors and do not calculate effect sizes as part of our analysis. Interpretation of the effect size as small, medium, or large is defined as: Cohen’s d = 0.20, 0.50, and 0.80.^176^

Abbreviations: L = low; M = medium; RCT = randomized controlled trial; SOE = strength of evidence; TF-CBT = Trauma-Focused Cognitive-Behavioral Therapy.

#### Trauma-Focused Treatments, Summary of Strength of Evidence Grades

We summarize the SOE grade for all trauma-focused treatments in Table 52.

Table 52 Trauma-focused treatments: Summary strength of evidence for child well-being outcomes^a^

Intervention (G1) | Comparison (G2) | Outcome | N Trials, Participants | Strength of Evidence Magnitude of Effect
Combined Parent-Child Cognitive Behavioral Therapy | Active Control^a^ | Mental and behavioral health | 1^107^; 75 | Low; medium (d=0.61)
Combined Parent-Child Cognitive Behavioral Therapy | Active Control^a^ | Healthy caregiver-child relationship | 1^107^; 75 | Insufficient
Eye Movement Desensitization and Reprocessing | Active Control^a^ | Mental and behavioral health | 1^112^; 14 | Insufficient
Group Psychotherapy for Sexually Abused Girls | Active control^b^ | Mental and behavioral health | 1^113^; 71 | Low (G1<G2); small to medium (d=0.36 to 0.79)
Group Treatment Program for Sexual Abuse | Inactive control | Mental and behavioral health | 1^114^; 30 | Low; NR
Trauma-Focused Cognitive Behavioral Therapy | Active Control^c^ | Mental and behavioral health | 2^108,115^; 315 | Low; small to medium (d=0.30 to 0.70)
Trauma-Focused Cognitive Behavioral Therapy | Active Control^c^ | Healthy caregiver-child relationship | 1^108^; 229 | Low; small to medium (d=0.38 or 0.57)
Trauma-Focused Cognitive Behavioral Therapy Group Adaptation | Active control^b^ | Mental and behavioral Health | 1^116^; 44 | Insufficient
Trauma-Focused Cognitive Behavioral Therapy Group Adaptation | Active control^b^ | Healthy caregiver-child relationship | 1^116^; 44 | Insufficient

a Active comparator is an approach derived from an intervention wherein the degree to which core components of the original model are implemented is unclear and/or core components are omitted or substantively modified.

b Active comparator is an approach representative of a conventional practice in the field.

c One comparator is a conventional approach, the other a derived approach.

Note: Table is organized alphabetically by intervention name. All results are G1>G2 unless otherwise noted. For estimation of the magnitude of effect, we include only the statistically significant (p<0.05) effect sizes provided by study authors and do not calculate effect sizes as part of our analysis. Interpretation of the effect size as small, medium, or large is defined as Cohen’s d = 0.20, 0.50, and 0.80.^176^ We include an effect size range when more than two effect sizes are reported. Abbreviations: G = group; N = number; NR = not reported.

### Enhanced Foster Care Interventions

#### Description of Included Studies

Table 53 presents the 4 trials, reported in 21 articles, evaluating enhanced foster care interventions included in KQ 1.

Table 53 Numbers of trials and articles investigating child well-being outcomes: Enhanced foster care interventions

Intervention | Trials
Bucharest Early Intervention Project (BEIP)117–129 | 1^a^
Fostering Healthy Futures131 | 1
Middle School Success136,137 | 1^b^
Multidimensional Treatment Foster Care – Preschoolers (MTFC-P)138,139,141,142,179 | 1^c^
Total | 4

a Reported in 13 articles.

b Reported in 2 articles.

c Reported in 5 articles.

Below we provide an overview of the key features in the body of evidence for enhanced foster care interventions.

- All four trials were RCTs.117–124,126–129,131,136–139,141,142,179
- All studies were efficacy trials (i.e., none of the studies self-identified as an effectiveness trial or did not meet the criteria for an effectiveness trial).
- Two of the experimental interventions included caregiver components. Both targeted children in early childhood.117–124,126–129,139,141,142,179
- One trial assessed an intervention that targeted the child only.131
- Three trials compared the experimental intervention with usual care.117–124,126–129,139,141,142,179
- One trial compared the experimental intervention with an inactive control group (i.e., assessment only).131
- All four trials reported on mental and behavioral health outcomes.
- Two trials also reported on healthy caregiver-child relationship and development outcomes.117–124,126–129,139,141,142,179
- None of the included trials assessed school-based functioning outcomes.

One trial was completed outside of the United States. It was in Bucharest, Romania, and targeted children in institutional care.117–124,126–129

#### Bucharest Early Intervention Project

We identified one RCT (13 articles)117–129 evaluating a high-intensity model of enhanced supports to foster parents adopting infants and toddlers from institutional care in Bucharest, Romania (Table 54). The trial, known as the Bucharest Early Intervention Project (BEIP), is a landmark research study examining the efficacy of enhanced foster care with children who have experienced severe social deprivation (Table 54). The intervention model is based on a similar approach developed by one of the study authors and implemented in the United States.130 The sample comprised children residing in one of six institutions; children with medical problems, such as genetic syndromes, observable characteristics of fetal alcohol syndrome, and microcephaly, were ineligible for the study. The primary inclusion criterion was for children to have entered their resident institution prior to 31 months of age.

Table 54 Bucharest early intervention project: Study characteristics

First Author et al., Year Country | Sample Description (Age Group) | Study Design and Duration^a^ | Comparison Groups | Baseline N | Risk of Bias
Bos et al., 2009,^117^ 2010;^118^ Fox et al., 2011;^119^ Ghera et al., 2009;^120^ Johnson et al., 2010;^121^ Marshall et al., 2008;^122^ McDermott et al., 2012;^123^ McLaughlin et al., 2011,^124^ 2012^125^; Nelson et al., 2007;^126^ Smyke et al., 2010;^127^ Windsor et al., 2011;^128^ Zeanah et al., 2009^129^ Romania | Institutionalized children (Mean age foster care=20.9, SD=7.1, Mean age institutional care=20.8, SD=7.17. Range 5–31 months) | RCT T1: 30 months (child age) T2: 42 months (child age) T3: 54 months (child age) T4: 96 months (8 years)^a^ | G1:Foster care G2: Institutional care | G1: 68^b^ G2: 68^b^ | Medium

a Ghera et al., 2009, Johnson et al., 2010, Marshall et al., 2008, Smyke, 2010, and Windsor et al., 2011, assess outcomes at 30 and 42 months; Bos et al., 2009, at 30, 42, and 54 months; Zeanah et al., 2009, at 54 months; McLaughlin et al., 2011, at 30, 42, and 96 months; Fox et al., 2011, and McDermott et al., 2012, at 96 months.

b Marshall et al, 2008 G1: 56, G2: 41

Abbreviations: G = group; RCT = randomized controlled trial; SD = standard deviation; T = time.

##### Key Points

- Mental and behavioral health: Compared with children who remained in institutional care, children in the BEIP intervention had significant improvements in attention and positive affect and reductions in internalizing and anxiety symptoms, stereotypies associated with severe deprivation and social isolation, and depression among females; there was no difference in efficacy of the BEIP intervention on externalizing disorders, ADHD, oppositional defiant or conduct disorders, depression among males, or comorbidity (low SOE of benefit).118,120,123,125,129
- Healthy caregiver-child relationship: Compared with children who remained in institutionalized care, children in the BEIP intervention were significantly more likely to exhibit secure and organized attachment behavior (low SOE of benefit).121,125,127
- Healthy development: Compared with children who remained in institutional care, children in the BEIP intervention had significantly higher levels of cognitive functioning and receptive/expressive language, improvements in executive functioning (working memory strategy, accuracy, faster reaction time), and improved physical growth (weight and height) (low SOE of benefit).117,119,121,122,124,126,128

##### Detailed Synthesis

Table 55 presents the results of the BEIP trial;117–129 additional study details are provided in the evidence tables (Appendix E). Mental and behavioral health outcomes were evaluated in five articles: one addressed psychiatric symptoms or disorders,129 another behavior stereotypies,118 and two assessed aspects of attention and executive functioning;120,123 two papers report outcomes stratified by sex.125,129

Table 55 Results: Bucharest early intervention project versus institutional care

First Author et al., Year | Comparison Groups | Mental and Behavioral Health | Healthy Caregiver-Child Relationship | Healthy Development
Ghera et al., 2009^120^ | G1:Foster care G2: Institutional care group | Attention^a^(Lab-TAB) T1: No difference between groups G1 and G2, p>0.05 T2: G1^+^>G2, p=0.01 Positive Affect^a^ T1: G1^+^>G2, p<0.001 T2: G1^+^>G2, p<0.001 Negative Affect^a^ T1, T2: No difference between groups G1 and G2, p>0.05 | NA | NA
Zeanah et al., 2009^129^ | G1:Foster care G2: Institutional care | Psychiatric Disorder^a^ (Preschool Age Psychiatric Assessment) [underlined: Any Disorder] G1>G2, p=0.10, trend [underlined: Any Externalizing Disorder] No difference between G1 and G2, p=0.69 [underlined: Any Internalizing Disorder] G1> G2, p=0.01, OR 2.8^b^ (95% CI, 1.2 to 6.4) [underlined: ADHD] No difference between G1 and G2, p=0.57 [underlined: Opp. Defiant or Conduct D/O] No difference between G1 and G2, p=0.57 [underlined: Depression] No difference between G1 and G2, p=0.50 [underlined: Any Anxiety] G1>G2, p=.01, OR 2.9^b^ (95% CI, 1.2 to 6.6) [underlined: Comorbid D/O>2] No difference between G1 and G2, p=0.53 | NA | NA
McLaughlin 2012^125^ | G1:Foster care G2: Institutional care | Psychiatric Disorder^a^ (Preschool Age Psychiatric Assessment) [underlined: Any Internalizing Disorder among Females] G1> G2, p=0.006, OR 0.17 [underlined: Any Internalizing Symptoms among Females] G1> G2, p=0.004 [underlined: Depression among Females] G1> G2, p=0.009 [underlined: Anxiety among Females] G1> G2, p=0.009 [underlined: Any Externalizing Disorder among Females] No difference between G1 and G2, p=NR [underlined: Any Externalizing Symptoms among Females] No difference between G1 and G2, p=NR [underlined: Any Internalizing Disorder among Males] No difference between G1 and G2, p=0.150 [underlined: Any Internalizing Symptoms among Males] No difference between G1 and G2, p=0.372 [underlined: Depression among Males] No difference between G1 and G2, p=0.879 [underlined: Anxiety among males] No difference between G1 and G2, p=0.190 [underlined: Any Externalizing Disorder among Males] No difference between G1 and G2, p=NR [underlined: Any Externalizing Symptoms among Males] No difference between G1 and G2, p=NR
Bos et al., 2010^118^ | G1:Foster care G2: Institutional care | Presence of Stereotypies (Preschool Age Psychiatric Assessment) T1: G1>G2, p=0.003 T2: G1>G2, p=0.001 T3: G1>G2, p=0.04 | NA | NA
Smyke et al., 2010^127^ | G1:Foster care G2: Institutional care | NA | Attachment at 42 months^*^ (strange situation) [underlined: Distribution of Attachment Types] G1>G2, p<0.001 [underlined: Organized v. Atypical] G1>G2, p<0.01 [underlined: Organized v. Atypical among G1] Girls>Boys, p<0.05 [underlined: Secure v. Insecure]r G1>G2, p<0.001 [underlined: Secure v. Insecure among G1] Girls>Boys, p=0.055 [underlined: Mean Attachment Security Rating] (Observation, score 0 to 9) G1>G2, p<0.001
McLaughlin 2012^125^ | G1:Foster care G2: Institutional care | NA | Attachment at 42 months^a^ (strange situation) [underlined: Secure v. Insecure among Females] T2 G1>G2, p<0.001, OR=12.5 [underlined: Change from Insecure to secure among Females] T2 G1>G2, p=0.029, OR= 6.6 [underlined: Secure v. Insecure among males] T2 No difference between G1 and G2, p=.205, OR= 1.1 [underlined: Change from Insecure to secure among males] T2 No difference between G1 and G2, p=.250, OR= 2.2
Nelson et al., 2007^126^ | G1:Foster care G2: Institutional care | NA | NA | Developmental/Intellectual Quotient^a^ (Bayley Scales of Infant Development, Wechsler Preschool and Primary Scale of Intelligence) T1: G1>G2, p=0.001, ES=0.62 T2: G1>G2, p=0.015, ES=0.47
Marshall et al., 2008^122^ | G1:Foster care G2: Institutional care | NA | NA | EEG signal power and coherence^a^ EEG Power (Absolute) No difference between groups G1 and G2, p=NR, NS EEG Coherence No difference between groups G1 and G2, p=NR, NS
Bos et al., 2009^117^ | G1:Foster care G2: Institutional care group | NA | NA | Memory^a^ (CANTAB) No difference between groups G1 and G2, p>0.05 Executive Functioning^*^ (CANTAB): Stocking of Cambridge subtest: No difference between groups G1 and G2, p>0.05 Spatial working memory subtest, total errors: No difference between groups G1 and G2, p>0.05 Spatial working memory subtest, strategy: G1^+^>G2, p=0.008
Fox et al., 2011^119^ | G1:Foster care G2: Institutional care group | NA | NA | Intellectual Quotient^*^ (Wechsler Intelligence Scale for Children, WISC-IV) Verbal Comprehension subtest: G1^+^>G2, p=0.036 Perceptual Reasoning subtest: No difference between groups G1 and G2, p>0.05 Working Memory subtest: No difference between groups G1 and G2, p>0.05 Processing Speed subtest No difference between groups G1 and G2, p>0.05 Full IQ: G1^+^>G2, trend p=0.07
Johnson et al., 2010^121^ | G1:Foster care G2: Institutional care group | NA | Caregiving Quality (Observational Record of the Caregiving Environment-ORCE) T1 G1>G2, p<0.05 T2 No difference between groups G1 and G2, p>0.05 T1/T2 mean G1>G2, p<0.05 | Auxology^a^ (physical maturation) Height: Mean growth Baseline /T1/T2 G1^*^>G2, p <0.001 Growth change from Baseline/T1/T2 G1^*^>G2, p <0.001 Weight Mean growth Baseline /T1/T2 G1^a^>G2, p <0.001 Growth change from Baseline/T1/T2 G1^a^>G2, p =0.05 Occipital-frontal circumference (Head grow): Growth change from Baseline/T1/T2 No difference between groups G1 and G2, p>0.05 Developmental/Intellectual Quotient^a^ (Bayley Scales of Infant Development, Wechsler Preschool and Primary Scale of Intelligence) T2 (DQ)G1^a^>G2, p <0.05, T3 (IQ) G1^a^>G2, p <0.05
McDermott., 2012^123^ | G1:Foster care G2: Institutional care group | NA | NA | Executive Functioning (inhibitory control, Go/No Go task): Accuracy: G1>G2, p <0.05 Faster Reaction time G1>G2, p <0.05 Differential reactivity (larger error related negativity difference score between correct and error trials) G1>G2, p=0.01
McLaughlin 2011^124^ | G1:Foster care G2: Institutional care | NA | NA | EEG Frontal Asymmetry No difference between groups G1 and G2, p=.663 EEG Parietal Asymmetry No difference between groups G1 and G2, p=.980
Windsor et al., 2011^128^ | G1:Foster care G2: Institutional care group | NA | NA | Expressive and Receptive Language^a^ (Receptive-Expressive Emergent Language Scale-REEL; Reynell Developmental Language Scales-III-RDLS) REEL-R (Receptive): T1 G1>G2, p=NR ES=0.53 (d) REEL-E (Expressive): T1 No difference between groups G1 and G2, p=NR RDLS-Expressive: T2 G1>G2, p=NR ES=0.50 (d) RDLS-Receptive: T2 G1>G2, p=NR ES=0.63 (d)

a = intention-to-treat (ITT) analysis

b Odds ratio indicator of probability: no association is represented by 1, the greater the departure from 1 the stronger the relationship.

Abbreviations: ADGD = attention deficit hyperactivity disorder; G = group; Lab-TAB = Laboratory Temperament Assessment Battery; NA = not applicable; NR = not reported; OR = odds ratio; SOE = strength of evidence; T = time.

An article by Zeanah and colleagues129 reported psychiatric disorder outcomes using a caregiver report measure that queried the presence, frequency, duration, and age at onset of symptoms corresponding to those in the American Psychiatric Association Diagnostic and Statistical Manual.180 Scoring algorithms correspond to DSM diagnoses and to composite, categorical diagnoses, such as internalizing and externalizing disorders. Although externalizing disorders did not occur at significantly different rates, internalizing disorders were more common in institutional care group children and these children were also more likely to meet criteria for an anxiety disorder. No significant group differences were observed for attention deficit hyperactivity disorder, disruptive disorders, depressive disorder, or diagnostic comorbidity. Differences in internalizing disorders by gender were further explored by McLaughlin 2012, finding that among girls, those placed in foster care were less likely than the institutional group to have internalizing symptoms, internalizing disorders, anxiety, and depression. No differences were found by intervention group among males in internalizing. The foster care intervention had no effect on externalizing symptoms or on externalizing disorders in either girls or boys. In a paper examining psychiatric problems,118 Bos et al. reported reductions in stereotypic behaviors often observed in contexts of deprivation and institutionalization, with improvements favoring children in BEIP at all time points.

Three articles121,125,127 examined group differences in children’s attachment behavior and offered relatively consistent support for the ability to alter attachment through BEIP. Attachment was assessed using a structured procedure, known as the “Strange Situation,” in which the child experiences separations from and reunions with the parent that represent laboratory analogues of normative parent-child separations.181 At 42 months, children in BEIP improved significantly in the security and organization attachment relative to their institutionalized peers, more of whose attachment styles remained insecure and disorganized. Among children placed in foster care, girls were more likely to have an organized attachment (compared with atypical attachment) classification than boys, and more likely to have secure attachment (compared with not secure) than boys. Analysis by age at placement in foster care showed that using multiple cut points for age (placement points between 18 and 28 months of age), children placed earlier when compared with those placed later for all age cutoffs were significantly more likely to have an organized attachment. For secure versus insecure attachment, children placed before 24 months of age were more likely to have secure attachment than those placed in foster care after 24 months. Time in foster care was also significant, with children being placed for longer time in foster care more likely to have an organized attachment than those placed for a shorter time. Differences in attachment by gender were further explored by McLaughlin and colleagues, finding that among females, those placed in foster care were more likely than the institutional group to have secure attachment and change from insecure/incompletely formed to secure attachment.125 No differences were found by intervention group among males. Johnson and colleagues compared the quality of caregiving across study conditions. At 30 months and a combined 30/42 months, caregiving quality in BEIP outperformed the institutional care group.121 Higher caregiving quality was significantly associated with improvements in child height and weight.

Seven articles investigated the efficacy of BEIP in promoting children’s cognitive functioning and development.117,119,121,122,124,126,128 Nelson126 and Johnson121 compared children’s mental development and intellectual ability across study conditions. At 42 and 54 months, children in BEIP outperformed the institutional care group (medium effect sizes). Intellectual ability was also compared across study conditions when children were 8 years old.119 Children in BEIP outperformed the institutional care group in the verbal subscale. One article compared expressive and receptive language.128 At 30 months children in foster care outperformed the institutional group in receptive language, and by 42 months they outperformed the institutional group in receptive and expressive language. Placement age was significantly associated with both expressive and receptive language. Children placed by 15 months of age had higher receptive and expressive scores at 30 months than children placed later and outperformed the institutional care group, moreover, the expressive scores of children placed before 15 months were equivalent to never-institutionalized children. By 42 months, children placed before 24 months of age had longer utterances than children placed after 24 months and outperformed the institutional care group.

The sequelae of maltreatment and adversity can include impairments in critical aspects of executive functioning. These include attention and impulsivity, task accuracy and efficiency, and higher order cognitive functions, presumably related to interference of stress symptomatology. In an article by Ghera and colleagues,120 the authors examined children’s attention and affect. At 30 months, attention levels in the two groups did not differ significantly but by 42 months children in the BEIP condition had significantly higher attention levels than the children who remained in institutionalized care. Additionally, at both 30 and 42 months, children participating in BEIP displayed more positive affect; however, there was no significant difference between study arms in negative affect at any time point. Two articles117,123 analyzed executive functioning at age 8. Children in foster care outperformed the institutional care group in strategy abilities,117 accuracy,123 faster reaction time,123 and differential reactivity (better error related negativity difference score between correct and error trials of inhibitory control task). Neither group differed in their ability to inhibit responses.123

Another article122 investigated cognitive functioning at the neurophysiological level comparing electroencephalogram (EEG) band power and coherence (as indices of neurological maturation and cortical functioning) across the study conditions. EEG band power reflects the rhythmicity of the EEG signal across different frequencies. Coherence signifies the degree of synchronization between measurements from two different cortical areas; decreased coherence is thought to reflect greater brain complexity and differentiation. At 42 months, there were no significant differences between study conditions for band power or coherence. Additional analyses examined the interactions between EEG band power and coherence with age of foster placement. Differences in coherence were found for children placed in foster care earlier than 24 months but not for those placed later. EEG was also reported in relation to differential hemispheric activation.124 Frontal EEG asymmetry (FEA) with right greater than left activation is associated with internalizing psychopathology. Although there were no significant differences in frontal and parietal FEA between children placed in foster care and the institutional care group, FEA among children placed before 24 months of age showed a significantly more favorable growth trajectory of FEA than children placed after 24 months. In the area of physical growth, Johnson121 compared children’s height and weight across study conditions. Children in BEIP outperformed the institutional care group in mean growth and change in growth for height and weight from baseline to 42 months.

Although this study was a rated a low risk of bias and provided precise outcome estimates, we graded the SOE as low for the mental and behavioral health, caregiver-child relationship, and developmental outcomes due to the presence of a single study (Table 56).

Table 56 Detailed strength of evidence grading table: Bucharest early intervention project

Intervention and Comparator | Outcome | Studies; subjects | Risk of Bias | Consistency | Directness | Precision | SOE Grade; Magnitude of effect
BEIP vs. Institutional Care (usual care) | Mental and behavioral health | 1 RCT118,120,123,125,129; 136 | M | Unknown, single study | Direct | Precise | Low Odds Ratio 2.8 [95% CI 1.2 to 6.4]
BEIP vs. Institutional Care (usual care) | Healthy caregiver-child relationship | 1 RCT121,125,127; 136 | M | Unknown, single study | Direct | Precise | Low; NR
BEIP vs. Institutional Care (usual care) | Healthy development | 1 RCT117,119,121,122,124,126,128; 136 | M | Unknown, single study | Direct | Precise | Low; Effect Size=0.47 or 0.62

Abbreviations: BEIP = Bucharest Early Intervention Project; CI = confidence interval; M = medium; NR = not reported; RCT = randomized controlled trial; SOE = strength of evidence.

#### Fostering Healthy Futures

We identified one RCT (one article, Table 57)131 evaluating outcomes relevant to KQ 1 for the intervention Fostering Healthy Futures (FHF). The study compares FHF, a high-intensity intervention, with an inactive control group (assessment-only condition). The study targeted maltreated children placed in out-of-home care (age 9 to 11).

Table 57 Fostering healthy futures: Study characteristics

First Author et al., Year Country | Sample Description (Age Group) | Study Design and Duration | Comparison Groups | Baseline N | Risk of Bias
Taussig and Culhane, 2010^131^ United States | Children in foster care (ages 9 to 11 years) | RCT (approximately 9 months in duration) Postintervention: 11 to 13 months postbaseline Followup: 6-month postintervention end | G1: Fostering Healthy Futures G2: Inactive control | G1: 79 G2: 77 Overall N=156 | Low

Abbreviations: G = group; N = number; RCT = randomized controlled trial.

##### Key Points

- Mental and behavioral health: Compared with an inactive control, participants in FHF reported significantly greater reductions in trauma symptoms, dissociative symptoms, and quality of life (low SOE of benefit).131

##### Detailed Synthesis

Table 58 presents the results of the FHF trial reporting outcomes relevant to KQ 1;129 additional study details are provided in the evidence tables (Appendix E). The authors examined children’s trauma symptoms, coping skills, self-perceptions, and life satisfaction. Immediately following the intervention, participants in FHF reported significantly higher quality of life scores than youth in the control group (small effect size); no other significant differences emerged at postintervention. At followup, participants in FHF showed significantly greater improvements than youth in the control group on a composite mental health index representing child, teacher, and caregiver report of trauma symptoms and internalizing problems (medium effect size). Also at followup, participants in FHF reported significantly greater improvement in dissociative symptoms compared with youth in the control group (small effect sizes for both outcomes).

Table 58 Results: Fostering healthy futures versus inactive control

First Author et al., Year | Comparison Groups | Mental and Behavioral Health Outcomes
Taussig and Culhane, 2010^a,131^ | G1: Fostering Healthy Futures G2: Inactive Control | [underlined: Primary Outcomes] Multi-informant mental health index^a^ (composite of Trauma Symptoms Checklist and Internalizing Scales of Child Behavior Checklist and Teacher Report Form) T1: No difference between G1 and G2, p=0.66 T2: G1>G2, p=0.003; mean difference, −0.51 (95% CI, −0.84 to −0.19); d=−0.51 Improvements in trauma symptoms^a^ (Trauma Symptoms Checklist – Post-Traumatic Stress Scale) T1: No difference between G1 and G2, p=0.53 T2: G1>G2, p=0.07; mean difference, −2.79 (95% CI, −5.77 to 0.19); d=0.30 Improvements in dissociation^a^ (Trauma Symptoms Checklist – Dissociation Scale) T1: No difference between G1 and G2, p=0.44 T2: G1>G2, p=0.02; mean difference, −3.66 (95% CI, −6.58 to −0.74); d=0.39 Quality of life^a^ (Life Satisfaction Survey) T1: G1>G2, p=0.006; mean difference, 0.11 (95% CI, 0.03 to 0.19); d=0.42 T2: No difference between G1 and G2, p=0.38 [underlined: Secondary Outcomes] Positive and negative coping^a^ (both, Coping Inventory), Global self-worth, social acceptance (both, Self Perception Profile for Children), T1, T2: No differences between G1 and G2

a intention-to-treat (ITT) analysis

Note: Greater comparative benefit is denoted using a greater (“>”) sign. Cohen’s d effect size index of the difference between groups means: 0.20 = small; 0.50 = medium; 0.80 = large.176

Abbreviations: CI = confidence interval; G = group; SOE = strength of evidence; T = time

Although this study was a rated a low risk of bias and provided precise outcome estimates, we graded the SOE as low for mental and behavioral health outcomes due to the presence of a single study (Table 59).

Table 59 Detailed strength of evidence grading table: Fostering healthy futures

Intervention and Comparator | Outcome | Studies; subjects | Risk of Bias | Consistency | Directness | Precision | SOE Grade; Magnitude of Effect
Fostering Healthy Futures vs. Inactive Control | Mental and behavioral health | 1 RCT131; 156 | L | Unknown, Single Study | Direct | Precise | Low; small to medium (d=0.30 to 0.51)

Note: All results are G1>G2 unless otherwise noted. For estimation of the magnitude of effect, we include only the statistically significant (p<0.05) effect sizes provided by study authors and do not calculate effect sizes as part of our analysis. Interpretation of the effect size as small, medium, or large is defined as Cohen’s d = 0.20, 0.50, and 0.80.^176^

Abbreviations: L = low; RCT = randomized controlled trial; SOE = strength of evidence.

#### Middle School Success

We identified one RCT (two articles)136,137 comparing a low-intensity intervention with routine foster care (usual care). The study targeted older girls (age 10 to 12 years) in foster care (Table 60).

Table 60 Middle school success: Study characteristics

First Author et al., Year | Sample Description (Age Group) | Study Design and Duration^a^ | Comparison Groups | Baseline N | Risk of Bias
Smith et al, 2011^137^ | Girls in foster care (ages 10–12 years) | RCT 6 sessions over 3 weeks Follow-up 6 months postbaseline | G1: MSS G2: RFC | G1: 48 G2: 52 Overall N = 100 | Low
Kim and Leve 2011^136^ | Girls in foster care (ages 10–12 years) | RCT T1: Follow-up 6 months postbaseline^a^ T2: 12 months postbaseline T3: 36 months postbaseline | G1: MSS G2: RFC | G1: 48 G2: 52 Overall N = 100 | Medium

a In the paper, the authors define timepoints as baseline (T1) and followup at 6 months (T2), 12 months (T3), 24 months (T4), and 36 months (T5) postbaseline. We include only the followup timepoints for which KQ 1 outcome data are reported in the paper and renumbered the timepoints accordingly.

Abbreviations: G = group; MSS = Middle School Success; N = number; RCT = randomized controlled trial; RFC = regular foster care control group; T = time.

##### Key Points

- Mental and behavioral health: Compared with usual care, participants in the Middle School Success intervention experienced significantly greater reductions in internalizing problems, frequency of substance use, and use of tobacco and marijuana and significantly greater increases in prosocial behavior compared with youth in routine foster care (low SOE of benefit).

##### Detailed Synthesis

Table 61 presents the results of the Middle School Success trial;136,137 additional study details are provided in the evidence tables (Appendix E). In an article by Smith and colleagues,137 the authors examined parent report of child internalizing and externalizing problems as well as prosocial behavior through 6-months postbaseline. The study found that youth in the intervention condition had significant reductions in internalizing and externalizing problems at followup compared with the usual care, taking into account participants’ maltreatment history, pubertal development, and internalizing/externalizing problems at baseline. No significant group differences were found for prosocial behavior. In a second paper,136 the authors again collected caregiver report data on internalizing and externalizing symptoms and prosocial behavior (using different measures than in the first study). This paper also reports data on substance use and delinquency (behavior, association with a deviant peer, and a composite score based on the mean of girls’ own delinquent behavior and her association with delinquent peers), collected via child self-report. Significant group differences were found in favor of the Middle School Success intervention for prosocial behaviors at both 6- and 12-month followup. At 36 months, participants in the intervention reported less frequent substance use (composite score based on mean of tobacco, alcohol, and marijuana use) and were also less likely to report tobacco or marijuana use over the past 12 months compared with youth in usual care. There were no significant group differences in internalizing and externalizing symptoms or alcohol use; however, a trend in favor of the intervention condition over the control group was found for delinquent behavior and the composite delinquency score (in the prior year).

Table 61 Results: Middle school success

First Author et al., Year | Comparison Groups | Mental and Behavioral Health
Smith et al, 2011^137^ | G1: MSS G2: RFC | Internalizing/externalizing problems (Parent Daily Report Checklist) [underlined: Internalizing problems] G1 > G2, p<0.01 [underlined: Externalizing problems] G1 > G2, p< 0.01 [underlined: Prosocial behavior] No difference between G1 and G2, p=ns (NR)
Kim and Leve, 2011^136^ | G1: MSS G2: RFC | Internalizing and Externalizing Problems (Achenbach System of Empirically Based Assessment/ASEBA)^*^ T1, T2: No difference between G1 and G2, p=ns (NR) Prosocial behavior (Parent Daily Report)^*^ T1, T2: G1 > G2, p=0.03, d=0.46 Composite substance use (Self-Report)^*^ T3: G1 > G2, p<0.05, d=0.47 Tobacco use (Self-Report)^*^ T3: G1 > G2, p=0.04, d=0.46 Alcohol use (Self-Report)^*^ T3: No difference between G1 and G2, p=ns (NR) Marijuana use (Self-Report)^*^ T3: G1 > G2, p=−0.01, d=0.57 Delinquency (Self-Report Delinquency Scale)^*^ [underlined: Composite Delinquency] T3: No difference between G1 and G2, p=0.07, trend; d=0.39 [underlined: Delinquent Behavior] No difference between G1 and G2, p=0.098, trend; d=0.36 [underlined: Association with Deviant Peer] T3: No difference between G1 and G2, p=ns (NR), trend; d=0.35

Note: Greater comparative benefit is denoted using a greater (“>”) sign. Cohen’s d effect size index of the difference between groups means: 0.20 = small; 0.50 = medium; 0.80 = large.176

Abbreviations: MSS = Middle School Success; N = number; RCT = randomized controlled trial; RFC = regular foster care control group.

* = ITT analysis

We graded the SOE as low due to the presence of a single study (Table 62).

Table 62 Detailed strength of evidence grading table: Middle school success

Intervention and Comparator | Outcome | Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | SOE Grade; Magnitude of Effect
MSS vs. usual care | Mental and behavioral health | 1 RCT136,137; 100 | L/M | Unknown, single study | Direct | Precise | Low; small to medium (d=0.35 to 0.57)

Note: All results are G1>G2 unless otherwise noted. For estimation of the magnitude of effect, we include only the statistically significant (p<0.05) effect sizes provided by study authors and do not calculate effect sizes as part of our analysis. Interpretation of the effect size as small, medium, or large is defined as: Cohen’s d = 0.20, 0.50, and 0.80.^176^

Abbreviations: L = low; M = medium; MSS = Middle School Success; RCT = randomized controlled trial; SOE = strength of evidence.

#### Multidimensional Treatment Foster Care for Preschoolers

We identified five articles relevant to KQ 1 outcomes for a trial evaluation of Multidimensional Treatment Foster Care for Preschoolers (MTFC-P),138,139,141,142,179 comparing this high-intensity foster care intervention to usual care (Table 63). The study was targeted at young children (3 to 6 years of age), foster or kin caregiver, and permanent placement resource (birth parents and adoptive relatives or nonrelatives).

Table 63 Multidimensional treatment foster care for preschoolers: Study characteristics

First Author et al., Year Country | Sample Description (Age Group) | Study Design and Duration | Comparison Groups | Baseline N | Risk of Bias
Fisher et al,, 2007,^139^ Fisher et al., 2007,^142^ Fisher and Stoolmiller, 2008,^141^ and Bruce et al., 2009,^138^ Fisher et al., 2011^179^ United States | Children ages 3 to 6 years in new foster placement, expected duration >3 months | RCT 12 months^a^ | G1: MTFC-P G2 Usual care | G1: 57^a^ G2: 60^a^ | Medium

a Bruce et al., 2009 timing of assessment is not specified, G1: 10, G2: 13.

Abbreviations: G = group; MTFC-P = Multidimensional Treatment Foster Care for Preschoolers; NR = not reported; RCT = randomized controlled trial.

##### Key Points

- Mental and behavioral health: Children who participated in MTFC-P exhibited more normative (regulated) cortisol levels compared with children in usual foster care (low SOE of benefit).138,142,179
- Healthy caregiver-child relationship: Compared with usual care, children who participated in MTFC-P had significantly greater increases in secure attachment behavior and decreases in avoidant attachment behavior; additionally, caregivers who participated in MTFC reported significantly less stress related to child problem behaviors (low SOE of benefit).139,141
- Healthy development: Compared with usual care, children who participated in MTFC-P exhibited significantly higher levels of electrophysiological functioning during a cognitive task; however, there was no significant difference in efficacy of the intervention on cognitive functioning as measured by a behavioral assessment (low SOE of benefit).138

##### Detailed Synthesis

Table 64 presents the results of the MTFC-P trial in regards to KQ1 outcomes;138,139,141,142,179 additional study details are provided in the evidence tables. An article by Fisher and colleagues142 that examined cortisol regulation (morning level, evening level, and morning-to-evening change) found that children in MTFC-P were significantly more likely to exhibit a pattern of relative cortisol stability whereas the children in usual care exhibited a significant decline (medium effect sizes). Another paper179 examined cortisol regulation among children who had experienced a placement change and found that children in MTFC-P experienced more typical morning-to-evening cortisol levels (e.g., higher in the morning and lower in the evening) following a placement change than children in regular foster care following a placement change. Regular foster care subjects had relatively blunted cortisol patterns from morning to evening.

Table 64 Results: Multidimensional treatment foster care for preschoolers versus usual care

First Author et al., Year | Comparison Groups | Mental and Behavioral Health | Healthy Caregiver-Child Relationship | Healthy Development
Fisher and Kim, 2007^139^ | G1: MTFC-P G2: Usual care | NA | Improved Trajectory (Increase) in Secure Attachment Behavior (Parent Attachment Diary) G1>G2, p<0.05 Improved Trajectory (Decrease) in Avoidant Attachment Behavior (Parent Attachment Diary) G1>G2, p<0.05 Improved Trajectory (Decrease) in Resistant Attachment Behavior (Parent Attachment Diary) No difference between G1^+^ and G2^+^, p=NS(NR) | NA
Fisher et al., 2007^142^ | G1: MTFC-P G2: usual care | Decrease AM-PM Change in Diurnal Salivary Cortisol G1^ns^>G2: p=0.040, d=−0.64 Decrease AM Cortisol level G1^ns^ >G2, p=0.027, d=−0.66 Decrease PM Cortisol level G1^+^ >G2, p=0.019, d=−0.68 | NA | NA
Fisher and Stoolmiller, 2008^141^ | G1: MTFC-P G2: usual care | NA | Decrease in Caregiver Stress Related to Child Problem Behaviors (Parent Daily Report) T1: G1^+^ >G2, p=0.009 T2: No difference between group G1 and G2, p=0.734 | NA
Bruce et al., 2009^138^ | G1: MTFC-P G2: usual care | NA | NA | Cognitive Control and Response Monitoring (Flanker Task) Errors of Commission No difference between G1 and G2, p=NR(NS) Reaction Time No difference between G1 and G2, p=NS(NR)
Bruce et al., 2009^138^ (continued) | | | | EEG ERP in Response to Feedback Response Locked Components G1>G2, p<0.01 Feedback Locked Components G1>G2, p<0.01
Fisher et al., 2011^179^ | G1: MTFC-P G2: RFC | More typical patterns of morning-to-evening cortisol levels following placement changes G1>G2, p<0.001 | NA | NA

Note: Greater comparative benefit is denoted using a greater (“>”) sign. Cohen’s d effect size index of the difference between groups means: 0.20 = small; 0.50 = medium; 0.80 = large.176

Abbreviations: AM = ante meridiem; EEG = electroencephalogram; ERP = Event Related Potentials; G = group; MTFC-P = Multidimensional Treatment Foster Care for Preschoolers; NA = not applicable; NR = not reported; NS = not significant; PM = post meridiem; SOE = strength of evidence; T = time.

In other papers, Fisher and colleagues139,141 examined outcomes reflective of the caregiver-child relationship. Fisher and Kim,139 examined child attachment behavior as reported by the caregiver. The study found significant differences in report of increased secure attachment behaviors and decreased insecure-avoidant attachment behavior favoring the MTFC-P condition. No group differences were found for insecure-resistant behavior. In a second study examining caregiver-child relationship outcomes, Fisher and Stoolmiller179 found that caregiver report of stress in response to child problem behaviors showed significantly greater declines compared with usual care, with an early decline in stress during the initial 2 study months that remained stable over the ensuing 10 months.

A fifth article examined cognitive functioning across study conditions.138 The authors measured children’s behavioral performance during cognitive tasks (cognitive control and response monitoring) and electrophysiological response (a substrate of cognitive processing) to cognitive tasks. Participants in MTFC-P did not differ significantly from usual care children on tasks of self-monitoring (“errors of commission”) or reaction time to response. However, electrophysiological responses (measured by EEG) to external stimuli (“response locked” and “feedback locked” conditions) during cognitive tasks showed significant improvement for MTFC-P relative to usual care (response locked F=5.66, p<0.01; feedback locked, F=5.82, p<0.01).

We graded the SOE as low for the mental and behavioral health, caregiver-child relationship, and developmental outcomes due to the presence of a single study (Table 65).

Table 65 Detailed strength of evidence grading table: Multidimensional treatment foster care for preschoolers

Intervention and Comparator | Outcome | Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | SOE Grade; Magnitude of Effect
MTFC-P vs. usual care | Mental and behavioral health | 1 RCT;142 117 | M | Unknown, single study | Direct | Precise | Low; m(d=0.64 to 0.68)
MTFC-P vs. usual care | Healthy caregiver-child relationship | 1 RCT139,141; 117 | M | Unknown, single study | Indirect | Precise | Low; NR
MTFC-P vs. usual care | Healthy development | 1 RCT;138: 23 | M | Unknown, single study | Direct | Precise | Low; NR

Note: All results are G1>G2 unless otherwise noted. For estimation of the magnitude of effect, we include only the statistically significant (p<0.05) effect sizes provided by study authors and do not calculate effect sizes as part of our analysis. Interpretation of the effect size as small, medium, or large is defined as: Cohen’s d = 0.20, 0.50, and 0.80.

Abbreviations: M = medium; MTFC-P = Multidimensional Treatment Foster Care for Preschoolers; NR = not reported; RCT = randomized controlled trial; SOE = strength of evidence.

#### Enhanced Foster Care, Summary of Strength of Evidence Grades

We summarize the SOE grade for all enhanced foster care interventions in Table 66.

Table 66 Enhanced Foster Care Interventions: Summary strength of evidence for child well-being outcomes

Intervention (G1) | Comparison (G2) | Outcome | N Trials, Participants | Strength of Evidence Magnitude of Effect
Bucharest Early Intervention Project | Usual care (institutional care in Romania) | Mental and behavioral health | 1^118,120,123,125,129^; 136 | Low; odds ratio 2.8 [95%CI 1.2 to 6.4]
Bucharest Early Intervention Project | Usual care (institutional care in Romania) | Healthy caregiver-child relationship | 1^121,125,127^; 136 | Low; NR
Bucharest Early Intervention Project | Usual care (institutional care in Romania) | Healthy development | 1^117,119,121,122,124,126,128^; 136 | Low; effect size^a^ =0.47 or 0.62
Fostering Healthy Futures | Inactive control | Mental and behavioral health | 1^131^; 156 | Low; small to medium (d=0.30 to 0.51)
Middle School Success | Usual care | Mental and behavioral health | 1^136,137^; 100 | Low; small to medium (d=0.35 to 0.57)
Multi-dimensional Treatment Foster Care for Preschoolers | Usual care | Mental and behavioral health | 1^142,179^; 117 | Low; medium (d=0.64 to 0.68)
Multi-dimensional Treatment Foster Care for Preschoolers | Usual care | Healthy caregiver-child relationship | 1^139,141^; 117 | Low; NR
Multi-dimensional Treatment Foster Care for Preschoolers | Usual care | Healthy development | 1^138^; 23 | Low; NR

a Effect size measure is not specified, therefore we did not classify the magnitude of effect as small, medium, or large.

Note: All results are G1>G2 unless otherwise noted. For estimation of the magnitude of effect, we include only the statistically significant (p<0.05) effect sizes provided by study authors and do not calculate effect sizes as part of our analysis. Interpretation of the effect size as small, medium, or large is defined as: Cohen’s d = 0.20, 0.50, and 0.80.^176^

Abbreviations: CV = control videotape group; G = group; NR = not reported; RCT = randomized clinical trial; VI = videotape intervention.

## Key Question 2 Comparative Effectiveness of Interventions for Improving Child Welfare Outcomes

### Organization

As in KQ 1, we organize KQ 2 by intervention type (parenting, trauma-focused, and enhanced foster care approaches). We begin this section with a description of included studies and an accompanying table presenting the number of trials and articles investigating child welfare outcomes by intervention type. Next, for each subsection, we begin with an overview of key features of the evidence base for the intervention type and then present the findings for each intervention. Findings include very brief key points presenting the main findings for KQ outcomes and the corresponding strength of evidence (SOE) grade. Immediately following the key points is a detailed synthesis of the findings for each intervention, providing information about study characteristics, the specific results (including magnitude of effect, if provided by study authors), and the SOE by grading domain (risk of bias, consistency, directness, and precision). Please refer to the Strength of Evidence Grading section in the Methods chapter for further detail about the SOE grading criteria.

We remind the reader that benefit is denoted in the results tables using a greater (“>“) sign (e.g., Group 1 > Group 2). Also, the results tables present within-group changes denoted as improvement (“+”), detriment (“−”), or nonsignificant change (“ns”) for studies that provided these data.

### Parenting Interventions

#### Description of Included Studies

Table 67 presents the five trials (five articles) evaluating four parenting interventions included in KQ 2.

Table 67 Number of trials and articles investigating child welfare outcomes by intervention type

Parenting Intervention | Trials
Keeping Foster and Kinship Parents Trained and Supported92 | 1
Nurse Home Visitation Intervention93 | 1
Parent-Child Interaction Therapy Adaptation Package95,96 | 2
SafeCare100 | 1
Total | 5

Below we provide an overview of the key features in the body of evidence for parenting interventions.

- All five trials were randomized controlled trials (RCTs).
- Four trials were effectiveness trials.92,93,95,100
- Four of the trials targeted maltreating parents and assessed safety outcomes.93,95,96,100
- One trial targeted foster and kinship parents and assessed both placement stability and permanency outcomes.92
- All five trials compared the experimental intervention with usual care.92,93,95,96,100

#### Keeping Foster and Kinship Parents Trained and Supported

We identified one large RCT comparing the effectiveness of the Keeping Foster and Kinship Parents Trained and Supported (KEEP) intervention with a usual care group for improving child welfare outcomes (Table 68).92 This RCT also reported outcomes relevant to KQ 1 (see previous section of Results chapter).

Table 68 Keeping foster and kinship parents trained and supported: Study characteristics

First Author et al., Year Country | Sample Description (Age Group) | Study Design and Duration | Comparison Groups | Baseline N | Risk of Bias
Price et al., 2008^92^ United States | Foster children ages 5 to12 years. Placed ≥30 days | RCT Placement status assessed at intervention end or 2 to 11 months postbaseline (if child exited current placement prior to intervention end) Child exits within 200 days (approximately 6.5 months) postbaseline | G1: KEEP G2: usual care | G1: 359 G2: 341 Overall N = 700 | Medium

Abbreviations: G = group; KEEP = Keeping Foster and Kinship Parents Trained and Supported; N = number; RCT = randomized controlled trial.

##### Key Points

- Placement stability: Comparing usual care with KEEP, there was no difference in placement stability outcomes in one trial (insufficient evidence).92
- Permanency: Compared with usual care, participants in KEEP had a significantly greater proportion of positive exits from foster care (e.g., reunification with biological parent or another relative or adoption for the duration of the study period) (moderate SOE for benefit).92

##### Detailed Synthesis

Table 69 presents the results for the KEEP trial; additional study details are provided in the evidence tables (Appendix E).92 Using child welfare records, the study authors examined negative placement changes (e.g., child being moved to a new foster care placement, a more restrictive environment such as psychiatric care or juvenile detention center, or child runaways), as a measure of placement instability. The authors also examined positive placement changes, defined as positive exits from foster care such as reunification with the biological parent or another relative or adoption. Although these positive placement exits were not identified as permanency outcomes in the study, we categorized them as such here with the caveat that they were outcomes sustained for the duration of the study. Results from Cox hazard models revealed children in KEEP were nearly twice as likely to exit their foster or kinship placement home for positive reasons compared with those in the usual care group. This finding was for the full sample, which included children with as many as 20 previous placements. Rates of negative placement changes were not significantly different between the two groups. However, the study found that number of previous placements was a significant predictor of hazard of placement disruption (i.e., negative exit) and that the intervention “mitigated the negative risk-enhancing effect of a history of multiple placements.” The authors also found that children living with a relative (kinship placement) and those with longer placements were less likely to have any placement change during the intervention period.

Table 69 Results: Keeping foster and kinship parents trained and supported versus usual care

First Author et al., Year | Comparison Groups | Placement Stability | Permanency
Price et al., 2008^92^ | G1: KEEP G2: Usual care | Percentage with Negative Placement Change No difference between G1 and G2, p=ns (NR) | Percentage with Positive Placement Exit G1 > G2, p=0.005

Note: Greater comparative benefit is denoted in the results tables using a greater (“>“) sign.

Abbreviations: G = group; KEEP = Keeping Foster and Kinship Parents Trained and Supported; NR = not reported; ns = not significant.

Although the body of evidence is limited to a single study for KEEP, we graded the SOE as moderate for positive permanency outcomes due to the size of the study and because it was an effectiveness trial (Table 70). We graded the SOE as insufficient for placement stability due to nonsignificant findings.

Table 70 Detailed strength of evidence grading table: Keeping foster and kinship parents trained and supported

Intervention and Comparator | Outcome | Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | SOE Grade; Magnitude of Effect
KEEP vs. usual care | Placement stability | 1 RCT;92 700 | M | Unknown, single study | Direct | Imprecise | Insufficient
KEEP vs. usual care | Permanency | 1 RCT;92 700 | M | Unknown, single study | Direct | Precise | Moderate; NR

Note: All results are G1>G2 unless otherwise noted. For estimation of the magnitude of effect, we include only the statistically significant (p<0.05) effect sizes provided by study authors and do not calculate effect sizes as part of our analysis.

Abbreviations: KEEP = Keeping Foster and Kinship Parents Trained and Supported; M = medium; NR = not reported; RCT = randomized controlled trial; SOE = strength of evidence.

#### Nurse Home Visitation Intervention

We identified one RCT comparing the effectiveness of a nurse home visitation (NHV) intervention with a usual care group for improving child welfare outcomes (Table 71).93 This RCT also reported outcomes relevant to KQ 1 (see previous section of Results chapter).

Table 71 Nurse home visitation intervention: Study characteristics

First Author et al., Year County | Sample Description (Age Group) | Study Design and Duration | Comparison Groups | Baseline N | Risk of Bias
MacMillan et al., 2005^93^ Canada | Physically abused or neglected children 13 years and younger and their primary caregivers | RCT T1: 1 year postbaseline T2: 2 years postbaseline T3: 3 years postbaseline | G1: NHV G2: usual care | G1: 89 G2: 74 Overall N=163 | Low

Abbreviations: G = group; N = number; NHV = nurse home visitation intervention; T = time

##### Key Points

- Safety: Compared with usual care, there was no significant difference in efficacy of the intervention on maltreatment recurrence based on Child Protective Services (CPS) records whereas hospital records showed significantly higher rates of recidivism for the NHV condition compared with usual care (insufficient SOE).93

##### Detailed Synthesis

Table 72 presents the results of the NHV trial for child welfare outcomes;93 additional study details are provided in the evidence tables (Appendix E). The authors used both CPS records and hospital records to assess safety outcomes. Based on the CPS data, no significant differences emerged in favor of the NHV on any of the safety measures: incidence of physical abuse, days to first incident of physical abuse, or severity of physical abuse incidents. There was a borderline significant difference between the intervention and comparison groups in the severity of neglect incidents, favoring the intervention group; however, the authors indicate that the difference was not clinically important. The no-difference finding using the CPS data was not consistent with hospital data, which showed the recurrence of physical abuse and/or neglect was significantly more likely in the NHV group than the usual care group (23.6% versus 10.8%). The authors suggest this finding may be the result of detection bias as a function of the nurse home visitors “identifying the need for medical care in children in the visited families.” The authors also note that “the potential for harm should not be overlooked” but that the finding related to the hospital data needs to be “taken in the context of….no clinically meaningful differences between groups” based on child welfare records.

Table 72 Results: Nurse home visitation intervention versus usual care

First Author et al., Year | Comparison Groups | Safety
MacMillan et al., 2005^93^ | G1: NHV G2: Usual care | Incidence of physical abuse and/or neglect, days to first incident of physical abuse or neglect, severity of physical abuse All, p=ns (NR) Severity of neglect G1 > G2, p=0.053 Recurrence of physical abuse or neglect G1<G2, p=NR (sig); 23.6% vs. 10.8%, difference 12.8% [95% CI, 1.4 to 24.1]

Note: Greater comparative benefit is denoted in the results tables using a greater (“>“) sign.

Abbreviations: CI = confidence interval; G = group; NHV = nurse home visitation intervention; NR = not reported; ns = not significant; sig = significant.

We graded the SOE for this effectiveness trial as insufficient due to conflicting evidence on safety outcomes depending on the measure (Table 73).

Table 73 Detailed strength of evidence grading table: Nurse home visitation intervention

Intervention and Comparator | Outcome | Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | SOE Grade; Magnitude of Effect
NHV vs. Usual care | Safety | 1,^93^ 163 | M | Unknown, single study | Direct | Imprecise | Insufficient

Abbreviations: M = medium; NHV = nurse home visitation intervention; SOE = strength of evidence.

#### Parent-Child Interaction Therapy Adaptation Package

We identified two RCTs evaluating an adaptation of PCIT for maltreating parents that combined PCIT with a self-motivational orientation intervention (the combined approach is referred to here as a PCIT Adaptation “Package” or PCIT-AP) (Table 74).95,96 The first trial96 was an efficacy study comparing PCIT-AP with a standard parenting program (usual care) for child welfare–involved clients and with an “enhanced” version of the experimental intervention that also provided families with individualized services and home visits to reinforce skills learned during the clinical sessions. The study targeted physically abusive caregivers and their children, age 4 to 12 years; many families had histories of multiple reports to CPS and severe parent-to-child violence. The second RCT95 was an effectiveness study examining the relative effects of the PCIT and the motivational intervention components compared with the usual care (standard orientation and parenting program). This study targeted physically abusive or neglecting caregivers and their children, age 2.5 to 12 years, as long as the caregiver had access to the child. The standard parenting program was developed at the provider agency and comprised three modules: (a) an orientation group to introduce parents to agency services and provide information about listening skills, how parenting practices influence children, and how the parents’ own upbringing has influenced the way in which they discipline and parent their children; (b) a parenting-skills group in which parents learned about child development, discipline, praise, behavior management, communication strategies, stress management, and the ways in which parental problems affect children; and (c) an anger management group. The overall approach relied on discussions of how parenting was conceptualized by the parent, identifying and regulating emotions, and verbal problem solving.

Table 74 Parent-child interaction therapy adaptation package: Study characteristics

First Author et al., Year Country | Sample Description (Age Group) | Study Design and Duration | Comparison Groups | Baseline N | Risk of Bias
Chaffin, 2004^96^ United States | Physically abused children ages 4 to 12 years and their caregivers | RCT Median follow-up time=850 days postbaseline | G1: PCIT-AP G2: PCIT-AP enhanced G3: SAU | G1: 42 G2: 33 G3: 35 Overall N=110 | Medium
Chaffin, 2011^95^ United States | Neglected or physically abused children ages 2.5 to 12 years and their caregivers | RCT Median follow-up time=904 days postbaseline | G1: PCIT-AP G2: SM + SAU parenting program G3: PCIT + SAU orientation G4: Usual care | G1: 34 G2: 41 G3: 36 G4: 42 Overall N=153^a^ | Low

a Initial randomization to the orientation group conditions: N=192.

Abbreviations: G = group; N = number; PCIT-AP = Parent-Child Interaction Therapy Adaptation Package (i.e., PCIT combined with self-motivational orientation); RCT = randomized controlled trial; SAU = services as usual (community standard orientation + parenting program); SM = self-motivational orientation.

##### Key Points

- Safety
  ○ An efficacy trial showed benefit for PCIT-AP compared with services as usual in reducing child maltreatment recidivism (reports to the child welfare system).96 In a second RCT that was an effectiveness trial, there was not a significant difference between PCIT-AP and usual care in recidivism, although a trend was found in favor of the intervention (low SOE of benefit).95
  ○ An enhanced version of the intervention that provided individualized services and home visits showed no significant difference in efficacy on recidivism compared with PCIT-AP (insufficient SOE).96
  ○ In an effectiveness trial, PCIT–AP resulted in significantly reduced recidivism compared with the community standard parenting program combined with the experimental self-motivational orientation (low SOE).95
  ○ In an effectiveness trial, PCIT-AP resulted in significantly reduced recidivism compared with PCIT combined with the community standard orientation (low SOE).95

##### Detailed Synthesis

Table 75 presents the results of the two PCIT-AP trials;96 additional study details are provided in the evidence tables (Appendix E). In the first trial, Chaffin and colleagues96 analyzed recidivism using survival analysis (length of time to event-free survival) and found the PCIT-AP condition was more efficacious than usual care. The authors also found there was no statistically significant difference between the enhanced condition and either usual care or PCIT-AP, although there was a trend for PCIT-AP to have better survival than the enhanced PCIT condition. The second trial, an effectiveness study,95 again examined survival outcomes and found that the combination of PCIT and the self-motivational intervention resulted in significantly reduced recidivism rates compared with services as usual. The authors reported outcomes using a primary model with observed risk intervals and also an imputed event history model where there was imputation on survival outcomes during only risk-deprived intervals (i.e., times when the child was not with the caregiver). Findings were comparable across modeling approaches, with the greatest benefit for children living at home or who had returned to their home earlier rather than later.

Table 75 Results: Parent-child interaction therapy adaptation package versus variant versus usual care

First Author et al., Year | Comparison Groups | Safety
Chaffin, 2004^96^ | G1: PCIT-AP G2: PCIT-AP enhanced G3: SAU | Recurrence of Maltreatment^a^ G1>G3, p=0.02 No difference between G1 and G2, p=0.13 No difference between G2 and G3, p=ns [NR]
Chaffin, 2011^95^ | G1: PCIT-AP G2: SM + SAU parenting program G3: SAU orientation + PCIT G4: SAU | Recurrence of maltreatment (adjusted for risk deprivation)^a^ G1>G2, HR=0.10, p<0.05^b^ G1>G3, HR=0.11, p<0.05^c^ G1>G4, HR=0.20, p=NR, trend^c^

a Intention-to-treat (ITT) analysis

b Point estimate, standard error, and confidence interval of hazard ratio not provided by authors.

c The authors present model estimated Cox regression curves for the four study groups showing the expected survival of all participants who were at risk for an event during the entire follow-up interval. The authors provide the hazard ratio but not confidence intervals for the survival curves and describe a “sizable trend” in regards to the benefit of PCIT-AP over standard services (orientation and parenting program).

Note: Greater comparative benefit is denoted in the results tables using a greater (“>“) sign.

Abbreviations: G = group; HR =hazard ratio; NR = not reported; NS = not significant; PCIT-AP = Parent-Child Interaction Therapy Adaptation Package (i.e., PCIT combined with self-motivational orientation); SAU = services as usual (community standard orientation + parenting program); SM = self-motivational orientation.

The authors also examined the relative effects of PCIT and the self-motivational orientation by contrasting varying combinations of experimental and usual care service components (again, see Table 75). The results, which showed benefit for PCIT-AP over other combinations, suggest a “synergistic” effect of combining PCIT with a motivational intervention in reducing future child abuse reports.

We graded the SOE as low for PCIT-AP compared with usual care in improving child welfare outcomes based on the results of two studies, one of which was an effectiveness trial, demonstrating precise estimates for direct outcomes and consistent benefit in favor of the intervention across studies (Table 76). We graded the SOE as insufficient for addressing child welfare outcomes for PCIT-AP compared with an enhanced version due to nonsignificant findings. We also graded the SOE as insufficient for PCIT-AP enhanced compared with usual care, again, due to nonsignificant findings.

Table 76 Detailed strength of evidence grading table: Parent-child interaction therapy adaptation package

Intervention and Comparator | Outcome | Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | SOE Grade; Magnitude of Effect
PCIT-AP vs. usual care | Safety | 2;^95,96^ 153 | L/M | Consistent | Direct | Precise | Low; NR^a^
PCIT-AP vs. PCIT-AP Enhanced^b^ | Safety | 1;^96^ 75 | M | Unknown, single study | Direct | Imprecise | Insufficient
PCIT-AP Enhanced^b^ vs. usual care | Safety | 1;^96^ 88 | M | Unknown, single study | Direct | Imprecise | Insufficient

a Chaffin et al, 2011 reports a hazard ratio but it is not statistically significant (i.e., reported as a trend).

b ”Enhanced” refers to the provision of individualized services to the parents.

Note: All results are G1>G2 unless otherwise noted. For estimation of the magnitude of effect, we include only the statistically significant (p<0.05) effect sizes provided by study authors and do not calculate effect sizes as part of our analysis.

Abbreviations: L = low; M = medium; NR = not reported; PCIT-AP = Parent-Child Interaction Therapy Adaptation Package (i.e., PCIT combined with self-motivational orientation); SOE = strength of evidence.

#### SafeCare

We identified one large RCT comparing the effectiveness of SafeCare with usual care for improving child welfare outcomes (Table 77).100 The study targeted children and their maltreating parents (nonsexual abusers) living in six CPS administrative regions in one state who were involved in community home-based services provided by CPS contract agencies. In the first stage of a nested design, the six regions were randomly assigned to SafeCare or services as usual (SAU) conditions, both of which utilized home visitors. A second stage assigned home visitors to a coached or uncoached condition (as an implementation quality control strategy). SafeCare and SAU services were comparable with the exception of the SafeCare modules (e.g., home visitors across study conditions had similar caseloads, qualifications, and funding, and service administrative goals were comparable). The mean duration of both conditions was 6 months, with SafeCare involving at least weekly home visits and the SAU group receiving monthly home visits. Participants were children up to 12 years of age, with the majority (76%) of preschool age. The usual SafeCare inclusion criteria of a preschool-aged child and absence of untreated parental substance abuse disorder were suspended for this study; the intervention itself was not changed.

Table 77 SafeCare: Study characteristics

First Author et al., Year | Sample Description (Age Group) | Study Design and Duration | Comparison Groups | Baseline N | Risk of Bias
Chaffin et al., 2012^100^ United States | Children up to age 12 and caregivers involved in home-based care through Child Protective Services (mean age, SD, NR) | RCT Average time to followup = 6 years | G1: SafeCare G2: SAU | G1: 1153 G2: 1022 Overall N = 2175 | Low

Abbreviations: G = group; N = number; RCT = randomized controlled trial; SAU = services as usual; SD = standard deviation.

##### Key Points

- Safety: SafeCare resulted in significantly reduced child maltreatment recidivism (reports to the child welfare system) compared with usual care.100

##### Detailed Synthesis

Table 78 presents the results of the SafeCare trial;100 additional study details are provided in the evidence tables (Appendix E). The primary outcome of interest was child maltreatment recidivism in the form of repeat reports to CPS. Data relevant to KQ 1 were collected but not reported as group contrasts. The authors used two strategies of propensity stratification to equalize differences across home visitors (creating home visit case pairings). The first strategy “divided Cartesian propensity score plots into 4 quadrants plus a central area.” The one quadrant that was unbalanced was dropped. The authors refer to this as the “4-strata solution,” which captured 185 of 219 home visitors and 2,035 of 2,175 cases. The second approach used coarsened exact matching (CEM), which “coarsens or bins continuous variables that otherwise are difficult to match exactly, then seeks exact matches, yielding more homogenous strata but at the expense of excluding cases.” This approach resulted in a 6-strata CEM solution, which matched 68 home visitors and 959 cases. Survival analysis of time to maltreatment recidivism indicated a main effect for SafeCare (regardless of coaching) relative to the SAU (regardless of coaching) across the entire study population (i.e., across all ages) and also for the preschool-age subpopulation. Based on the resulting hazard ratios, the authors estimated that SafeCare would prevent 64 to 104 first-year recurrences per 1,000 treated cases. Although not directly related to the comparisons of interest, two points should be noted. First, intervention compliance was similarly high across conditions and those receiving a higher intervention dosage, regardless of group assignment, recidivated at lower levels. Second, the study showed a main effect for the benefit of coaching (for the full population using the 4-strata approach); however, the findings were reported only at the level of coaching (yes or no) and not at the level of four-way contrasts (i.e., SafeCare with or without coaching compared with SAU with or without coaching). Therefore, these data are not presented in results table.

Table 78 Results: SafeCare versus usual care

First Author et al., Year | Comparison Groups | Safety
Chaffin, et al., 2012^96^ | G1: SafeCare G2: SAU | CPS Recidivism^*^ 4-strata pooled effect: G1 > G2, p = 0.03 (full population) Estimate=−0.186 (SE=0.087), HR=0.83 [95% CI, 0.70 to 0.98] G1 > G2, p = 0.016 (preschool subpopulation) Estimate=−0.301 (SE=0.125), HR=0.74 [95% CI, 0.58 to 0.95] Coarsened Exact Matching (CEM): G1 > G2, p = 0.001 (full population) Estimate=−0.181 (SE=0.056), HR=0.83 [95% CI, 0.75 to 0.93] G1 > G2, p < 0.005 (preschool subpopulation) Estimate=−0.241 (SE=0.086), HR=0.79 [95% CI, 0.66 to 0.93]

Note: Greater comparative benefit is denoted in the results tables using a greater (“>“) sign.

Abbreviations: CI = confidence interval; CPS = Child Protective Services; G = group; HR = hazard ratio; SE = standard error;

* = ITT analyses

Although the body of evidence regarding the comparisons studied is limited to a single trial for SafeCare, we graded the SOE as moderate for child welfare outcomes due to the size of the study and because it was an effectiveness trial (Table 79).

Table 79 Detailed strength of evidence grading table: SafeCare

Intervention and Comparator | Outcome | Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | SOE Grade; Magnitude of Effect
SafeCare vs. Usual Care | Safety | 1;^100^ 2175 | L | Unknown, single study | Direct | Precise | Moderate; HR=0.74 to 0.83

Note: All results are G1>G2 unless otherwise noted. For estimation of the magnitude of effect, we include only the statistically significant (p<0.05) effect sizes provided by study authors and do not calculate effect sizes as part of our analysis.

Abbreviations: L = low; HR = hazard ratio; SOE = strength of evidence.

#### Parenting Interventions, Summary Strength of Evidence Grades

We summarize the SOE grade for all parenting interventions in Table 80.

Table 80 Parenting interventions: Summary strength of evidence for child welfare outcomes

Intervention (G1) | Comparison (G2) | Outcome | N Trials, Participants | Strength of Evidence; Magnitude of Effect
Keeping Foster and Kinship Parents Trained and Supported | Usual care | Placement Stability | 1^91^; 700 | Insufficient
Keeping Foster and Kinship Parents Trained and Supported | Usual care | Permanency | 1^91^; 700 | Moderate; NR
Nurse Home Visitation Intervention | Usual care | Safety | 1^93^; 163 | Insufficient
PCIT Adaptation Package | PCIT Adaptation Package enhanced^a^ | Safety | 1^96^; 75 | Insufficient
PCIT Adaptation Package | Usual care | Safety | 2^95,96^; 153 | Low; NR^b^
PCIT Adaptation Package enhanced^a^ | Usual care | Safety | 1^96^; 88 | Insufficient
SafeCare | Usual Care | Safety | 1,^100^ 2175 | Moderate; HR=0.74 to 0.83

a ”Enhanced” refers to the provision of individualized services to the parents.

b Chaffin et al, 2011 reports a hazard ratio but it is not statistically significant (i.e., reported as a trend).

Note: Greater comparative benefit is denoted using a greater (“>“) sign. All results are G1>G2 unless otherwise noted. For estimation of the magnitude of effect, we include only the statistically significant (p<0.05) effect sizes provided by study authors and do not calculate effect sizes as part of our analysis. Authors do not report effect sizes for some of the outcomes presented in this table.

Abbreviations: HR = hazard ratio; NR = not reported; PCIT = Parent-Child Interaction Therapy.

### Trauma-Focused Treatments

We did not identify any trauma-focused treatments that assessed KQ 2 outcomes, as their focus is ameliorating children’s mental and behavioral symptoms.

### Enhanced Foster Care Interventions

#### Description of Included Studies

Table 81 presents the four trials (six articles) evaluating enhanced foster care interventions included in KQ 2.

Table 81 Number of trials and articles investigating child welfare outcomes by intervention type

Enhanced Foster Care Interventions | Trials
Fostering Healthy Futures132 | 1
Middle School Success136 | 1
Multidimensional Treatment Foster Care for Preschoolers140,143 | 1^b^
New Orleans Intervention130 | 1
Total | 4

b Reported in two articles.

Below we provide an overview of the key features in the body of evidence for parenting interventions.

- Three of the trials were RCTs132,136,140,143; the other was a nonconcurrent cohort study.130
- None of the trials were effectiveness trials.
- One intervention targets the child only.132
- All four trials target particular age subgroups:
  ○ Two in early childhood.130,140,143
  ○ One in middle childhood.132
  ○ One in early adolescence.136
- One trial compares the experimental intervention with an inactive control group (assessment only).132
- Three studies compare the experimental intervention with a usual care group.130,136,140,143,144
- One study reported safety outcomes.130
- Two trials reported placement stability outcomes.132,136
- Three studies reported permanency outcomes.130,140,143

#### Fostering Healthy Futures

We identified one RCT (one article) comparing Fostering Healthy Futures (FHF) with an inactive control (an assessment-only group) for improving child welfare outcomes (Table 82).132 This RCT also reported outcomes relevant to KQ 1 (see previous section of Results chapter). This article reports placement changes, placement in residential treatment facilities (a negative placement outcome), and permanency outcomes (attainment; type) among maltreated youth age 9 to 11 in foster care.

Table 82 Fostering healthy futures: Study characteristics

First Author et al., YearCountry | Sample Description (Age Group) | Study Design and Duration | Comparison Groups | Baseline N | Risk of Bias
Taussig et al., 2012^132^ United States | Children in foster care (ages 9 to 11 years) | RCT (approximately 9 months in duration) Postintervention: 11 to 13 months postbaseline Followup: 6-month postintervention end | G1: Fostering Healthy Futures G2: Inactive control | G1: 56 G2: 54 Overall N=110 | Low

Abbreviations: G = group; N = number; RCT = randomized controlled trial.

##### Key Points

- Placement stability:
  ○ No significant difference in efficacy of FHF on placement changes was found for the total sample; however, among children in nonrelative foster care, participants in FHF had fewer placement changes compared with an inactive control (low SOE for benefit).132
  ○ Participants in FHF were less likely to be placed in a residential treatment center compared with an inactive control; similar results in favor of FHF were shown for the subsample of children placed in nonrelative foster care (low SOE for benefit).132
- Permanency:
  ○ No significant difference in efficacy of FHF on permanency was found for the total sample; however, among children placed in nonrelative foster care, participants in FHF were more likely to attain permanency compared with an inactive control.132
  ○ Participants in FHF without termination of parental rights or in foster care were more likely to be reunified compared with their counterparts in an inactive control group (low SOE of benefit).132

##### Detailed Synthesis

Table 83 presents the results of the FHF trial reporting outcomes relevant to KQ 2;132 additional study details are provided in the evidence tables (Appendix E). The authors examined whether children experienced a new placement in a residential treatment center, whether children attained permanency (using case closure as the index of permanency), and type of permanency (adoption or reunification with biological parents). At least a quarter of all children in the sample had been to a residential treatment center before receiving the intervention (children in residential treatment centers, a type of psychiatric facility for youth and children, are likely to receive psychotropic medications and several types of psychotherapeutic interventions). Controlling for preintervention placement in a residential treatment center, along with several other covariates (type of baseline placement and baseline externalizing behavior problems), the study found no statistically significant difference between groups for number of placement changes or attainment of permanency, although findings were in the expected direction in favor of the FHF. Descriptive analyses showed that most of the children who were living with a relative (kinship care) at baseline experienced few placement changes, were not subsequently placed in a residential treatment center, and achieved permanence within the study period. Thus, the authors did subgroup analyses on the children living in nonrelative foster care as they represented a group more likely to have unstable placements. Among this subgroup, the study found significant benefit for FHF on placement changes, residential treatment center placement, and permanency outcomes. Treatment effects on reunification were estimated for the subsample of youth whose parental rights had not been terminated; a greater proportion of FHF participants, both across the total sample and for the subsample of youth in foster care, had reunified 1-year postintervention compared with the control youth. Treatment effects on adoption could not be calculated because of the small number of cases per cell.

Table 83 Results: Fostering healthy futures versus inactive control

First Author et al., Year | Comparison Groups | Placement | Permanency
Taussig et al., 2012^132^ | G1: Fostering Healthy Futures G2: Inactive control | Placement Stability^a^ [underlined: Total sample]: No difference between G1 and G2, p=0.17 [underlined: Foster care]: G1 > G2, p=0.03, OR=0.56 [95% CI, 0.34 to 0.93] Residential Treatment Center Placement^b^ [underlined: Total sample]: G1 > G2, p=0.04, OR=0.29 [95% CI, 0.09 to 0.98] [underlined: Foster care]: G1 > G2, p=0.03, OR=0.18 [95% CI, 0.03 to 0.96] | Permanency Attained^b^ [underlined: Total sample] No difference between G1 and G2, p=0.17 [underlined: Foster care] G1 > G2, p=0.005, OR=5.14 [95% CI, 1.55 to 17.07] Type of Permanency Outcome^b^ [underlined: Reunification among youth without termination of parental rights] G1 > G2, p<0.05^a^ [underlined: Reunification among youth in foster care]: G1 > G2, p=0.03^a^

a The authors report only p value and not odd ratios for these outcomes.

b intention-to-treat (ITT) analysis

Note: Greater comparative benefit is denoted in the results tables using a greater (“>“) sign.

Abbreviations: CI = confidence interval; G = group; OR = odds ratio.

Although this study was rated as low risk of bias and provided precise outcome estimates, we graded the SOE for the FHF intervention as low for child welfare outcomes due to the presence of a single study (Table 84).

Table 84 Detailed strength of evidence grading table: Fostering healthy futures

Intervention and Comparator | Outcome | Studies; subjects | Risk of Bias | Consistency | Directness | Precision | SOE Grade; Magnitude of effect
Fostering Healthy Futures vs. inactive control | Placement stability | 1;^132^ 110 | L | Unknown, single study | Direct | Precise | Low OR=0.18 to 0.56
Fostering Healthy Futures vs. inactive control | Permanency | 1;^132^ 110 | L | Unknown, single study | Direct | Precise | Low OR=5.14

Note: All results are G1>G2 unless otherwise noted. For estimation of the magnitude of effect, we include only the statistically significant (p<0.05) effect sizes provided by study authors and do not calculate effect sizes as part of our analysis.

Abbreviations: L = low; OR = odds ratio; SOE = strength of evidence.

#### Middle School Success

We identified one RCT (one article) comparing Middle School Success with routine foster care (Table 85).136 This RCT also reported outcomes relevant to KQ 1 (see previous section of Results chapter). The study reports placement changes at two follow-up timepoints among girls age 10 to 12 in foster care.

Table 85 Middle school success: Study characteristics

First Author et al., Year | Sample Description (Age Group) | Study Design and Duration^a^ | Comparison Groups | Baseline N | Risk of Bias
Kim & Leve 2011^136^ | Girls in foster care (ages 10–12 years) | RCT T1: Followup 6 months postbaseline^a^ T2: 12 months postbaseline | G1: MSS G2: RFC | G1: 48 G2: 52 Overall N = 100 | Low

a In the paper, the authors define timepoints as baseline (T1) and followup at 6 months (T2), 12 months (T3), 24 months (T4), and 36 months (T5) postbaseline. We include only the followup timepoints for which KQ 2 outcome data are reported in the paper and renumbered the timepoints accordingly.

Abbreviations: G = group; MSS = Middle School Success; N = number; RCT = randomized controlled trial; RFC = regular foster care control group.

##### Key Points

- Placement stability: Compared with usual care, participants in the Middle School Success intervention experienced significantly fewer placement changes compared with youth in routine foster care (low SOE of benefit).136

##### Detailed Synthesis

Table 86 presents the results of the Middle School Success trial reporting outcomes relevant to KQ 2;136 additional study details are provided in the evidence tables (Appendix E). The authors examined whether girls in the intervention experienced fewer placement changes based on data from child welfare system records collected from baseline through 12-month followup. The study found a significant group difference at both the 6- and 12-month follow-up timepoints in favor of the intervention.

Table 86 Results: Middle school success

First Author et al., Year | Comparison Groups | Mental Health Outcomes
Kim & Leve, 2011^136^ | G1: MSS G2: RFC | Placement Changes^a^ T1, T2: G1 > G2, p=0.02, d=0.50

a intention-to-treat (ITT) analysis

Note: Greater comparative benefit is denoted using a greater (“>“) sign. Cohen’s d effect size index of the difference between groups means: 0.20 = small; 0.50 = medium; 0.80 = large.176

Abbreviations: G = group; MSS = Middle School Success; RFC = regular foster care control group; T = time.

Although this study was rated as low risk of bias and provided precise outcome estimates, we graded the SOE for the Middle School Success intervention as low for child welfare outcomes due to the presence of a single study (Table 87).

Table 87 Detailed strength of evidence grading table: Middle school success

Intervention and Comparator | Outcome | Studies; subjects | Risk of Bias | Consistency | Directness | Precision | SOE Grade; Magnitude of Effect
Middle School Success vs. routine foster care | Placement stability | 1;^136^, 100 | L | Unknown, single study | Direct | Precise | Low, medium(d=0.50)

Note: All results are G1>G2 unless otherwise noted. For estimation of the magnitude of effect, we include only the statistically significant (p<0.05) effect sizes provided by study authors and do not calculate effect sizes as part of our analysis. Interpretation of the effect size as small, medium, or large is defined as: Cohen’s d = 0.20, 0.50, and 0.80.^176^

Abbreviations: L = low; SOE = strength of evidence.

#### Multidimensional Treatment Foster Care for Preschoolers

We identified one RCT comparing the effectiveness of Multidimensional Treatment Foster Care for Preschoolers (MTFC-P) with usual care for improving child welfare outcomes (Table 88).140,143,144 This RCT also reported outcomes relevant to KQ 1 (see previous section of Results chapter).

Table 88 Multidimensional treatment foster care for preschoolers: Study characteristics

First Author et al., Year | Sample Description (Age Group) | Study Design and Duration | Comparison Groups | Baseline N | Risk of Bias
Fisher et al., 2005^143^ and Fisher et al. 2009;^140^ United States | Children ages 3 to 6 years in new foster placement, expected duration ≥3 months | RCT 24 months^a^ (postbaseline: initial out-of-home placement) | G1: MTFC-P G2 Usual care | G1: 47 G2: 43 Overall N = 90^b^ | Medium

a Out-of-home placements were typically prior to study.

b Fisher et al., 2009 G1 N=29, G2 N=23

Abbreviations: G = group; MTFC-P = Multidimensional Treatment Foster Care for Preschoolers; N = number; RCT = randomized controlled trial.

##### Key Points

- Permanency: Compared with usual care, MTFC-P resulted in increased attempted placements, a greater proportion of attempts resulting in permanent placements, and a greater number of cases resulting in permanent placements compared with children in usual care (low SOE).140,143

##### Detailed Synthesis

Results of the MTFC-P trial span seven articles drawn from the same sample, two of which address child welfare outcomes (Table 89);140,143,144 additional study details are provided in the evidence tables (Appendix E).

Table 89 Results: Multidimensional treatment foster care for preschoolers versus usual care

First Author et al., Year | Comparison Groups | Placement Stability | Permanency
Fisher et al., 2005^143^ | G1: MTFC-P G2: Usual care | NA | Fewer Permanent Placement Failures (after closed CPS case) G1>G2: p=0.02
Fisher et al., 2009^140^ | G1: MTFC-P G2: Usual care | NA | Proportion with Attempt at Permanent Placement No difference between G1 and G2, p>0.05 Proportion of Attempts Resulting in Successful Placement G1>G2, p<0.01 Proportion of Cases Resulting in Permanent Placement (i.e., no further placement change) G1>G2, p<0.01

Note: Greater comparative benefit is denoted in the results tables using a greater (“>“) sign.

Abbreviations: CPS = Child Protective Services; G = group; MTFC-P = Multidimensional Treatment Foster Care for Preschoolers; NA = not applicable.

Fisher et al.143 provided an early analysis of placement stability. The sample consisted of 90 of the 117 children in the final study sample (47 MTFC-P; 43 usual care). Children receiving MTFC-P experienced significantly fewer failed permanent placement attempts relative to those in usual care; that is, children receiving MTFC-P were less likely to return to CPS care after placement and case closure. Usual care children had similar rates of placement failure during their initial 10 months of care, after which their rates diverged significantly in favor of the MTFC-P children.

Another article by Fisher and colleagues provides further evidence for the efficacy of the MTFC-P approach in improving positive permanency outcomes.140 Permanent placements were attempted at equal rates for each group; however, for MTFC-P children, these attempts were more likely to be sustained on the first placement attempt and without further CPS involvement. Additionally, a larger proportion of children in the MTFC-P group remained in their permanent placement and required no further CPS involvement relative to usual care children.

We graded the SOE as low for child welfare outcomes due to the presence of a single study (Table 90).

Table 90 Detailed strength of evidence grading table: Multidimensional treatment foster care for preschoolers

Intervention and Comparator | Outcome | Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | SOE Grade; Magnitude of Effect
MTFC-P vs. usual care | Permanency | 1^140,143^; 90 | M | Unknown, single study | Direct | Precise | Low; NR

Note: All results are G1>G2 unless otherwise noted. For estimation of the magnitude of effect, we include only the statistically significant (p<0.05) effect sizes provided by study authors and do not calculate effect sizes as part of our analysis.

Abbreviations: M = medium; NR = not reported; SOE = strength of evidence

#### New Orleans Intervention

We identified one nonconcurrent cohort study examining the efficacy of a comprehensive, multimodal, individualized intervention for infants and toddlers in foster care, referred to as the New Orleans Intervention, compared with usual care (Table 91).130 The intervention is a partnership between the child welfare agency and a team of university-based experts in infant mental health to address the developmental and mental health needs of young children in foster care for abuse or neglect in New Orleans, Louisiana. Children adjudicated between 1991 and 1994, before the intervention was implemented, were the comparison group; children adjudicated between 1995 and 1998, after the intervention was implemented, comprised the intervention group. A comparison group of children in foster care adjudicated between 1995 and 1998 who were supposed to receive the intervention but instead received usual care were also included in a subset of the analyses as a nonintervention group. The authors examined child and maternal recidivism, length of time in foster care, and types of permanency outcomes (e.g., reunification, termination of parental rights, surrender, and relative placement).

Table 91 New Orleans intervention: Study characteristics

First Author et al., Year | Sample Description (Age Group) | Study Design and Duration | Comparison Groups | Baseline N | Risk of Bias
Zeanah et al., 2001^130^ United States | Adjudicated children <48 months of age | Nonconcurrent cohort study [pre-intervention implementation cohort (1/1/1994–12/31/1994) and postintervention implementation cohorts (1/1/1995–12/31/1998] 1–4 years^a^ | G1: New Orleans Intervention group G2: Comparison group (usual care) G3: Nonintervention group (children who were eligible but did not receive the intervention) | G1: 145 G2: 95 G3: 25 Overall = 265 Children returned to birth parents & relatives: G1: 45 G2: 98 Subgroup overall = 143 Children returned to birth parents: G1: 33 G2: 71 Subgroup overall = 104 Mothers whose parental rights were terminated: G1: 38 G2: 19 Subgroup overall = 57 | Medium

a Duration depended on when child entered foster care: 4-year period for children entering care in 1991 and in 1995; 3-year period for those entering care in 1992 and 1996, 2-year period for those entering care in 1993 and 1997, and 1-year period for those entering care in 1994 and 1998.

Abbreviation: G = group.

##### Key Points

- Safety. Compared with children in usual foster care, participants in the New Orleans Intervention had significant reductions in child and maternal recidivism; additionally, the intervention showed a trend towards reduced risk of maternal recidivism with another child (low SOE).130
- Permanency. Participation in the New Orleans Intervention resulted in increased termination of parental rights and decreased reunification outcomes compared with children in usual foster care (low SOE).130

##### Detailed Synthesis

The authors provide evidence for the efficacy of the New Orleans model in reducing the risk of subsequent validated incidents of maltreatment (child recidivism) comparing the intervention with the comparison and nonintervention groups (Table 92). The intervention group also experienced fewer adjudicated subsequent incidents, a more stringent maltreatment recurrence outcome, compared with the preintervention cohort. The authors report that all of the documented cases of recidivism in the intervention group occurred in children returned to their birth parents or placed with relatives. However, analysis of the subgroup of children who had been returned to birth parents or placed with relatives did not demonstrate significant differences for either validated or adjudicated subsequent maltreatment between the intervention and comparison groups. Further subgroup analysis of only children returned to birth parents again found no statistically significant difference between the intervention and comparison group for either validated or adjudicated subsequent maltreatment. The authors report a trend toward significance comparing the intervention and comparison group on maternal recidivism, again either validated or adjudicated. Similarly, a trend was found comparing the intervention and nonintervention group on maternal recidivism for validated maltreatment. Subgroup analysis of maternal recidivism among mothers whose parental rights were terminated demonstrated a trend toward significance when comparing the intervention and comparison group on subsequent validated maltreatment incidents and a significant reduction in adjudicated maltreatment.

Table 92 Results: New Orleans intervention versus comparison groups

First Author et al., Year | Comparison Groups | Safety | Permanency
Zeanah et al., 2001^130^ | G1: New Orleans intervention group G2: Comparison group (usual care) G3: Nonintervention group (usual care) | Child Recidivism^a^ Validated as maltreated in subsequent incident: G1 > G2, p = 0.022; RRR=0.68 [95% CI, 0.09 to 0.89]^b^ G1 > G3, p = 0.036; RRR=0.74 (95% CI, 0.02 to 0.93)^b^ Adjudicated in subsequent incident: G1 > G2, p = 0.036; RRR=0.67 (95% CI, −0.11 to 0.90)^b^ G1 > G3, p = 0.072, trend Child Recidivism subgroup: only children returned to birth parents or placed with relatives^a^ Validated: No difference between G1 and G2, p = 0.114 G1 and G3, p = NR Adjudicated: No difference between G1 and G2, p = 0.193 G1 and G3, p = NR Child Recidivism subgroup: only children returned to birth parents^a^ Validated: No difference between G1 and G2, p = 0.126 G1 and G3, p = NR Adjudicated: No difference between G1 and G2, p = 0.175 G1 and G3, p = NR Maternal Recidivism^a^ Validated for subsequent child: G1 > G2, p = 0.055, trend G1 > G3, p = 0.060, trend Adjudicated for subsequent child: G1 > G2, p = 0.091, trend G1 > G3, p = 0.10 Maternal Recidivism subgroup: mothers whose parental rights were terminated^a^ Validated for subsequent child: G1 > G2, p = 0.051, trend No difference between G1 and G3, p = NR Adjudicated for subsequent child: G1 > G2, p = 0.022; RRR=0.75 (95% CI, 0.11 to 0.93)^b^ No difference between G1 and G3: p = NR | Length of Time in Foster Care: No difference between G1 and G2, p = ns (NR) Difference in Permanency Outcomes: Reunification, Termination, Surrender, and Relative Placement G1 < G2, p < .01 Note: this result is a negative outcome for the intervention group with twice as many terminations and significantly fewer reunifications. G1 and G3, p = NR

a For the recidivism data, the study authors provided relative risk reduction (RRR) statistics without noting the statistical significance of the findings; the Evidence-based Practice Center (EPC) research team performed Mantel-Haenszel chi square analyses to assess the significance of the between-group results and calculated confidence intervals for the RRR statistics.

b Point estimates are provided in the evidence tables (Appendix E).

Note: Greater comparative benefit is denoted in the results tables using a greater (“>“) sign.

Abbreviations: CI = confidence interval; G = group; N = number; NR = not reported; RRR = relative risk reduction.

No differences were found between the intervention and comparison group for length of time in foster care. The authors attribute this no-difference finding in part to legal and child welfare system processes and the tendency of the court to grant continuances to give the parent more time and opportunity to prove their fitness to regain custody. The study also found that parents who participated in the intervention group were twice as likely to lose custody (termination of parental rights) and significantly less likely to be reunified with their children compared with the cohort that did not receive the intervention. The authors suggest that the “more intense scrutiny of parents…with its focus on psychological accountability” may have resulted in this increase and acknowledge that the decreased rates of recidivism in the intervention group may have been in part attributable to the termination of parental rights. Parents gaining insight about the needs of their child for a safe, stable, and nurturing environment may mobilize them to appraise realistically their parental capacity and opt for termination of parental rights, which frees the child to be adopted or reach permanency through the guardianship of a relative. Thus, the finding of increased termination of parental rights and decreased reunification can be interpreted as a clinically positive outcome.

We graded the SOE for the New Orleans Intervention as low for child welfare outcomes based on the presence of a single study (Table 93).

Table 93 Detailed strength of evidence grading table: New Orleans intervention

Intervention and Comparator | Outcome | Studies; subjects | Risk of Bias | Consistency | Directness | Precision | SOE Grade; Magnitude of effect
New Orleans Intervention vs. Usual care | Safety | 1^130^; 255 | M | Unknown, single study | Direct | Precise | Low; RRR=0.67 to 0.75
New Orleans Intervention vs. Usual care | Permanency | 1^130^; 240 | M | Unknown, single study | Direct | Precise | Low, G1 < G2; NR

Note: For estimation of the magnitude of effect, we include only the statistically significant (p<0.05) effect sizes provided by study authors and do not calculate effect sizes as part of our analysis. Authors do not report effect sizes for the some of the outcomes presented in this table.

Abbreviations: G = group; M = medium; NR = not reported; RRR = relative risk reduction; SOE = strength of evidence.

#### Enhanced Foster Care, Summary Strength of Evidence Grades

We summarize the SOE grade for all enhanced foster care in Table 94.

Table 94 Enhanced foster care: Summary strength of evidence for child welfare outcomes

Intervention (G1) | Comparison (G2) | Outcome | N Trials, Participants | Strength of Evidence Magnitude of Effect
Fostering Healthy Futures | Inactive control | Placement stability | 1^132^;110 | Low; OR=0.18 to 0.56
Fostering Healthy Futures | Inactive control | Permanency | 1^132^; 110 | Low; OR=5.14
Middle School Success | Routine foster care | Placement stability | 1^136^; 100 | Low; medium (d=0.50)
Multi-dimensional Treatment Foster Care | Usual care | Permanency | 1^140,143^; 90 | Low; NR
New Orleans Intervention | Usual care | Safety | 1^130^; 255 | Low; RRR=0.67 to 0.75
New Orleans Intervention | Usual care | Permanency | 1^130^; 240 | Low (G1<G2); NR

Note: All results are G1>G2 unless otherwise noted. For estimation of the magnitude of effect, we include only the statistically significant (p<0.05) effect sizes provided by study authors and do not calculate effect sizes as part of our analysis. Interpretation of the effect size as small, medium, or large is defined as: Cohen’s d = 0.20, 0.50, and 0.80.^176^

Abbreviations: G = group; NR = not reported; OR = odds ratio; RRR = relative risk reduction.

## Key Question 3 Comparative Effectiveness of Interventions with Different Characteristics

### Organization

The Results in this section are organized according to type of intervention characteristic assessed for key question (KQ) 3. Following the description of included studies, we present the key points which summarize the main findings for each comparison and the strength of evidence (SOE) grade. The trials included in this section were all included in KQ 1, so they are very briefly summarized here and the reader is referred to previous sections of the Results chapter for detail about study design and findings.

### Description of Included Studies

Several treatment characteristics were identified a priori for this KQ, based on factors of interest identified in the mental health services and intervention research literature. These characteristics were modality (i.e., format, such as individual vs. dyadic), theoretical orientation, and type of service delivery setting. We did not identify any eligible studies that compared an intervention’s effectiveness across different type(s) of setting. Regarding modality and theoretical orientation, very few studies were aligned with this KQ and our team was cautious to avoid overinterpretation so as to make a study “fit” the question. Our intention in selecting theoretical orientation as an intervention characteristic to examine in KQ 3 was to contribute to the literature on (and ongoing debate regarding) active ingredients in efficacious interventions. However, because the majority of interventions included in this review drew on multiple theoretical underpinnings and did not espouse a unifying or overarching theoretical orientation, the results of comparisons did not lend themselves to interpretation. Additionally, many studies did not provide clear, specific detail regarding the theoretical orientation(s) of the comparative approach. Thus, we identified only three trials that provided meaningful comparisons for inclusion in KQ 3 (Table 95).77–79,81–83,85,108

Table 95 Number of trials and articles comparing the effectiveness of interventions with different characteristics

Intervention Characteristic | Comparison | Intervention | Trials
Theoretical Orientation | Attachment-based vs. didactic | Attachment and Biobehavioral Catch-up77–79,81–83,85 | 2 a
Theoretical Orientation | Cognitive behavioral vs. psychodynamic | Trauma-Focused Cognitive Behavioral Therapy108 | 1
| | Total | 3

a Reported in seven articles

Below we provide an overview of the key features in the body of evidence for theoretical orientation.

- Three trials provided two comparisons of interventions by theoretical orientation. Two trials focused on an attachment-based intervention;77–79,81–83,85 one trial focused on a cognitive-behavioral approach.108
- One trial targeted foster parents and the young children in their care;77–79,85 two trials focused on biological parents.81–83,108
- One comparison (two trials) compared an intervention based on attachment theory with a didactic approach that emphasized teaching parents how to support their children’s language and cognitive development (derived comparator).77–79,81–83,85,108
- One trial examined the comparative efficacy of a cognitive-behavioral intervention relative to a conventional psychodynamic approach.108
- Two trials reported on mental and behavioral health outcomes.77,78,82,83,108
- All three trials reported on caregiver-child relationship outcomes.79,81,108
- One trial assessed developmental outcomes.85
- No trials assessed school-based functioning outcomes.
- No trials assessed child welfare outcomes.

### Theoretical Orientation

#### Key Points

- Attachment-based versus didactic
  ○ Mental health and behavioral outcomes: Children whose foster or biological parents participated in the attachment-based intervention had better mental and behavioral health outcomes than children whose foster parents participated in the didactic intervention (low SOE of benefit).77,78,82,83
  ○ Healthy caregiver-child relationship: Parents (foster or biological) who participated in the attachment-based intervention reported significantly more positive caregiver-child relationship outcomes compared with parents who participated in the didactic comparator (low SOE of benefit).79,81
  ○ Healthy development: Children whose foster parents participated in the attachment-based intervention exhibited higher levels of cognitive functioning compared with children in the didactic condition.85
- Cognitive behavioral versus psychodynamic
  ○ Mental health and behavioral outcomes: Children participating in the cognitive-behavioral approach reported better mental health outcomes compared with participants in the psychodynamic condition (low SOE).108
  ○ Healthy caregiver-child relationship: Children and caregivers participating in the cognitive-behavioral approach reported better caregiver-child relationship outcomes than participants in the psychodynamic condition (low SOE).108

#### Detailed Synthesis

We identified three trials that compared interventions’ effectiveness by theoretical orientation. We note these studies in Table 96 but do not discuss them here, as they are discussed in previous sections of the Results chapter.

Table 96 Theoretical orientations: Strength of evidence for KQ 1 outcomes

Intervention (G1) | Comparison (G2) | Outcome | N Trials, Participants | Strength of Evidence^a^ Magnitude of Effect^b^
Attachment-based | Didactic | Mental and behavioral health | 2^77,78,82,83^; 153 | Low; NR
Attachment-based | Didactic | Healthy caregiver-child relationship | 1^79,81^; 46 | Low; NR
Cognitive behavioral | Psychodynamic | Mental and behavioral health | 1^108^; 229 | Low; Small to medium (d=0.33 to 0.70)
Cognitive behavioral | Psychodynamic | Healthy caregiver-child relationship | 1^108^; 229 | Low; Small to medium (d=0.38 to 0.57)

a All strength of evidence results are G1>G2 unless noted otherwise.

b For estimation of the magnitude of effect, we include only the statistically significant (p<0.05) effect sizes provided by study authors and do not calculate effect sizes as part of our analysis. Interpretation of the effect size as small, medium, or large is defined as Cohen’s d = 0.20, 0.50, and 0.80.^176^ We include an effect size range when more than two effect sizes are reported. Authors did not report effect sizes for some measures.

Abbreviations: G = group; KQ = key question; N = numbers; NR = Not Reported

## Key Question 4 Comparison of Intervention Effectiveness for Improving Child Well-Being or Child Welfare Outcomes in Population Subgroups

### Organization

We organize the results for key question (KQ) 4 by overarching category of child or caregiver subgroup population. Each section provides a brief overview of the included studies, the key points, and a summary strength of evidence (SOE) table for the different subgroups. Because all studies included in this section are also included in either or both KQ 1 and KQ 2, the reader is referred to previous sections for detail about the study design and findings. Also in the interest of reducing repetition, we do not repeat findings with insufficient SOE in KQ 4.

Below we list the subgroups that were specified a priori for consideration in KQ 4:

KQ 4a Child subgroups:
  ○ Age and other sociodemographic subgroups (e.g., race, ethnicity, sex)
  ○ Type of maltreatment exposure (e.g., neglect, physical abuse, sexual abuse)
  ○ Severity of maltreatment exposure
  ○ Presence of mental or behavioral health problems or other special needs
KQ 4b Caregiver subgroups:
  ○ Primary caregiving context: biological parent; foster, kin (relative), or adoptive caregivers; residential program or group home
  ○ Presence of mental health problems, substance abuse, or domestic violence
  ○ Sociodemographic groups (e.g., age, race, ethnicity, sex)

### Description of Included Studies

We identified 23 trials which addressed the subgroups specified for KQ 4. As noted above, all trials included in this section also were included in either or both KQ 1 and KQ 2 and all three intervention types (parenting interventions, trauma-focused treatments, and enhanced foster care interventions) are represented in the results for KQ 4. Table 97 presents the number of trials and articles for each child and caregiver subgroup; the table also describes which intervention was evaluated with the different subpopulations of interest to this KQ. For the age subgroup, we included those studies that limited the population to children whose ages fell within the following developmental periods: early childhood (ages 0 to 5), middle childhood (ages 6 to 10), and early adolescence (ages 11 to 14). So as not to be too restrictive, we allowed the age parameters to vary by 1 year. Hence, studies with populations that spanned wide age ranges (e.g., 3 to 8 years, 6 to 14 years) were not eligible for inclusion in KQ 4 age subgroup analyses.

Table 97 Total number of studies (trials and cohort studies) in KQ 4

Intervention | Trials | Early childhood | Middle childhood | Early adolescence | Female | Neglect | Physical Abuse | Sexual Abuse | Trauma Symptoms | Biological parent | Foster caregiver
Parenting Interventions | Total = 10 | 7 | 1 | - | - | 1 | 1 | - | - | 7 | 3
Attachment and Biobehavioral Catch-up | 3 | 3 | - | - | - | - | - | - | - | 1 | 2
Attachment-based Intervention | 1 | 1 | - | - | - | - | - | - | - | 1 | -
Child-Parent Psychotherapy | 2 | 2 | - | - | - | - | - | - | - | 2 | -
Keeping Foster and Kinship Parents Trained and Supported | 1 | - | - | - | - | - | - | - | - | - | 1
Parent-Child Interaction Therapy Adaptation Package | 2 | - | - | - | - | - | 1 | - | - | 2 | -
SafeCare | 1 | 1 | - | - | - | 1 | - | - | - | 1 | -
Trauma-Focused Treatments | Total = 5 | - | - | - | 2 | - | 1 | 4 | 5 | 1 | 0
Combined Parent-Child Cognitive Behavioral Therapy | 1 | - | - | - | - | - | 1 | - | 1 | 1 | -
Group Psychotherapy for Sexually Abused Girls | 1 | - | - | - | 1 | - | - | 1 | 1 | - | -
Group Treatment Program for Sexual Abuse | 1 | - | - | - | 1 | - | - | 1 | 1 | - | -
Trauma-Focused Cognitive Behavioral Therapy | 2 | - | - | - | - | - | - | 2 | 2 | - | -
Enhanced Foster Care Interventions | Total = 5 | 3 | 1 | 1 | 1 | 1 | - | - | - | 1 | 3
Bucharest Early Intervention Project | 1 | 1 | - | - | 1 | 1 | - | - | - | - | 1
Fostering Healthy Futures | 1 | - | 1 | - | - | - | - | - | - | - | -
Middle School Success | 1 | - | - | 1 | - | - | - | - | - | - | 1
Multidimensional Treatment Foster Care-Preschoolers | 1 | 1 | - | - | - | - | - | - | - | - | 1
New Orleans Intervention | 1^a^ | 1 | - | - | - | - | - | - | - | 1 | -
TOTAL | 20 | 10 | 2 | 1 | 3 | 2 | 2 | 4 | 5 | 9 | 6

a Cohort study

Abbreviation: KQ = key question.

Regarding severity, we operationalized this population characteristic in terms of the chronic and multiple nature of the child’s exposure. Although several studies characterized the study population as “severely maltreated” or described families as having multiple reports to Child Protective Services (CPS) or severe parent-to-child violence, further breakdown of the population by severity or analysis of outcomes by degree of severity was not provided.80,95 In general, reporting of the degree of maltreatment exposure was notably limited in the literature reviewed, a function of researchers having to rely on child welfare or other administrative records and/or parent report (both of which can be difficult to obtain and are subject to inaccuracies and omission) for information about the child’s maltreatment history.

Regarding caregiving context, we did not identify eligible trials focused on adoptive parents, either already related or not previously related to the child. We also did not identify eligible trials addressing residential or group care, caregivers with mental health or substance abuse problems, or caregiver sociodemographics (e.g., age, sex, race, ethnicity).

### KQ 4a Child Well-Being and Child Welfare Outcomes in Child Subgroups

#### Age and Other Sociodemographic Subgroups: Early Childhood

##### Key Points

- Attachment and Biobehavioral Catch-up (ABC): In one trial targeting infants and toddlers (approximately 3 to 39 months of age) and their foster caregivers, ABC resulted in improvements in child mental and behavioral health and caregiver-child relationship outcomes compared with an active control (low SOE for benefit).77–79 In a second trial targeting infants and toddlers (approximately 2 to 21 months of age) and their maltreating parents, ABC again resulted in improvements in child mental and behavioral health and caregiver-child relationship outcomes compared with the active control used in the previous trial (low SOE for benefit).81–83 A third trial conducted with children in foster care age 0 to 6 years and their foster caregivers, found significant benefit for ABC in improving child mental and behavioral health and caregiver-child relationship outcomes compared with a wait-list control (low SOE of benefit).80
- Attachment-based Intervention: A randomized controlled trial (RCT) targeting infants and toddlers (approximately 1 to 6 years) evaluating an intervention loosely based on ABC and other attachment-focused approaches found improved caregiver-child relationship outcomes in the intervention arm compared with usual care (low SOE of benefit).86
- Bucharest Early Intervention Project (BEIP): The BEIP trial demonstrated numerous benefits for infants and toddlers (age 6 to 30 months) removed from institutionalized care and placed in an enhanced foster care intervention compared with children who remained in institutional care. The intervention showed benefit in numerous long-term child mental and behavioral health, caregiver-child relationship, and developmental outcomes. Analysis by age of placement in foster care showed that children placed in foster care earlier were significantly more likely to have an organized attachment compared with children placed later. For secure versus insecure attachment, children in the enhanced foster care placement before 24 months of age were more likely to have secure attachment than those placed in the foster care condition after 24 months. Time in foster care was also significant, with children being placed for a longer time in the enhanced foster care more likely to have an organized attachment than those placed for a shorter time (low SOE of benefit).117–129
- Child-Parent Psychotherapy (CPP): In two RCTs targeting young children and their maltreating parent (one study targeted 12-month-old infants; the second study targeted 4-year-old children), a variant of Child-Parent Psychotherapy developed by Cicchetti and colleagues resulted in improved caregiver-child relationship outcomes compared with usual care (low SOE of benefit).87,88
- Multidimensional Treatment Foster Care: One RCT with young children (3 to 6 years) found significant benefit of a highly individualized multimodal intervention in improving child mental and behavioral health, caregiver-child relationship, healthy development, and positive permanency outcomes (low SOE of benefit).138–144,179
- New Orleans Intervention: One nonconcurrent cohort study examined a multimodal intervention that included intensive dyadic psychotherapy with adjudicated (i.e., placed in foster care) infants and young children (age 0 to 4 years) and their biological parents. Referred to as the New Orleans Intervention, this study found significantly reduced risk of child recidivism compared with usual care and also with a comparison group of children who were eligible but did not receive the intervention. In addition, the study found that the intervention, compared with usual care, resulted in increased termination of parental rights, decreased reunification, and reduced risk of maternal recidivism with a subsequent child among mothers whose rights had been terminated (low SOE of benefit).130
- SafeCare: In one large-scale effectiveness RCT examining a home-visiting intervention for parents involved with CPS due to neglect, SafeCare resulted in significantly reduced child recidivism (rereports to child welfare) compared with usual care; the benefits of SafeCare were strongest for preschool-age children compared with the full study population, which included children up to 12 years of age (moderate SOE of benefit).100

##### Detailed Synthesis

We summarize the outcomes and SOE for each study in Table 98. We do not present a detailed synthesis section because all studies are discussed in previous sections of the Results chapter.

Table 98 Strength of evidence summary table: Early childhood

Intervention (G1) | Comparison (G2) | Outcome | N Trials, Participants | Strength of Evidence; Magnitude of Effect
Attachment and Biobehavioral Catch-up | Active control^a^ | Mental health and behavior | 2^77,78,82,83^; 213 | Low; NR
Attachment and Biobehavioral Catch-up | Active control^a^ | Healthy caregiver-child relationship | 2^79,81^; 166 | Low; NR
Attachment and Biobehavioral Catch-up | Active control^a^ | Healthy development | 1^85^; 37 | Low; NR
Attachment and Biobehavioral Catch-up | Wait list | Mental and behavioral health | 1^80^; 58 | Low; medium (partial eta squared=0.436 or 0.511)
Attachment and Biobehavioral Catch-up | Wait list | Healthy caregiver-child relationship | 1^80^; 58 | Low; medium or large (partial eta squared=0.59 or 0.791)
Attachment-based Intervention | Usual care | Healthy caregiver-child relationship | 1^86^; 79 | Low; small to medium (d=0.47, r=0.36 or 0.37)
Child-Parent Psychotherapy^b^ | Usual Care | Healthy caregiver-child relationship | 2^87,88^; 141 | Low; medium to large (h=0.64 to 1.34)
Bucharest Early Intervention Project | Usual care (institutional care in Romania) | Mental health and behavior | 1^118,120,123,125,129^; 136 | Low; odds ratio 2.8 [95%CI 1.2 to 6.4]
Bucharest Early Intervention Project | Usual care (institutional care in Romania) | Healthy caregiver-child relationship | 1^121,125,127^; 136 | Low; NR
Bucharest Early Intervention Project | Usual care (institutional care in Romania) | Healthy development | 1^117,119,121,122,124,126,128^; 136 | Low; effect size^c^=0.47 or 0.62
Multi-dimensional Treatment Foster Care for Preschoolers | Usual care | Mental health and behavior | 1^142,179^; 117 | Low; medium (d=0.64 to 0.68)
Multi-dimensional Treatment Foster Care for Preschoolers | Usual care | Healthy caregiver-child relationship | 1^139,141^; 117 | Low; NR
Multi-dimensional Treatment Foster Care for Preschoolers | Usual care | Healthy development | 1^138^; 23 | Low; NR
Multi-dimensional Treatment Foster Care for Preschoolers | Usual care | Permanency | 1^79,143^; 90 | Low; NR
New Orleans Intervention | Usual care | Safety | 1^130^; 255 | Low RRR=0.67 to 0.75
New Orleans Intervention | Usual care | Permanency | 1^130^; 240 | Low; NR
SafeCare | Usual care | Safety | 1^100^; 1653 | Moderate HR=0.74 to 0.79

a Active comparator is an approach derived from an intervention wherein the degree to which core components of the original model are implemented is unclear and/or core components are omitted or substantively modified.

b Intervention is a variant of relationship-based dyadic psychotherapy as developed and manualized by Cicchetti and colleagues.87,88

c Effect size measure is not specified, so we did not classify the magnitude of effect as small, medium, or large.

Note: Table is organized alphabetically by intervention name. All results are G1>G2 unless otherwise noted. For estimation of the magnitude of effect, we include only the statistically significant (p<0.05) effect sizes provided by study authors and do not calculate effect sizes as part of our analysis. Interpretation of the effect size as small, medium, or large is defined as: Cohen’s d = 0.20, 0.50, and 0.80; Cohen’s h = 0.20, 0.50, and 0.80; and correlation coefficient r = 0.10, 0.30, and 0.50.^176^ When authors use partial eta squared effect sizes we use the interpretation that the authors provide.80 We include an effect size range when more than two effect sizes are reported.

Abbreviations: G = group; HR = hazard ratio; N = number; NR = not reported; RRR = relative risk reduction.

#### Age and Other Sociodemographic Subgroups: Middle Childhood

##### Key Points

- Fostering Healthy Futures(FHF): One RCT found that youth age 9 to 11 years who participated in the FHF intervention experienced significantly greater improvements in mental health outcomes, had greater placement stability, were less likely to be placed in residential treatment care, and were more likely to be reunified than youth in an inactive control group; participants in FHF who were in nonrelative foster care were more likely to attain permanency compared with the control group (low SOE of benefit).132

##### Detailed Synthesis

We summarize the outcomes and SOE for each study in Table 99. We do not present a detailed synthesis section because all studies are discussed in previous sections of the Results chapter.

Table 99 Strength of evidence summary table: Middle childhood

Intervention (G1) | Comparison (G2) | Outcome | N Trials, Participants | Strength of Evidence; Magnitude of Effect
Fostering Healthy Futures | Inactive control | Mental and behavioral health | 1^131^; 156 | Low; small to medium (d=0.30 to 0.51)

Note: Table is organized alphabetically by intervention name. All results are G1>G2 unless otherwise noted. For estimation of the magnitude of effect, we include only the statistically significant (p<0.05) effect sizes provided by study authors and do not calculate effect sizes as part of our analysis. Interpretation of the effect size as small, medium, or large is defined as Cohen’s d = 0.20, 0.50, and 0.80.^176^

Abbreviations: G = group; N = number.

#### Age and Other Sociodemographic Subgroups: Early Adolescence

##### Key Points

- Middle School Success: One RCT found that youth age 10 to 12 years who participated in the Middle School Success intervention experienced significantly greater improvements in mental and behavioral health outcomes and greater placement stability compared with routine foster care (low SOE of benefit).136,137

##### Detailed Synthesis

We summarize the outcomes and SOE for each study in Table 100. We do not present a detailed synthesis section because all studies are discussed in previous sections of the Results chapter.

Table 100 Strength of evidence summary table: Early adolescence

Intervention (G1) | Comparison (G2) | Outcome | N Trials, Participants | Strength of Evidence; Magnitude of Effect
Middle School Success | Usual care | Mental and behavioral health | 1^136,137^; 100 | Low; small to medium (d=0.35 to 0.57)
Middle School Success | Usual care | Placement stability | 1^136^; 100 | Low; medium (d=0.50)

Note: Table is organized alphabetically by intervention name. All results are G1>G2 unless otherwise noted. For estimation of the magnitude of effect, we include only the statistically significant (p<0.05) effect sizes provided by study authors and do not calculate effect sizes as part of our analysis. Interpretation of the effect size as small, medium, or large is defined as Cohen’s d = 0.20, 0.50, and 0.80.^176^

Abbreviations: G = group; N = number.

#### Age and Other Sociodemographic Subgroups: Sex

##### Key Points

- Bucharest Early Intervention Project (BEIP): The BEIP trial conducted subgroup analyses by sex. The study found that girls were more likely to have healthy caregiver-child relationship (attachment) outcomes than boys. Additionally, girls in the BEIP condition were more likely than their counterparts remaining in institutional care to have secure attachment and change from an insecure/incompletely formed to secure attachment; however, the study found no differences by intervention group among males (low SOE of benefit).125,127
- Group Psychotherapy for Sexually Abused Girls: One RCT evaluating a group psychotherapy intervention explicitly developed for girls found superior long-term benefits in child mental and behavioral health outcomes compared with conventional psychoanalytic therapy; this comparative benefit was sustained at a 2-year postbaseline followup (low SOE of benefit).113
- Group Treatment Program for Sexual Abuse: One nonrandomized study evaluating a group treatment program with a sample comprising only girls found significant benefit in favor of the intervention for improving mental and behavioral health outcomes compared with wait-list control; the findings must be interpreted with caution in light of the nonrandomized design and very small sample size (low SOE of benefit).114

##### Detailed Synthesis

We summarize the outcomes and SOE for each study that was completed within a subgroup in Table 101. We do not present a detailed synthesis section because all studies are discussed in previous sections of the Results chapter.

Table 101 Strength of evidence summary table: Sex (females)

Intervention (G1) | Comparison (G2) | Outcome | N Trials, Participants | Strength of Evidence; Magnitude of Effect
Group Psychotherapy | Active control^a^ | Mental and behavioral health | 1,^113^ 71 | Low, G1<G2 Small to medium (d=0.36 to 0.79)
Group Treatment Program for Sexual Abuse | Inactive control | Mental and behavioral health | 1,^114^ 30 | Low; NR

a Active comparator is an approach representative of a conventional practice in the field.

NOTE: Table is organized alphabetically by intervention name. All results are G1>G2 unless otherwise noted. For estimation of the magnitude of effect, we include only the statistically significant (p<0.05) effect sizes provided by study authors and do not calculate effect sizes as part of our analysis. Interpretation of the effect size as small, medium, or large is defined as Cohen’s d = 0.20, 0.50, and 0.80.^176^

Abbreviations: G = group; N = number; NR = not reported.

#### Type of Maltreatment Exposure: Neglect

##### Key Points

- Bucharest Early Intervention Project (BEIP): One RCT evaluated an enhanced foster care intervention with infants and young children exposed to social and developmental deprivation in institutional care. The BEIP trial resulted in superior improvements in child mental and behavioral health, caregiver-child relationship, and developmental outcomes compared with usual (institutional) care (low SOE of benefit).117–129
- SafeCare: One large-scale effectiveness RCT evaluated SafeCare, an intervention designed for parents involved with CPS due to neglect. The intervention resulted in significantly reduced child recidivism (rereports to child welfare) compared with usual care. More than a third of the children in each study group had previous histories of physical abuse and of sexual abuse. As noted previously, the benefits of SafeCare were strongest for preschool-age children compared with the full study population, which included children up to 12 years of age (moderate SOE of benefit).100

##### Detailed Synthesis

We summarize the outcomes and SOE for each study in Table 102. We do not present a detailed synthesis section because all studies are discussed in previous sections of the Results chapter.

Table 102 Strength of evidence summary table: Neglect

Intervention (G1) | Comparison (G2) | Outcome | N Trials, Participants | Strength of Evidence; Magnitude of Effect
Bucharest Early Intervention Project | Usual care (institutional care in Romania) | Mental health and behavior | 1,^118,120,123,125,129^ 136 | Low; odds ratio 2.8 [95%CI 1.2 to 6.4]
Bucharest Early Intervention Project | Usual care (institutional care in Romania) | Healthy caregiver-child relationship | 1,^121,125,127^ 136 | Low; NR
Bucharest Early Intervention Project | Usual care (institutional care in Romania) | Healthy development | 1,^117,119,121,122,124,126,128^ 136 | Low; effect size^a^ =0.47 or 0.62
SafeCare | Usual care | Safety | 1,^100^ 2175 | Moderate HR=0.74 to 0.83

a Effect size measure is not specified, so we did not classify the magnitude of effect as small, medium, or large.

b The comparison group for one study was an n < 10 participants.

Note: Table is organized alphabetically by intervention name. All results are G1>G2 unless otherwise noted. For estimation of the magnitude of effect, we include only the statistically significant (p<0.05) effect sizes provided by study authors and do not calculate effect sizes as part of our analysis.

Abbreviations: CI = confidence interval; G = group; HR = hazard ratio; N = number; NR = not reported.

#### Type of Maltreatment Exposure: Physical Abuse

##### Key Points

- Combined Parent-Child Cognitive Behavioral Therapy (CPC-CBT): One RCT evaluated an intervention, CPC-CBT, designed specifically to treat children exposed to physical abuse. This study found greater improvements in child mental and behavioral health among children in the intervention group compared with an inactive control (low SOE of benefit).107
- Parent-Child Interaction Therapy Adaptation Package (PCIT-AP): An RCT evaluating an adaptation of PCIT for physically abusive parents and their children, which included a motivational interviewing orientation, found significantly reduced child recidivism (median follow-up time 850 days postbaseline) in favor of the intervention (low SOE of benefit).96

##### Detailed Synthesis

We summarize the outcomes and SOE for each study in Table 103. We do not present a detailed synthesis section because all studies are discussed in previous sections of the Results chapter.

Table 103 Strength of evidence summary table: Physical abuse

Intervention (G1) | Comparison (G2) | Outcome | N Trials, Participants | Strength of Evidence; Magnitude of Effect
Combined Parent-Child Cognitive Behavioral Therapy | Active control^a^ | Mental and behavioral health | 1,^107^ 75 | Low; medium (d=0.61)
Parent-Child Interaction Therapy (PCIT) Adaptation Package^b^ | Usual care | Safety | 1,^96^ 77 | Low; NR

a Active comparator is an approach derived from an intervention wherein the degree to which core components of the original model are implemented is unclear and/or core components are omitted or substantively modified.

b ”Package” refers to the inclusion of a supplemental motivational intervention orientation.

Note: Table is organized alphabetically by intervention name. All results are G1>G2 unless otherwise noted. For estimation of the magnitude of effect, we include only the statistically significant (p<0.05) effect sizes provided by study authors and do not calculate effect sizes as part of our analysis. Interpretation of the effect size as small, medium, or large is defined as Cohen’s d = 0.20, 0.50, and 0.80.^176^

Abbreviations: G = group; N = number; NR = not reported.

#### Type of Maltreatment Exposure: Sexual Abuse

##### Key Points

- Group Psychotherapy for Sexually Abused Girls: One RCT assessed the efficacy of a group-based intervention developed specifically to treat sexually abused girls compared with conventional psychoanalytic therapy (active control). The study found the conventional therapy was superior to the group-based approach; as noted previously, this comparative benefit was sustained at a 2-year postbaseline followup (low SOE of greater benefit for active control group).113
- Group Treatment Program for Sexual Abuse: One nonrandomized study evaluated a group treatment program developed for child victims of sexual abuse. The study found significant benefit in favor of the intervention for improving mental and behavioral health outcomes compared with wait-list control; however, as noted previously, the findings must be interpreted with caution in light of the nonrandomized design and very small sample size (low SOE of benefit).114
- Trauma-Focused Cognitive Behavioral Therapy (TF-CBT): Two RCTs evaluated TF-CBT with sexually abused children, each with a different active control. In both trials, TF-CBT was superior in improving child mental and behavioral health outcomes, including sexualized behavior, and caregiver-child relationship outcomes (low SOE of benefit).108,115

##### Detailed Synthesis

We summarize the outcomes and SOE for each study in Table 104. We do not present a detailed synthesis section because all studies are discussed in previous sections of the Results chapter.

Table 104 Strength of evidence summary table: Sexual abuse

Intervention (G1) | Comparison (G2) | Outcome | N Trials, Participants | Strength of Evidence; Magnitude of Effect
Group Psychotherapy for Sexually Abused Girls | Active control^a^ | Mental and behavioral health | 1^113^; 71 | Low, G1<G2 Small to medium (d=0.36 to 0.79)
Group Treatment Program for Sexual Abuse | Inactive control | Mental and behavioral health | 1^114^; 30 | Low; NR
Trauma-Focused Cognitive Behavioral Therapy | Active control^b^ | Mental and behavioral health | 2^108,115^; 315 | Low; small to medium (d=0.30 to 0.70)
Trauma-Focused Cognitive Behavioral Therapy | Active control^b^ | Healthy caregiver-child relationship | 1^108^; 229 | Low; small to medium (d=0.38 or 0.57)

a Active comparator is an approach representative of a conventional practice in the field.

b One comparator is a conventional approach, the other a derived approach.

Note: Table is organized alphabetically by intervention name. All results are G1>G2 unless otherwise noted. For estimation of the magnitude of effect, we include only the statistically significant (p<0.05) effect sizes provided by study authors and do not calculate effect sizes as part of our analysis. Interpretation of the effect size as small, medium, or large is defined as Cohen’s d = 0.20, 0.50, and 0.80.^176^

Abbreviations: G = group; N = number; NR = not reported.

#### Presence of Mental or Behavioral Health Problems or Other Special Needs

##### Key Points

- Combined Parent-Child Cognitive Behavioral Therapy (CPC-CBT): One trial evaluating CPC-CBT compared with an active control found significantly greater short-term improvements in trauma symptoms (total diagnostic score; self-report and caregiver report on child) compared with an active control (low SOE of benefit); as noted previously, the short-term outcomes faded by the 3-month postintervention followup (low SOE of benefit).107
- Group Psychotherapy for Sexually Abused Girls: In one RCT, conventional psychoanalytic therapy resulted in significantly greater long-term improvements in re-experiencing and avoidance symptoms of traumatic stress compared with an experimental group-based intervention; as noted previously, this comparative benefit was sustained at a 2-year postbaseline followup (low SOE of benefit).113
- Group Treatment Program for Sexual Abuse: One nonrandomized study with girls who were symptomatic for attentional and behavioral problems found significant benefit in favor of the intervention in these and other mental and behavioral health outcomes compared with wait-list control; as noted previously, the findings must be interpreted with caution in light of the nonrandomized design and very small sample size (low SOE of benefit).114
- Trauma-Focused Cognitive Behavioral Therapy (TF-CBT): In two RCTs using two different active controls, TF-CBT was superior in reducing multiple trauma symptoms (re-experiencing, avoidance, hypervigilance) (low SOE of benefit).108,115

##### Detailed Synthesis

We summarize the outcomes and SOE for each study in Table 105. We do not present a detailed synthesis section because all studies are discussed in previous sections of the Results chapter.

Table 105 Strength of evidence summary table: Mental or behavioral health problems

Intervention (G1) | Comparison (G2) | Outcome | N Trials, Participants | Strength of Evidence; Magnitude of Effect
Combined Parent-Child Cognitive Behavioral Therapy | Active control^a^ | Mental and behavioral health | 1,^107^ 75 | Low; medium (d=0.61)
Group Psychotherapy | Active control^a^ | Mental and behavioral health | 1,^113^ 71 | Low, G1<G2 Small to medium (d=0.36 to 0.79)
Group Treatment Program for Sexual Abuse | Inactive control | Mental and behavioral health | 1,^114^ 30 | Low; NR
Trauma-Focused Cognitive Behavioral Therapy | Active control^c^ | Mental and behavioral health | 2,^108,115^ 315 | Low; small to medium (d=0.30 to 0.70)
Trauma-Focused Cognitive Behavioral Therapy | Active control^c^ | Healthy caregiver-child relationship | 1,^108^ 229 | Low; small to medium (d=0.38 or 0.57)

a Active comparator is an approach derived from an intervention wherein the degree to which core components of the original model are implemented is unclear and/or core components are omitted or substantively modified.

b One comparator is a conventional approach, the other a derived approach.

Note: Table is organized alphabetically by intervention name. All results are G1>G2 unless otherwise noted. For estimation of the magnitude of effect, we include only the statistically significant (p<0.05) effect sizes provided by study authors and do not calculate effect sizes as part of our analysis. Interpretation of the effect size as small, medium, or large is defined as Cohen’s d = 0.20, 0.50, and 0.80.^176^

Abbreviations: G = group; NR = not reported.

### KQ 4b Child Welfare and Child Well-Being Outcomes in Caregiver Subgroups

#### Primary Caregiving Context: Maltreating Parents

##### Key Points

- Attachment and Biobehavioral Catch-up (ABC): One trial evaluated ABC with biological parents involved with child welfare services and their young children. The study found significantly greater improvements in child mental and behavioral health and caregiver-child relationship outcomes compared with an active control (low SOE for benefit).81–83
- Attachment-based Intervention: One RCT evaluated an attachment-based intervention with parent-child pairs. Parents were substantially and legally documented for maltreatment, reported for maltreatment by a community organization, or self-reported the child’s maltreatment exposure. The study found improved caregiver-child relationship outcomes in the intervention arm compared with usual care (low SOE of benefit).86
- Child-Parent Psychotherapy (CPP): In two RCTs with maltreating parents and their young children, a variant of Child-Parent Psychotherapy developed by Cicchetti and colleagues resulted in improved caregiver-child relationship outcomes compared with usual care (low SOE of benefit).87,88
- Combined Parent-Child Cognitive Behavioral Therapy (CPC-CBT): One RCT evaluating CPC-CBT with physically abusive parents and their children found greater improvements in child mental and behavioral health outcomes compared with an inactive control; as noted previously, the short-term outcomes faded by 3-month postintervention followup (low SOE of benefit).107
- New Orleans Intervention: One nonconcurrent cohort study evaluated the New Orleans Intervention with adjudicated infants and young children (i.e., in foster care) and their biological parents. This study found significantly reduced risk of child recidivism compared with usual care and also with a comparison group of children who were eligible but did not receive the intervention. As noted previously, the study also found that the intervention, compared with usual care, resulted in increased termination of parental rights, decreased reunification, and reduced risk of maternal recidivism with a subsequent child among mothers whose rights had been terminated (low SOE of benefit).130
- Parent-Child Interaction Therapy Adaptation Package (PCIT-AP): One RCT (efficacy trial) evaluating an adaptation of PCIT for physically abusive parents and their children, which included a motivational interviewing orientation, found significantly reduced child recidivism (median follow-up time 850 days postbaseline) in favor of the intervention;96 a trend towards this effect was found in a subsequent effectiveness trial that targeting parents referred for services by child welfare for neglect and/or physical abuse (low SOE of benefit).95
- SafeCare: One large-scale effectiveness RCT evaluated SafeCare, an intervention designed for parents involved with CPS due to neglect. The intervention resulted in significantly reduced child recidivism (rereports to child welfare) compared with usual care. As noted previously, the benefits of SafeCare were strongest for preschool-age children compared with the full study population, which included children up to 12 years of age (moderate SOE of benefit).100

##### Detailed Synthesis

We summarize the outcomes and SOE for each study in Table 106. We do not present a detailed synthesis section because all studies are discussed in previous sections of the Results chapter.

Table 106 Strength of evidence summary table: Maltreating parents

Intervention (G1) | Comparison (G2) | Outcome | N Trials, Participants | Strength of Evidence; Magnitude of Effect
Attachment and Biobehavioral Catch-up | Active control^a^ | Mental health and behavior | 1;^82,83^ 120 | Low; NR
Attachment and Biobehavioral Catch-up | Active control^a^ | Healthy caregiver-child relationship | 1;^81^ 120 | Low; NR
Attachment-based Intervention | Usual care | Healthy caregiver-child relationship | 1;^86^ 79 | Low; small to medium (d=0.47, r=0.36 or 0.37)
Child-Parent Psychotherapy^b^ | Usual care | Healthy caregiver-child relationship | 2,^87,88^ 141 | Low; medium to large (h=0.64 to 1.34)
Combined Parent-Child Cognitive Behavioral Therapy | Active control^a^ | Mental and behavioral health | 1,^107^ 75 | Low; medium (d=0.61)
New Orleans Intervention | Usual care | Safety | 1,^130^ 255 | Low RRR=0.67 to 0.75
New Orleans Intervention | Usual care | Permanency | 1,^130^ 240 | Low, G1 < G2
PCIT Adaptation Package | Usual care | Safety | 2,^95,96^ 153 | Low
SafeCare | Usual care | Safety | 1,^100^ 2175 | Moderate HR=0.74 to 0.83

a Active comparator is an approach derived from an intervention wherein the degree to which core components of the original model are implemented is unclear and/or core components are omitted or substantively modified.

b Intervention is a variant of relationship-based dyadic psychotherapy as developed and manualized by Cicchetti and colleagues.87,88

Note: Table is organized alphabetically by intervention name. All results are G1>G2 unless otherwise noted. For estimation of the magnitude of effect, we include only the statistically significant (p<0.05) effect sizes provided by study authors and do not calculate effect sizes as part of our analysis. Interpretation of the effect size as small, medium, or large is defined as Cohen’s d = 0.20, 0.50, and 0.80 and correlation coefficient r = 0.10, 0.30, and 0.50.^176^ When authors use eta we use the interpretation that the authors provide.177 We include an effect size range when more than two effect sizes are reported.

Abbreviations: G = group; HR = hazard ratio; N = number; NR = not reported; RRR = relative risk reduction.

#### Primary Caregiving Context: Foster and Kinship Caregivers

##### Key Points

- Attachment and Biobehavioral Catch-up: In three RCTs with different comparators, ABC with foster caregivers and young children improved child mental and behavioral health, caregiver-child relationship, and healthy development outcomes compared with both an active control and usual care (low SOE of benefit).77–80
- Bucharest Early Intervention Project (BEIP): The BEIP trial demonstrated numerous long-term child mental and behavioral health, caregiver-child relationship, and developmental benefits for young children removed from institutionalized care and placed in an enhanced foster care intervention compared with children who remained in institutional care (low SOE of benefit).117–129
- Keeping Foster and Kinship Parents Trained and Supported (KEEP): In one large effectiveness trial, KEEP resulted in greater improvements in child mental and behavioral health, caregiver-child relationship, and positive permanency outcomes (e.g., reunification with biological parent or another relative or adoption) compared with usual care (low SOE of benefit).91,92
- Middle School Success: An RCT evaluating an intervention that targeted both youth and their foster caregivers found significant benefit of the intervention on both child mental and behavioral health and placement outcomes compared with youth in routine foster care (low SOE of benefit).136,137
- Multidimensional Treatment Foster Care for Preschoolers (MTFC-P): In one RCT, a multimodal intervention that included foster parent training, therapeutic preschool, and medication management resulted in superior mental and behavioral health, caregiver-child, developmental, and increased rates of positive permanency outcomes compared with usual care (low SOE).138,139,141–144

##### Detailed Synthesis

We summarize the outcomes and SOE for each study in Table 107. We do not present a detailed synthesis section because all studies are discussed in previous sections of the Results chapter.

Table 107 Strength of evidence summary table: Foster or kinship parents

Intervention (G1) | Comparison (G2) | Outcome | N Trials, Participants | Strength of Evidence; Magnitude of Effect
Attachment and Biobehavioral Catch-up | Active control^a^ | Mental health and behavior | 1;^77,78^ 93 | Low; NR
Attachment and Biobehavioral Catch-up | Active control^a^ | Healthy caregiver-child relationship | 1;^79,81^ 46 | Low; NR
Attachment and Biobehavioral Catch-up | Active control^a^ | Healthy development | 1;^85^ 37 | Low; NR
Attachment and Biobehavioral Catch-up | Wait list | Mental and behavioral health | 1,^80^ 58 | Low; medium (partial eta squared=0.436 or 0.511)
Attachment and Biobehavioral Catch-up | Wait list | Healthy caregiver-child relationship | 1,^80^ 58 | Low; medium or large (partial eta squared=0.59 or 0.791)
Bucharest Early Intervention | Usual care (institutional care in Romania) | Mental health and behavior | 1,^118,120,123,125,129^ 136 | Low; odds ratio 2.8 [95%CI 1.2 to 6.4]
Bucharest Early Intervention | Usual care (institutional care in Romania) | Healthy caregiver-child relationship | 1,^121,125,127^ 136 | Low; NR
Bucharest Early Intervention | Usual care (institutional care in Romania) | Healthy development | 1,^117,119,121,122,124,126,128^ 136 | Low; effect size^b^ =0.47 or 0.62
Keeping Foster and Kinship Parents Trained and Supported | Usual care | Mental and behavioral health | 1,^91^ 700 | Moderate; small (d=0.26)
Keeping Foster and Kinship Parents Trained and Supported | Usual care | Healthy caregiver-child relationship | 1,^91^ 700 | Moderate; small (d=0.29)
Keeping Foster and Kinship Parents Trained and Supported | Usual care | Permanency | 1,^91^ 700 | Low
Middle School Success | Usual care | Mental health and behavior | 1,^136,137^ 100 | Low; small to medium (d=0.35 to 0.57)
Middle School Success | Usual care | Placement stability | 1,^136^ 100 | Low; medium (d=0.50)
Multi-dimensional Treatment Foster Care for Preschoolers | Usual care | Mental health and behavior | 1,^142^ 117 | Low; medium (d=0.64 to 0.68)
Multi-dimensional Treatment Foster Care for Preschoolers | Usual care | Healthy caregiver-child relationship | 1,^139,141^ 117 | Low; NR
Multi-dimensional Treatment Foster Care for Preschoolers | Usual care | Healthy development | 1,^138^ 23 | Low; NR
Multi-dimensional Treatment Foster Care for Preschoolers | Usual care | Permanency | 1,^140,143^ 90 | Low; NR

a Active comparator is an approach derived from an intervention wherein the degree to which core components of the original model are implemented is unclear and/or core components are omitted or substantively modified.

b Effect size measure is not specified, so we did not classify the magnitude of effect as small, medium, or large.

Note: Table is organized alphabetically by intervention name. All results are G1>G2 unless otherwise noted. For estimation of the magnitude of effect, we include only the statistically significant (p<0.05) effect sizes provided by study authors and do not calculate effect sizes as part of our analysis. Interpretation of the effect size as small, medium, or large is defined as Cohen’s d = 0.20, 0.50, and 0.80.^176^ When authors use partial eta squared we use the interpretation that the authors provide.80 We include an effect size range when more than two effect sizes are reported.

Abbreviations: CI = confidence interval; G = group; N = number; NR = not reported.

## Key Question 5 Comparative Effectiveness of Interventions With Children Exposed to Maltreatment for Engaging Children and/or Caregivers in Treatment

### Organization

This section takes the same organizational approach as that followed in key question (KQ) 1 and KQ 2. However, we identified a single intervention for inclusion in this KQ. We remind the reader that benefit is denoted in the results tables using a greater (“>“) sign (e.g., Group 1 > Group 2) and that within-group changes are denoted as improvement (“+”), detriment (“−”), or nonsignificant change (“ns”) for studies that provided these data.

### Description of Included Studies

We present the results of one trial (two articles) (Table 108)95,97 that assessed the effectiveness of an intervention for engaging participants in treatment and treatment retention.

Table 108 Number of trials and articles investigating treatment engagement or retention

Intervention | Trials
Motivational Intervention | 1^a^
Total | 1

a Reported in two articles.

### Motivational Intervention

We identified one large effectiveness randomized controlled trial (RCT), reported in two articles, evaluating a motivational orientation intervention designed to improve parenting program retention compared with a community standard orientation provided by the child welfare agency (Table 109).95,97 In a previous efficacy trial,96 the authors describe the intervention as a self-motivational intervention (MI) orientation comprising six clinic-based group sessions and employing a variety of motivational strategies including testimonials from parents who completed the Parent-Child Interaction Therapy (PCIT) adaptation, decisional exercises weighing the pros and cons of harsh physical discipline and of change, encouraging parents to develop their own list of parenting and parent-child relationship goals, elaborating discrepancy between current parent-child interactional patterns and personalized goals, and encouraging the parents’ commitment to change. The standard orientation comprised six sessions and was primarily informational and educational. Topics addressed in the standard orientation included the roles of child welfare and of the service provider organization, definitions of child maltreatment and how it affects children, and information about the possible insight-oriented links between a parent’s own childhood experiences and current parenting practices.

Table 109 Motivational intervention: Study characteristics

First Author et al., Year Country | Sample Description (Age Group) | Study Design and Duration | Comparison Groups | Baseline N | Risk of Bias
Chaffin et al., 2009^97^ | Maltreating parents of children ages 4 to 12 years, primarily neglected (70%) or physically abused (23%) | RCT 6 weeks (treatment engagement) and ≥18 to 20 weeks (treatment retention) | G1: PCIT-AP G2: MI +usual care G3: SAU orientation + PCIT G4: SAU | G1: 34 G2: 41 G3: 36 G4: 42 Overall N=153^a^ | Medium
Chaffin et al., 2011^95^ | Maltreating parents of children ages 4 to 12 years, primarily neglected (70%) or physically abused (23%) | RCT Median follow-up time=64 days (after 6-week intervention) | G1: MI G2: SAU orientation | G1: 75 G2: 78 Overall N=153^a^ | Medium

a 192 participants were randomized to one of the two orientation interventions, however, 39 were withdrawn before randomization to either PCIT or services as usual.

Note: Both articles listed here are from the same trial.

Abbreviations: G = group; MI = motivational orientation intervention; PCIT-AP = Parent-Child Interaction Therapy Adaptation Package (i.e., PCIT combined with motivational orientation); RCT = randomized controlled trial; SAU = services as usual (community standard orientation + parenting program).

In an initial article reporting on the results of the subsequent effectiveness trial, Chaffin and colleagues97 compare the MI with the community standard orientation, combined with either PCIT or the community standard didactic parenting program. In a subsequent article,95 the authors examine the relative effects of PCIT and the MI by contrasting varying combinations of experimental and usual care service components. Refer to the results for KQ 2 for the Parent-Child Interaction Therapy Adaptation Package for more detail about the study arms.

#### Key Points

- Treatment engagement: In one large effectiveness trial, maltreating parents who participated in the MI orientation reported greater readiness for change and other positive self-motivational outcomes compared with parents who participated in a standard orientation (moderate strength of evidence [SOE]).95,97
- Treatment retention: In one large effectiveness trial, maltreating parents who participated in PCIT combined with the MI orientation had higher treatment completion rates compared with parents who participated in a standard orientation combined with PCIT (moderate SOE)97 (Table 81).

#### Detailed Synthesis

Table 110 presents the results of the MI trial;95,97 additional study details are provided in the evidence tables (Appendix E). The authors first randomized participants either to the MI orientation or to the standard orientation conditions. In the first article,97 Chaffin and colleagues assess participants’ readiness for change upon completion of their respective orientations. Parents who participated in the MI orientation had consistently greater improvements on the overall readiness scale and on the “readiness to change” and “attitude toward the program” subscales compared with those in the standard orientation. Participants were then randomized a second time to receive either PCIT or the standard parenting program. The PCIT and standard parenting programs had a comparable number of sessions. The study found higher treatment completion rates among participants who received PCIT combined with the MI orientation compared with participants who received any of the other conditions: (a) the MI condition combined with the community standard parenting program, (b) the standard orientation in conjunction with PCIT, or (c) the services as usual (standard orientation combined with standard parenting program). In the second article the authors again compared participants’ readiness for change across study arms and provide an effect size.95 Though participants in both orientation conditions reported increased readiness for change, caregivers who participated in the MI orientation reported greater improvements in readiness for change.

Table 110 Results: Motivational intervention

First Author et al., Year | Comparison Groups | Treatment Engagement^a^ | Treatment Retention
Chaffin et al, 2009^97^ | G1: PCIT-AP G2: MI + SAU G3: SAU orientation + PCIT G4: SAU | Increased readiness to change total score (Readiness for Parenting Change Scale) (G1, G2)^+^ > (G3, G4)^+^, p<0.01 Increased readiness to change (Readiness for Parenting Change Scale subscale) (G1, G2)>(G3, G4), p<0.05 Better attitude to the program (Readiness for Parenting Change Scale subscale) (G1, G2)>(G3, G4), p<0.05 Increased self-efficacy (Readiness for Parenting Change Scale subscale) (G1, G2)>(G3, G4), p=0.06 | Higher percentage of treatment completers G1>G2, p=0.01 G1>G3, p=0.05 G1>G4, p=0.05
Chaffin et al., 2011^95^ | G1: MI G2: SAU orientation | Increased readiness to change total score (Readiness for Parenting Change Scale) G1^+^>G2^+^, p<0.01 d=0.33^b^ | NA

a Treatment engagement outcomes were assessed at the end of the motivational intervention, before participants began the second phase of intervention (i.e., either the PCIT adaptation or usual care parenting program).

b Cohen’s d effect size index of the difference between groups means: 0.20 = small; 0.50 = medium; 0.80 = large.176

Note: Greater comparative benefit is denoted in the results tables using a greater (“>“) sign.

Abbreviations: G = group; MI = motivational orientation intervention; NA = not applicable; PCIT-AP = Parent-Child Interaction Therapy Adaptation Package (i.e., PCIT combined with motivational orientation intervention); SAU = services as usual (community standard orientation + parenting program); SM = self-motivational orientation.

Although the body of evidence is limited to a single trial for the MI orientation, we graded the SOE as moderate for improved treatment and engagement outcomes due to the size of the study and because it was an effectiveness trial (Table 111).

Table 111 Strength of evidence for treatment engagement and retention outcomes: Motivational intervention

Intervention (G1) | Comparator (G2) | Outcome | Number of Trials, Number of Participants | SOE and Magnitude of Effect
Motivational Intervention | Standard orientation | Treatment engagement | 1^95,97^; 153 | Moderate Small (d=0.33)
Parent-Child Interaction Therapy Adaptation Package^d^ | Parent-Child Interaction Therapy plus standard orientation | Treatment retention | 1^97^; 153 | Moderate

a ”Package” refers to the combination of PCIT with the motivational orientation intervention.

Note: For estimation of the magnitude of effect, we include only the statistically significant (p<0.05) effect sizes provided by study authors and do not calculate effect sizes as part of our analysis. Interpretation of the effect size as small, medium, or large is defined as Cohen’s d = 0.20, 0.50, and 0.80.^176^ Authors did not report effect sizes for some measures.

Abbreviations: G = group; MI = motivational orientation intervention; PCIT-AP = Parent-Child Interaction Therapy Adaptation Package (i.e., PCIT combined with motivational orientation); RCT = randomized controlled trial; SAU = services as usual (community standard orientation + parenting program).

## Key Question 6 Adverse Events Associated With Interventions for Children Exposed to Maltreatment

### Organization

This section takes the same organizational approach as that followed in key question (KQ) 1 and KQ 2. However, we identified a single intervention for inclusion in this KQ.

### Description of Included Studies

We require studies to report active surveillance of harms to be included in KQ 6. Only one study met inclusion criteria for KQ 6 (Table 112). Since this comparative evidence review (CER) focuses on a particularly vulnerable population, we also describe what appear to be spontaneously reported adverse events; however, we do not grade the strength of evidence (SOE) for these outcomes.

Table 112 Number of trials and articles investigating adverse events

Parenting Interventions | Trials
Trauma-Focused Cognitive Behavioral Therapy115 | 1
Total | 1

### Active Surveillance of Harms (Included in KQ 6)

#### Trauma-Focused Cognitive Behavioral Therapy

##### Key Points

- Adverse events: Compared with an active (derived) comparator, a greater number of children in the comparative condition experienced removal from treatment because of their persistent sexually inappropriate behavior involving another child or adult (low SOE).

##### Detailed Synthesis

Only one study reported active surveillance of adverse events; this trial compared TF-CBT with nondirective supportive therapy.115 Specifically, the study assessed the incidence of sexually inappropriate behavior that involved another child or adult. During the trial, Cohen and colleagues report that 6 of the 28 children in nondirective supportive therapy and 0 of the 39 children in TF-CBT persistently exhibited such behavior and required removal from treatment. We rate the SOE for the comparative harms of these two interventions as low (Table 113) as fewer children in the TF-CBT group experienced the adverse event of removal from treatment.

Table 113 Detailed strength of evidence grading table: Trauma-focused cognitive behavioral therapy

Intervention and Comparator | Outcome | Studies; Subjects | Risk of Bias | Consistency | Directness | Precision | SOE Grade; Magnitude of Effect
TF-CBT vs. nondirective supportive therapy | Adverse events | 1;^115^ 67 | M | Unknown, single study | Direct | Precise | Low

Note: For estimation of the magnitude of effect, we include only the statistically significant (p<0.05) effect sizes provided by study authors and do not calculate effect sizes as part of our analysis. Authors did not report an effect size for this outcome.

Abbreviations: M = medium; SOE = strength of evidence; TF-CBT = Trauma-Focused Cognitive Behavioral Therapy.

### Spontaneous Reporting of Adverse Events

#### Parent-Child Interaction Therapy Adaptation

##### Key Points

- None. This study does not meet KQ 6 inclusion criteria.

##### Detailed Synthesis

Because this CER focuses on a particularly vulnerable population, we also report here any instance of adverse events described by study authors. We do not rate the SOE for this outcome because it did not meet our inclusion criteria for this KQ; that is, the article does not report active surveillance of adverse events.

In a trial comparing a PCIT Adaptation Package with usual care,95,97 the authors described an instance of an adverse event but did not describe their method of monitoring adverse events. In the study, a participant whose child was in foster care requested to be removed from the PCIT condition because of difficulties separating from the child after dyadic sessions. The authors did not report any such instances for the other treatment groups.