# References

1 Felitti VJ, Anda RF, Nordenberg D, et al. Relationship of childhood abuse and household dysfunction to many of the leading causes of death in adults. The Adverse Childhood Experiences (ACE) Study. Am J Prev Med. May. 1998;14(4):245-58. [pmid: 9635069].
2 Turner HA, Finkelhor D, Ormrod R. The effect of lifetime victimization on the mental health of children and adolescents. Soc Sci Med. Jan. 2006;62(1):13-27. [pmid: 16002198].
3 MacMillan HL, Fleming JE, Streiner DL, et al. Childhood abuse and lifetime psychopathology in a community sample. Am J Psychiatry. 2001;158(11):1878-83. [pmid: 11691695].
4 Widom CS, DuMont K, Czaja SJ. A prospective investigation of major depressive disorder and comorbidity in abused and neglected children grown up. Arch Gen Psychiatry. Jan. 2007;64(1):49-56. [pmid: 17199054].
5 Widom CS, Marmorstein NR, White HR. Childhood victimization and illicit drug use in middle adulthood. Psychol Addict Behav. Dec. 2006;20(4):394-403. [pmid: 17176174].
6 World Health Organization and International Society for Prevention of Child Abuse and Neglect. Preventing maltreatment: a guide to taking action and generating evidence. Geneva, Switzerland. 2006. whqlibdoc.who.int/publications/2006/9241594365_eng.pdf. Accessed on October 20, 2010.
7 Gilbert R, Widom CS, Browne K, et al. Burden and consequences of child maltreatment in high-income countries. Lancet. Jan. 3. 2009;373(9657):68-81. [pmid: 19056114].
8 Courtois CA, Ford JD, editors. Treating Complex Traumatic Stress Disorders: An Evidence-Based Guide. New York. The Guilford Press. 2009.
9 Perry BD. Incubated in terror: Neurodevelopmental factors in the “cycle of violence”. Osofsky J, editor. Children in a Violent Society. New York. Guilford Press. 1997:124-49.
10 Shonkoff JP, Phillips D, editors. From neurons to neighborhoods: the science of early childhood development. Washington, DC. National Academy Press. 2000.
11 Cicchetti DV, Lynch M. Failures in the expectable environment and their impact on individual development: The case of child maltreatment. Cicchetti DV, Cohen DJ, editors. Developmental Psychopathology: Vol. 2. Risk, disorder, and adaptation. New York. Wiley. 1995:32-71.
12 Egeland B, Yates T, Appleyard K, et al. The long-term consequences of maltreatment in the early years: A developmental pathway model to antisocial behavior. Soc Pol Res Pract. 2002;5(4):249-60. 2002-11383-001.
13 Middlebrooks JS, Audage NC. The effects of childhood stress on health across the lifespan. Atlanta, GA. Centers for Disease Control and Prevention, National Center for Injury Prevention and Control. 2008.
14 Chu AT, Lieberman AF. Clinical implications of traumatic stress from birth to age five. Annu Rev Clin Psychol. Apr. 27. 2010;6:469-94. [pmid: 20192799].
15 Cassidy J, Mohr JJ. Unsolvable fear, trauma, and psychopathology: theory, research and clinical considerations related to disorganized attachment across the lifespan. Clin Psychol Sci Pract. 2001;8(3):275-98.
16 Matheson Nicholas J, Harnden A, Perera R, et al. Neuraminidase inhibitors for preventing and treating influenza in children. Cochrane Database Syst Rev. 2007;(1):CD002744. [pmid: 17253479].
17 Flaherty EG, Thompson R, Litrownik AJ, et al. Effect of early childhood adversity on child health. Arch Pediatr Adolesc Med. Dec. 2006;160(12):1232-8. [pmid: 17146020].
18 MacKenzie MJ, Kotch JB, Lee L-C, et al. A cumulative ecological–transactional risk model of child maltreatment and behavioral outcomes: Reconceptualizing early maltreatment report as risk factor. Child Youth Serv Rev. 2011;33(11):2392-8. 2011-22647-015.
19 Tabone JK, Guterman NB, Litrownik AJ, et al. Developmental trajectories of behavior problems among children who have experienced maltreatment: Heterogeneity during early childhood and ecological predictors. J Emot Behav Disord. 2011;19(4):204-16. 2011-28146-002.
20 Agency for Healthcare Research and Quality. What Is Comparative Effectiveness Research. Rockville, MD. Agency for Healthcare Research and Quality. effectivehealthcare.ahrq.gov/index.cfm/what-is-comparative-effectiveness-research1/. Accessed July 16, 2012.
21 Slutsky J, Atkins D, Chang S, et al. AHRQ series paper 1: comparing medical interventions: AHRQ and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):481-3. [pmid: 18834715].
22 Groves B. Early intervention as prevention: addressing trauma in young children. Res Pol Pract Child Ment Health. 2007;21(1):16-8.
23 Lieberman AF, van Horn P, Ozer EJ. Preschooler witnesses of marital violence: Predictors and mediators of child behavior problems. Dev Psychopathol. 2005;17(2):385-96. 2005-05658-005. [pmid: 16761550].
24 Osofsky JD, editor. Young Children and Trauma: Interventions and Treatment. New York. Guilford Press. 2007.
25 Schechter DS, Willheim E. The effects of violent experiences on infants and young children. Zeanah CH, editor. Handbook of Infant Mental Health. 3rd ed. New York. Guilford Press. 2009.
26 Hamby S, Finkelhor D, Turner H, et al. The overlap of witnessing partner violence and child maltreatment and other victimizations in a nationally representative survey of youth. Child Abuse Negl. 2010;34:734-41. [pmid: 20850182].
27 Leeb RT, Paulozzi L, Melanson C, et al. Child maltreatment surveillance: uniform definitions for public health and recommended data elements, version 1.0. Atlanta, GA. Centers for Disease Control and Prevention, National Center for Injury Prevention and Control. 2008. www.cdc.gov/violenceprevention/pdf/CM_Surveillance-a.pdf. Accessed November 15, 2010.
28 The Child Abuse Prevention and Treatment Act As Amended by P.L. 111-320, the CAPTA Reauthorization Act of 2010. U.S. Department of Health and Human Services, Administration for Children and Families, Administration on Children, Youth and Families, Children’s Bureau. 2011. www.acf.hhs.gov/programs/cb/laws_policies/cblaws/capta/capta2010.pdf. Accessed August 15, 2011.
29 Finkelhor D, Turner H, Ormrod R, et al. Trends in childhood violence and abuse exposure: evidence from 2 national surveys. Arch Pediatr Adolesc Med. Mar. 2010;164(3):238-42. [pmid: 20194256].
30 Finkelhor D, Ormrod RK, Turner HA. The developmental epidemiology of childhood victimization. J Interpers Violence. 2009;24(5):711-31. 2009-05365-001. [pmid: 18467689].
31 U.S. Department of Health and Human Services. Child Maltreatment 2010. Washington, DC. Administration for Children and Families. 2011. www.acf.hhs.gov/programs/cb/pubs/cm10/index.htm. Accessed February 14, 2012.
32 Fang XM, Brown DS, Florence CS, et al. The economic burden of child maltreatment in the United States and implications for prevention. Child Abuse Negl. Feb. 2012;36(2):156-65. [pmid: 22300910].
33 Bartholet E, Wulczyn F, Barth RP, et al. Race and Child Welfare. Chicago, IL. Chapin Hall at the University of Chicago. 2011. www.chapinhall.org/sites/default/files/publications/06_27_11_Issue%20Brief_F.pdf. Accessed February 14, 2012.
34 Chibnall S, Dutch NM, Jones-Harden B, et al. Children of Color in the Child Welfare system: Perspectives from the Child Welfare community. Washington, DC. Child Welfare Information Gateway, U.S. Department of Health & Human Services, Administration for Children & Families. 2003. Accessed February 14, 2012.
35 Centers for Disease Control and Prevention (CDC). Child maltreatment: risk and protective factors. 2009. www.cdc.gov/violenceprevention/childmaltreatment/riskprotectivefactors.html. Accessed October 20, 2010.
36 U.S. Department of Health and Human Services, Office on Child Abuse and Neglect. A coordinated response to child abuse and neglect: the foundation for practice. Washington, DC. 2003. www.childwelfare.gov/edtoolkit/topics/advocacy_and_community_organizing/coordinated_response.html. Accessed October 20, 2010.
37 Cicchetti D, Rizley R. Developmental perspectives on the etiology, intergenerational transmission, and sequelae of child maltreatment. New Dir Child Adolesc Dev. 1981;11:35-51.
38 Harmer AL, Sanderson J, Mertin P. Influence of negative childhood experiences on psychological functioning, social support, and parenting for mothers recovering from addiction. Child Abuse Negl. May. 1999;23(5):421-33. [pmid: 10348379].
39 Kissin WB, Svikis DS, Morgan GD, et al. Characterizing pregnant drug-dependent women in treatment and their children. J Subst Abuse Treat. Jul. 2001;21(1):27-34. [pmid: 11516924].
40 McCauley J, Kern DE, Kolodner K, et al. Clinical characteristics of women with a history of childhood abuse: unhealed wounds. JAMA. May. 7. 1997;277(17):1362-8. [pmid: 9134941].
41 Suchman NE, McMahon TJ, Slade A, et al. How early bonding, depression, illicit drug use, and perceived support work together to influence drug-dependent mothers’ caregiving. Am J Orthopsychiatry. Jul. 2005;75(3):431-45. [pmid: 16060738].
42 Zeanah C, Zeanah P. Intergenerational transmission of maltreatment: Insights from attachment theory and research. Psychiatry. May. 1989;52(2):177-96. [pmid: 2660176].
43 Child Welfare Information Gateway. Understanding the effects of maltreatment on early brain development. 2009. www.childwelfare.gov/pubs/issue_briefs/brain_development/brain_development.pdf. Accessed September 29, 2010.
44 Johnson EO, Kamilaris TC, Chrousos GP, et al. Mechanisms of stress: a dynamic overview of hormonal and behavioral homeostasis. Neurosci Biobehav Rev. 1992;16(2):115-30. [pmid: 1630726].
45 Gunnar MR, Fisher PA. the Early Experience Stress and Prevention Network. Bringing basic research on early experience and stress neurobiology to bear on preventive interventions for neglected and maltreated children. Deb Psychopathol. 2006;18:651-77. [pmid: 17152395].
46 Pears K, Fisher PA. Developmental, cognitive, and neuropsychological functioning in preschool-aged foster children: Associations with poor maltreatment and placement history. J Dev Behav Pediatr. 2005;26:112-22. [pmid: 15827462].
47 McBurnett K, Lahey BB, Rathouz PJ, et al. Low salivary cortisol and persistent aggression in boys referred for disruptive behavior. Arch Gen Psychiatry. Jan. 2000;57(1):38-43. [pmid: 10632231].
48 Nelson CA. A neurobiological perspective on early human deprivation. Child Dev Perspect. 2007;1(1):13-8. ISI:000207179600003.
49 Pajer K, Gardner W, Rubin RT, et al. Decreased cortisol levels in adolescent girls with conduct disorder. Arch Gen Psychiatry. Mar. 2001;58(3):297-302. [pmid: 11231837].
50 Baes CV, Tofoli SMD, Martins CMS, et al. Assessment of the hypothalamic-pituitary-adrenal axis activity: glucocorticoid receptor and mineralcorticoid receptor function in dperession with early life stress—a systematic review. Acta Neuropsychiatrica. 2012;24:4-15.
51 Casanueva C, Smith K, Dolan M, et al. NSCAW II Baseline Report: Maltreatment. OPRE Report #2011-27c. Washington, DC. Office of Planning, Research and Evaluation, Administration for Children and Families, U.S. Department of Health and Human Services. 2011. www.acf.hhs.gov/programs/opre/abuse_neglect/nscaw/reports/nscaw2_maltreatment/nscaw2_maltreatment.pdf.
52 Dorsey S, Farmer EMZ, Barth RP, et al. Current status and evidence base of training for foster and treatment foster parents. Child Youth Serv Rev. 2008;30(12):1403-16. [pmid: 21647272].
53 Administration for Children and Families. National Survey of Child and Adolescent Well-Being (NSCAW): CPS Sample Component, Wave 1 Data Analysis Reportq. 2005. www.acf.hhs.gov/programs/opre/abuse_neglect/nscaw/reports/cps_sample/cps_report_revised_090105.pdf. Accessed January 7, 2009.
54 Rubin DM, O’Reilly ALR, Hafner L, et al. Placement stability and early behavioral outcomes among children in out-of-home care. Haskins R, Wulczyn F, Webb M, editors. Child Protection: Using Research to Improve Policy and Practice. Washington, DC. Brookings Institution. 2007:171-86.
55 Wildfire J, Barth RP, Green RL. Predictors of reunification. Haskins R, Wulczyn F, Webb MB, editors. Child Protection: Using Research to Improve Policy and Practice. Washington, DC. Brookings Institution. 2007:155-70.
56 Wulczyn F, Hislop K, George R. Foster Care Dynamics 1983–1988. Chicago. Chapin Hall Center for Children. 2001.
57 Wulczyn F. Family reunification. Child Fam Foster Care. Winter. 2004;14(1).
58 Wulczyn F, Hislop KB, Harden BJ. The placement of infants in foster care. Infant Ment Health J. September. 2002;23:454-75.
59 Rubin DM, Allessandrini EA, Feudtner C, et al. Placement stability and mental health costs for children in foster care. Pediatrics. 2004;113:1336-41. [pmid: 15121950].
60 Dozier M, Bick J. Changing caregivers: coping with early adversity. Psychiatric Annals. 2007;37:411-5.
61 Smyke AT, Breidenstine AS. Foster care in early childhood. Zeanah CH, editor. Handbook of Infant Mental health. 2nd ed. Guilford Press. 2009:500-15.
62 Shonkoff JP. Excessive Stress Disrupts the Architecture of the Developing Brain. 2005. www.developingchild.net/pubs/wp/Stress_Disrupts_Architecture_Developing_Brain.pdf. Accessed April 2008.
63 The National Child Traumatic Stress Network. Complex trauma in children and adolescents. White Paper from the National Child Traumatic Stress Network, Complex Trauma Task Force. National Center for Child Traumatic Stress. Los Angeles, Calif., and Durham, N.C. 2003.
64 Zero to Three. Diagnostic classification of mental health and developmental disorders of infancy and early childhood, (DC: 0-3R) revised ed. Washington. Zero to Three Press. 2005.
65 van der Kolk BA, Pynoos RS, Cicchetti D, et al. Proposal to include a developmental trauma disorder diagnosis for children and adolescents in DSM-V. 2009. www.traumacenter.org/announcements/DTD_papers_Oct_09.pdf. Accessed August 15, 2011.
66 Leslie LK, Hurlburt MS, James S, et al. Relationship between entry into child welfare and Mental Health Service Use. Psychiatr Serv. 2005;56(8):981-7. 2005-09093-011. [pmid: 16088016].
67 Casanueva CE, Cross TP, Ringeisen H. Developmental needs and individualized family service plans among infants and toddlers in the child welfare system. Child Maltreat. 2008;13(3):245-58. [pmid: 18495948].
68 Burns BJ, Phillips SD, Wagner HR, et al. Mental health need and access to mental health services by youths involved with child welfare: a national survey. J Am Acad Child Adolesc Psychiatry. Aug. 2004;43(8):960-70. [pmid: 15266190].
69 Stahmer AC, Leslie LK, Hurlburt M, et al. Developmental and behavioral needs and service use for young children in child welfare. Pediatrics. 2005;116:891-900. [pmid: 16199698].
70 Vandivere S, Malm K, Radel L. Adoption USA: a chartbook based on the 2007 National Survey of Adoptive Parents (NSAP): The US Department of Health and Human Services, Office of the Secretary for Planning and Evaluation. 2009.
71 Juffer F, van Ijzendoorn MH. Behavior problems and mental health referrals of international adoptees: a meta-analysis. JAMA. May. 25. 2005;293(20):2501-15. [pmid: 15914751].
72 Kreider RM, Cohen PN. Disability among internationally adopted children in the United States. Pediatrics. Nov. 2009;124(5):1311-8. [pmid: 19858154].
73 dos Reis S, Zito JM, Safer DJ, et al. Mental health services for youths in foster care and disabled youths. Am J Public Health. Jul. 2001;91(7):1094-9. [pmid: 11441737].
74 Halfon N, Mendonca A, Berkowitz G. Health status of children in foster care. The experience of the Center for the Vulnerable Child. Arch Pediatr Adolesc Med. Apr. 1995;149(4):386-92. [pmid: 7704166].
75 Harman JS, Childs GE, Kelleher KJ. Mental health care utilization and expenditures by children in foster care. Arch Pediatr Adolesc Med. Nov. 2000;154(11):1114-7. [pmid: 11074852].
76 Geen R, Sommers AS, Cohen M. Medicaid Spending on Foster Children. The Urban Institute. Washington, DC. 2005.
77 Dozier M, Peloso E, Lindhiem O, et al. Developing evidence-based interventions for foster children: An example of a randomized clinical trial with infants and toddlers. J Soc Issues. 2006;62(4):767-85. ISI:000241562500006.
78 Dozier M, Peloso E, Lewis E, et al. Effects of an attachment-based intervention on the cortisol production of infants and toddlers in foster care. Dev Psychopathol. Summer. 2008;20(3):845-59. [pmid: 18606034].
79 Dozier M, Lindhiem O, Lewis E, et al. Effects of a foster parent training program on young children’s attachment behaviors: Preliminary evidence from a randomized clinical trial. Child Adolesc Soc Work J. Aug. 2009;26(4):321-32. [pmid: 22065891].
80 Sprang G. The efficacy of a relational treatment for maltreated children and their families. Child Adolesc Ment Health. 2009;14(2):81-8. 2009-06028-005.
81 Bernard K, Dozier M, Bick J, et al. Enhancing attachment organization among maltreated children: results of a randomized clinical trial. Child Dev. Mar. 2012;83(2):623-36. [pmid: 22239483].
82 Dozier M, Bernard K, Bick J, et al. Normalizing Neglected Children’s Blunted Diurnal Cortisol Rhythms: The Effects of an Early Intervention. unpublished B.
83 Dozier M, Bernard K, Ross E, et al. The Effects of an Attachment-Based Intervention on Children’s Expression of Negative Affect in a Challenging Task. unpublished A.
84 Gershater-Molko RM, Lutzker JR, Wesch D. Using recidivism data to evaluate project safecare: teaching bonding, safety, and health care skills to parents. Child Maltreat. Aug. 2002;7(3):277-85. [pmid: 12139194].
85 Lewis-Morrarty E, Dozier M, Bernard K, et al. Cognitive flexibility and theory of mind outcomes among foster children: Preschool follow-up results of a randomized clinical trial. J Adolesc Health. August. 2012;51(2 Suppl):S17-S22. [pmid: 22794528].
86 Moss E, Dubois-Comtois K, Cyr C, et al. Efficacy of a home-visiting intervention aimed at improving maternal sensitivity, child attachment, and behavioral outcomes for maltreated children: a randomized control trial. Dev Psychopathol. Feb. 2011;23(1):195-210. [pmid: 21262048].
87 Cicchetti D, Rogosch FA, Toth SL. Fostering secure attachment in infants in maltreating families through preventive interventions. Dev Psychopathol. Summer. 2006;18(3):623-49. [pmid: 17152394].
88 Toth SL, Maughan A, Manly JT, et al. The relative efficacy of two interventions in altering maltreated preschool children’s representational models: implications for attachment theory. Dev Psychopathol. Fall. 2002;14(4):877-908. [pmid: 12549708].
89 Linares LO, Montalto D, Li M, et al. A promising parenting intervention in foster care. J Consult Clin Psychol. Feb. 2006;74(1):32-41. [pmid: 16551141].
90 Wesbster-Stratton C. The Incredible Years Training series. Office of Juvenile Justice and Delinquency Prevention Bulletin Review. 2000;(June):1-24.
91 Chamberlain P, Price J, Leve LD, et al. Prevention of behavior problems for children in foster care: outcomes and mediation effects. Prev Sci. Mar. 2008;9(1):17-27. [pmid: 18185995].
92 Price JM, Chamberlain P, Landsverk J, et al. Effects of a foster parent training intervention on placement changes of children in foster care. Child Maltreat. Feb. 2008;13(1):64-75. ISI:000252471700006. [pmid: 18174349].
93 MacMillan HL, Thomas BH, Jamieson E, et al. Effectiveness of home visitation by public-health nurses in prevention of the recurrence of child physical abuse and neglect: a randomised controlled trial. Lancet. May. 21–27. 2005;365(9473):1786-93. [pmid: 15910951].
94 Olds DL, Eckenrode J, Henderson CR Jr, et al. Long-term effects of home visitation on maternal life course and child abuse and neglect. Fifteen-year follow-up of a randomized trial. JAMA. Aug. 27. 1997;278(8):637-43. [pmid: 9272895].
95 Chaffin M, Funderburk B, Bard D, et al. A combined motivation and Parent-Child Interaction Therapy package reduces child welfare recidivism in a randomized dismantling field trial. J Consult Clin Psychol. Feb. 2011;79(1):84-95. [pmid: 21171738].
96 Chaffin M, Silovsky JF, Funderburk B, et al. Parent-child interaction therapy with physically abusive parents: efficacy for reducing future abuse reports. J Consult Clin Psychol. Jun. 2004;72(3):500-10. [pmid: 15279533].
97 Chaffin M, Valle LA, Funderburk B, et al. A motivational intervention can improve retention in PCIT for low-motivation child welfare clients. Child Maltreat. Nov. 2009;14(4):356-68. [pmid: 19258303].
98 Bell SK, Eyberg SM. Parent-child interaction therapy. VanderCreek L, Knapp S, Jackson TL, editors. Innovations in clinical practice: A source book. Sarasota, FL. Professional Resource Press. 2002;20.
99 Jouriles EN, McDonald R, Rosenfield D, et al. Improving parenting in families referred for child maltreatment: a randomized controlled trial examining effects of Project Support. J Fam Psychol. Jun. 2010;24(3):328-38. [pmid: 20545406].
100 Chaffin M, Hecht D, Bard D, et al. A statewide trial of the SafeCare home-based services model with parents in Child Protective Services. Pediatrics. Mar. 2012;129(3):509-15. [pmid: 22351883].
101 Jinich S, Litrownik AJ. Coping with sexual abuse: development and evaluation of a videotape intervention for nonoffending parents. Child Abuse Negl. Feb. 1999;23(2):175-90. [pmid: 10075186].
102 Center for Mental Health Services (CMHS), Substance Abuse and Mental Health Services Administration, U.S. Department of Health and Human Services. National Child Traumatic Stress Network empirically supported treatments and promising practices. 2010. www.nctsn.org/nccts/nav.do?pid=ctr_top_trmnt_prom. Accessed November 10, 2010.
103 US Department of Health and Human Services, Substance Abuse and Mental Health Services Administration. NREPP: SAMHSA’s national registry of evidence-based programs and practices. www.nrepp.samhsa.gov.
104 U.S. Department of Health and Human Services, Administration for Children and Families. Child welfare information gateway. www.childwelfare.gov. Accessed November 10, 2010.
105 Office of Juvenile Justice and Delinquency Prevention. Office of Juvenile Justice and Delinquency Prevention Model Programs Guide. www.ojjdp.gov/mpg/. Accessed on November 10, 2010.
106 California evidence-based clearinghouse for child welfare. www.cebc4cw.org. Accessed November 10, 2010.
107 Runyon MK, Deblinger E, Steer RA. Group Cognitive Behavioral Treatment for Parents and Children At-Risk for Physical Abuse: An Initial Study. Child Fam Behav Ther. 2010;32(3):196-218. WOS:000281079800002.
108 Cohen JA, Deblinger E, Mannarino AP, et al. A multisite, randomized controlled trial for children with sexual abuse-related PTSD symptoms. J Am Acad Child Adolesc Psychiatry. Apr. 2004;43(4):393-402. [pmid: 15187799].
109 Deblinger E, Lippmann J, Steer R. Sexually abused children suffering posttraumatic stress symptoms: Initial treatment outcome findings. Child Maltreat. 1996;1(4):310-21.
110 Kolko DJ. Individual cognitive behavioral treatment and family therapy for physically abused children and their offending parents: A comparison of clinical outcomes. Child Maltreat. 1996;1:322-42.
111 Kolko DJ, Swenson C. Assessing and treating physically abused children and their families: A cognitive-behavioral approach. Thousand Oaks, CA. Sage Publications. 2002.
112 Jaberghaderi N, Greenwald R, Rubin A, et al. A comparison of CBT and EMDR for sexually-abused Iranian girls. Clin Psychol Psychother. 2004;11:358-68.
113 Trowell J, Kolvin I, Weeramanthri T, et al. Psychotherapy for sexually abused girls: psychopathological outcome findings and patterns of change. Br J Psychiatry. Mar. 2002;180:234-47. [pmid: 11872516].
114 McGain B, McKinzey RK. The efficacy of group treatment in sexually abused girls. Child Abuse Negl. Sep. 1995;19(9):1157-69. [pmid: 8528821].
115 Cohen JA, Mannarino AP. A treatment outcome study for sexually abused preschool children: initial findings. J Am Acad Child Adolesc Psychiatry. Jan. 1996;35(1):42-50. [pmid: 8567611].
116 Deblinger E, Stauffer LB, Steer RA. Comparative efficacies of supportive and cognitive behavioral group therapies for young children who have been sexually abused and their nonoffending mothers. Child Maltreat. Nov. 2001;6(4):332-43. [pmid: 11675816].
117 Bos KJ, Fox N, Zeanah CH, et al. Effects of early psychosocial deprivation on the development of memory and executive function. Front Behav Neurosci. 2009;3:16. [pmid: 19750200].
118 Bos KJ, Zeanah CH Jr, Smyke AT, et al. Stereotypies in children with a history of early institutional care. Arch Pediatr Adolesc Med. May. 2010;164(5):406-11. [pmid: 20439790].
119 Fox NA, Almas AN, Degnan KA, et al. The effects of severe psychosocial deprivation and foster care intervention on cognitive development at 8 years of age: findings from the Bucharest Early Intervention Project. J Child Psychol Psychiatry. Sep. 2011;52(9):919-28. [pmid: 21244422].
120 Ghera MM, Marshall PJ, Fox NA, et al. The effects of foster care intervention on socially deprived institutionalized children’s attention and positive affect: results from the BEIP study. J Child Psychol Psychiatry. Mar. 2009;50(3):246-53. [pmid: 19309327].
121 Johnson DE, Guthrie D, Smyke AT, et al. Growth and associations between auxology, caregiving environment, and cognition in socially deprived Romanian children randomized to foster vs ongoing institutional care. Arch Pediatr Adolesc Med. Jun. 2010;164(6):507-16. [pmid: 20368481].
122 Marshall PJ, Reeb BC, Fox NA, et al. Effects of early intervention on EEG power and coherence in previously institutionalized children in Romania. Dev Psychopathol. Summer. 2008;20(3):861-80. [pmid: 18606035].
123 McDermott JM, Westerlund A, Zeanah CH, et al. Early adversity and neural correlates of executive function: Implications for academic adjustment. Dev Cog Neurosci. 2012;2(Suppl 1):S59-S66. 2012-04022-007.
124 McLaughlin KA, Fox NA, Zeanah CH, et al. Adverse rearing environments and neural development in children: the development of frontal electroencephalogram asymmetry. Biol Psychiatry. Dec. 1. 2011;70(11):1008-15. [pmid: 21962332].
125 McLaughlin KA, Zeanah CH, Fox NA, et al. Attachment security as a mechanism linking foster care placement to improved mental health outcomes in previously institutionalized children. J Child Psychol Psychiatry. Jan. 2012;53(1):46-55. [pmid: 21733136].
126 Nelson CA 3rd, Zeanah CH, Fox NA, et al. Cognitive recovery in socially deprived young children: the Bucharest Early Intervention Project. Science. Dec. 21. 2007;318(5858):1937-40. [pmid: 18096809].
127 Smyke AT, Zeanah CH, Fox NA, et al. Placement in foster care enhances quality of attachment among young institutionalized children. Child Dev. Jan–Feb. 2010;81(1):212-23. [pmid: 20331663].
128 Windsor J, Benigno JP, Wing CA, et al. Effect of foster care on young children’s language learning. Child Dev. Jul–Aug. 2011;82(4):1040-6. [pmid: 21679171].
129 Zeanah CH, Egger HL, Smyke AT, et al. Institutional rearing and psychiatric disorders in Romanian preschool children. Am J Psychiatry. Jul. 2009;166(7):777-85. [pmid: 19487394].
130 Zeanah CH, Larrieu JA, Heller SS, et al. Evaluation of a preventive intervention for maltreated infants and toddlers in foster care. J Am Acad Child Adolesc Psychiatry. 2001:214-21. [pmid: 11211370].
131 Taussig HN, Culhane SE. Impact of a mentoring and skills group program on mental health outcomes for maltreated children in foster care. Arch Pediatr Adolesc Med. Aug. 2010;164(8):739-46. [pmid: 20679165].
132 Taussig HN, Culhane SE, Garrido E, et al. RCT of a mentoring and skills group program: Placement and permanency outcomes for foster youth. Pediatrics. Jul. 2012;130(1):e33-9. [pmid: 22689870].
133 Greenberg MT, Kusche C. Promoting alternative thinking strategies. Elliot DS, editor. Book 10: Blueprints for Violence Prevention. Boulder. Institute for Behavioral Science, University of Colorado. 2002.
134 Kusche CA, Greenberg MT. The PATHS Curriculum: Promoting Alternative Thinking Strategies. Seattle, WA. Developmental Research and Programs Inc. 1994.
135 Committee for Children. Second Step: A Violence Prevention Curriculum. Seattle, WA. Committee for Children. 2001.
136 Kim HK, Leve LD. Substance use and delinquency among middle school girls in foster care: a three-year follow-up of a randomized controlled trial. J Consult Clin Psychol. Dec. 2011;79(6):740-50. [pmid: 22004305].
137 Smith DK, Leve LD, Chamberlain P. Preventing internalizing and externalizing problems in girls in foster care as they enter middle school: Impact of an intervention. Prevention Science. Sep. 2011;12(3):269-77. [pmid: 21475990].
138 Bruce J, McDermott JM, Fisher PA, et al. Using behavioral and electrophysiological measures to assess the effects of a preventive intervention: a preliminary study with preschool-aged foster children. Prev Sci. Jun. 2009;10(2):129-40. [pmid: 19030992].
139 Fisher PA, Kim HK. Intervention effects on foster preschoolers’ attachment-related behaviors from a randomized trial. Prev Sci. Jun. 2007;8(2):161-70. [pmid: 17340186].
140 Fisher PA, Kim HK, Pears KC. Effects of multidimensional treatment foster care for preschoolers (MTFC-P) on reducing permanent placement failures among children with placement instability. Child Youth Serv Rev. May. 2009;31(5):541-6. [pmid: 19430545].
141 Fisher PA, Stoolmiller M. Intervention effects on foster parent stress: associations with child cortisol levels. Dev Psychopathol. Summer. 2008;20(3):1003-21. [pmid: 18606041].
142 Fisher PA, Stoolmiller M, Gunnar MR, et al. Effects of a therapeutic intervention for foster preschoolers on diurnal cortisol activity. Psychoneuroendocrinology. Sep–Nov. 2007;32(8–10):892-905. [pmid: 17656028].
143 Fisher PA, Burraston B, Pears K. The early intervention foster care program: permanent placement outcomes from a randomized trial. Child Maltreat. Feb. 2005;10(1):61-71. [pmid: 15611327].
144 Fisher PA, Stoolmiller M, Mannering AM, et al. Foster placement disruptions associated with problem behavior: Mitigating a threshold effect. J Consult Clin Psychol. Aug. 2011;79(4):481-7. [pmid: 21787051].
145 Harvey ST, Taylor JE. A meta-analysis of the effects of psychotherapy with sexually abused children and adolescents. Clin Psychol Rev. Jul. 2010;30(5):517-35. [pmid: 20417003].
146 Lundahl BW, Nimer J, Parsons B. Preventing child abuse: A meta-analysis of parent training programs. Res Social Work Prac. May. 2006;16(3):251-62. WOS:000237111700001.
147 Turner W, Macdonald G, Dennis Jane A. Behavioural and cognitive behavioural training interventions for assisting foster carers in the management of difficult behaviour. Cochrane Database Syst Rev. Chichester, UK. John Wiley & Sons, Ltd. 2007.
148 Gardener F, Bjornstad GJ, Ramchandani P, et al. Family therapy for children who have been physically abused. 2009. Protocol Stage.
149 Everson-Hock ES, Jones R, Guillaume L, et al. The effectiveness of training and support for carers and other professionals on the physical and emotional health and well-being of looked-after children and young people: a systematic review. Child Care Health Dev. March. 2012;38(2):162-74. [pmid: 21615770].
150 Paulsell D, Avellar S, Sama Martin E, et al. Home visiting evidence of effectiveness review. Washington, DC. Office of Planning, Research and Evaluation, Administration for Children and Families, US, Department of Health and Human Services. 2010.
151 Mikton C, Butchart A. Child maltreatment prevention: a systematic review of reviews. Bull World Health Organ. May. 2009;87(5):353-61. [pmid: 19551253].
152 MacMillan HL, Wathen CN, Barlow J, et al. Child Maltreatment 3 Interventions to prevent child maltreatment and associated impairment. Lancet. Jan. 2009;373(9659):250-66. WOS:000262537500028. [pmid: 19056113].
153 PreVAIL: Preventing Violence Across the Lifespan Research Network. Research Brief: Interventions to prevent child maltreatment. prevail.fims.uwo.ca/docs/CM%20Research%20Brief%20Mar10.pdf.
154 Chadwick Center on Children and Families. Closing the quality chasm in child abuse treatment: Identifying and disseminating best practices. San Diego, CA. Author. 2004. www.chadwickcenter.org/Documents/Kaufman%20Report/ChildHosp-NCTAbrochure.pdf. Accessed March 22, 2012.
155 Saunders BE, Berliner L, Hanson RF, editors. Child physical and sexual abuse: guidelines for treatment. (Revised Report: April 26, 2004). Charleston, SC. National Crime Victims Research and Treatment Center. 2004.
156 West SL, Gartlehner G, Mansfield AJ, et al. Comparative Effectiveness Review Methods: Clinical heterogeneity. (Prepared by RTI International–University of North Carolina Evidence-based Practice Center, Research Triangle Park, North Carolina under Contract No. 290-2007-10056-I). Methods Research Paper. AHRQ Publication No. 10-EHC070-EF. Rockville, MD. Agency for Healthcare Research and Quality. September. 2010. www.ncbi.nlm.nih.gov/books/NBK53310.
157 West SL, Gartlehner G, Mansfield AJ, et al. Comparative Effectiveness Review Methods: Clinical Heterogeneity. Rockville (MD). 2010.
158 Chaffin M, Hanson R, Saunders BE, et al. Report of the APSAC task force on attachment therapy, reactive attachment disorder, and attachment problems. Child Maltreat. 2006;13(3):245-58.
159 White paper on coercion in treatment: association for treatment and training in the attachment of children. 2007. www.attach.org/WhitePaper.pdf. Accessed November 15, 2010.
160 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews Agency for Healthcare Research and Quality. AHRQ Publication No. 10(11)-EHC063-EF. Rockville, MD. February. 2011. Chapters available at: www.effectivehealthcare.ahrq.gov.
161 Whitlock EP, Lopez SA, Chang S, et al. AHRQ series paper 3: identifying, selecting, and refining topics for comparative effectiveness systematic reviews: AHRQ and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):491-501. [pmid: 19540721].
162 Counsell C. Formulating questions and locating primary studies for inclusion in systematic reviews. Ann Intern Med. Sep. 1. 1997;127(5):380-7. [pmid: 9273830].
163 Helfand M, Balshem H. AHRQ series paper 2: principles for developing guidance: AHRQ and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):484-90. [pmid: 19716268].
164 Regents of the University of Colorado. Center for the study and prevention of violence. www.colorado.edu/cspv/infohouse/index.html. Accessed November 12, 2010.
165 Hagan JF, Shaw JS, Duncan PM, editors. Bright futures: guidelines for health supervision of infants, children, and adolescents. Third ed. Elk Grove Village, IL. American Academy of Pediatrics. 2008.
166 Hussey JM, Marshall JM, English DJ, et al. Defining maltreatment according to substantiation: Distinction without a difference?. Child Abuse Negl. 2005;29(5):479-92. [pmid: 15970321].
167 Leiter J, Myers KA, Zingraff MT. Substantiated and unsubstantiated cases of child maltreatment: Do their consequences differ?. Soc Work Res. 1994;18(2):67-82.
168 Chou R, Aronson N, Atkins D, et al. AHRQ series paper 4: assessing harms when comparing medical interventions: AHRQ and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):502-12. [pmid: 18823754].
169 Hartling L, Bond K, Harvey K, et al. Developing and Testing a Tool for the Classification of Study Designs in Systematic Reviews of Interventions and Exposures Methods Research Report. AHRQ Publication No. 11-EHC-007. Rockville, MD. Agency for Healthcare Research and Quality. December. 2010.
170 Gartlehner G, Hansen RA, Nissman D, et al. A simple and valid tool distinguished efficacy from effectiveness studies. J Clin Epidemiol. Oct. 2006;59(10):1040-8. [pmid: 16980143].
171 Viswanathan M, Ansari MT, Berkman ND, et al. Assessing the Risk of Bias of Individual Studies in Systematic Reviews of Health Care Interventions Agency for Healthcare Research and Quality Methods Guide for Comparative Effectiveness Reviews. AHRQ Publication No. 12-EHC047-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2012. www.effectivehealthcare.ahrq.gov.
172 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions—Agency for Healthcare Research and Quality and the Effective Health-Care Program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
173 Treadwell JR, Uhl S, Tipton K, et al. Assessing equivalence and noninferiority. J Clin Epidemiol. 2012.
174 Ramey CT, McGinness GD, Cross L, et al. The Abecedarian approach to social competence: Cognitive and linguistic intervention for disadvantaged preschoolers. Borman K, editor. The social life of children in a changing society. Hillsdale, NJ. Erlbaum. 1982:14-174.
175 Ramey CT, Yeates KO, Short EJ. The plasticity of intellectual development: insights from preventive intervention. Child Dev. Oct. 1984;55(5):1913-25. [pmid: 6510061].
176 Cohen J. Statistical Power Analysis for the Behavioral Sciences. Hillsdale, NJ. L. Erlbaum Associates. 1988.
177 Letarte MJ, Normandeau S, Allard J. Effectiveness of a parent training program “Incredible Years” in a child protection service. Child Abuse Negl. 2010:253-61. [pmid: 20356626].
178 Appleyard K, Berlin LJ, Rosanbalm KD, et al. Preventing early child maltreatment: implications from a longitudinal study of maternal abuse history, substance use problems, and offspring victimization. Prev Sci. Jun. 2011;12(2):139-49. [pmid: 21240556].
179 Fisher PA, Van Ryzin MJ, Gunnar MR. Mitigating HPA axis dysregulation associated with placement changes in foster care. Psychoneuroendocrinology. May. 2011;36(4):531-9. [pmid: 20888698].
180 American Psychiatric Association. American Psychiatric Association Diagnostic and Statistical Manual. Washington, DC. American Psychiatric Association. 1994.
181 Ainsworth M, Blehar M, Waters E, et al. Patterns of Attachment: A Psychological Study of the Strange Situation. Hillsdale, NJ. Erlbaum. 1978.
182 Turner W, Macdonald GM, Dennis JA. Cognitive-behavioural training interventions for assisting foster carers in the management of difficult behaviour. Cochrane Database Syst Rev. 2007;(1):CD003760. [pmid: 17253496].
183 Luborsky L, Singer B, Luborsky L. Comparative Studies of Psychotherapies - Is It True That Everyone Has Won and All Must Have Prizes. Arch Gen Psychiatry. 1975;32(8):995-1008. ISI:A1975AM81400004. [pmid: 239666].
184 Bergin AE, Garfield SL. Handbook of Psychotherapy and Behavior Change. 4th ed. New York. Wiley. 1994.
185 Budd R, Hughes I. The Dodo Bird Verdict—controversial, inevitable and important: a commentary on 30 years of meta-analyses. Clin Psychol Psychother. Nov–Dec. 2009;16(6):510-22. [pmid: 19728292].
186 Barlow J, Johnston I, Kendrick D, et al. Individual and group-based parenting programmes for the treatment of physical child abuse and neglect. Cochrane Database Syst Rev. 2006;3:CD005463. [pmid: 16856097].
187 Craven PA, Lee RE. Therapeutic interventions for foster children: A systematic research synthesis. Res Social Work Prac. May. 2006;16(3):287-304. ISI:000237111700004.
188 Sameroff A, Fiese B. Transactional regulation and early intervention. Meisels JS, Shonkoff JP, editors. Handbook of Early Childhood Intervention. New York. Cambridge University Press. 2000:119-49.
189 Casanueva C, Cross TP, Ringeisen H, et al. Prevalence, trajectories, and risk factors for depression among caregivers of young children involved in child maltreatment investigations. J Emot Behav Disord. Jun. 2011;19(2):98-116. ISI:000290353300003.
190 Conron KJ, Beardslee W, Koenen KC, et al. A longitudinal study of maternal ddepression and child maltreatment in a national sample of families investigated by child protective services. Arch Pediatr Adolesc Med. Oct. 2009;163(10):922-30. ISI:000270496300007. [pmid: 19805711].
191 Administration for Children and Families. Adoption and Safe Families Act of 1997 Titles IV-B and IV-E, Section 403(b), Section 453, and Section 1130(a) of the Social Security Act. Washington, DC. US Department of Health and Human Services. 1997.
192 Berlin L, Ziv Y, Amaya-Jackson L, et al. Enhancing Early Attachments: Theory, Research, Intervention, and Policy. New York. The Guilford Press. 2005.
193 Chamberlain P, Moore K. A clinical model for parenting juvenile offenders: A comparison of group care versus family care. Clinical Child Psychology and Psychiatry. 1998;3(3):375-86. 1999-11265-003. First Author & Affiliation: Chamberlain, Patricia.
194 Chamberlain P, Mihalic SF. Multidimensional treatment foster care: Blueprints for Violence Prevention, Book Eight Blueprints for Violence Prevention Series. Boulder, CO. Center for the Study and Prevention of Violence, Institute of Behavioral Science, University of Colorado. 1998.
195 Swenson CC, Schaeffer CM, Tuerk EH, et al. Adapting Multisystemic Therapy for co-occurring child maltreatment and parental substance abuse: The building stronger families project. Emotional and Behavioral Disorders in Youth. 2009;W:3-8.
196 Swenson CC, Penman JE, Henggeler SW, et al. Multisystemic Therapy for Child Abuse and Neglect, revised edition. Charleston, SC. Family Services Research Center, National Institute of Mental Health and Connecticut Department of Children and Families. 2011.
197 Rivard JC, Bloom SL, McCorkle D, et al. Preliminary results of a study examining the implementation and effects of a trauma recovery framework for youths in residential treatment. Ther Communities. 2005;26(1):83-96.
198 Rivard J, Bloom S, Abramovitz R, et al. Assessing the imlementation and effects of a trauma-focused intervention for youths in residential treatment. Psychiatric Q. 2003;74(2):137-54.
199 Flay BR, Biglan A, Boruch RF, et al. Standards of evidence: criteria for efficacy, effectiveness and dissemination. Prev Sci. Sep. 2005;6(3):151-75. [pmid: 16365954].
200 Viswanathan M, Ansari M, Berkman N, et al. Assessing the Risk of Bias of Individual Studies in Systematic Reviews of Health Care Interventions. Agency for Healthcare Research and Quality Methods Guide for Comparative Effectiveness Reviews. AHRQ Publication No. 12-EHC047-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2012. www.effectivehealthcare.ahrq.gov.
201 Cohen JA, Mannarino AP. A treatment study for sexually abused preschool children: outcome during a one-year follow-up. J Am Acad Child Adolesc Psychiatry. Sep. 1997;36(9):1228-35. [pmid: 9291724].
202 Cohen JA, Mannarino AP. Factors that mediate treatment outcome of sexually abused preschool children: six- and 12-month follow-up. J Am Acad Child Adolesc Psychiatry. Jan. 1998;37(1):44-51. [pmid: 9444899].
203 Cohen JA, Mannarino AP. Interventions for sexually abused children: Initial treatment outcome findings. Child Maltreat. 1998;3(1):17-26. 1997-39106-002.
204 Cohen JA, Mannarino AP, Knudsen K. Treating sexually abused children: 1 year follow-up of a randomized controlled trial. Child Abuse Negl. Feb. 2005;29(2):135-45. [pmid: 15734179].
205 Deblinger E, Mannarino AP, Cohen JA, et al. A follow-up study of a multisite, randomized, controlled trial for children with sexual abuse-related PTSD symptoms. J Am Acad Child Adolesc Psychiatry. Dec. 2006;45(12):1474-84. [pmid: 17135993].
206 Deblinger E, Steer RA, Lippmann J. Two-year follow-up study of cognitive behavioral therapy for sexually abused children suffering post-traumatic stress symptoms. Child Abuse Negl. Dec. 1999;23(12):1371-8. [pmid: 10626618].
207 Deblinger E, Mannarino AP, Cohen JA, et al. Trauma-focused cognitive behavioral therapy for children: impact of the trauma narrative and treatment length. Depress Anxiety. Jan. 2011;28(1):67-75. [pmid: 20830695].
208 Schulz KF, Altman DG, Moher D. CONSORT 2010 Statement: Updated guidelines for reporting parallel group randomised trials. J Clin Epidemiol. Aug. 2010;63(8):834-40. [pmid: 20346629].
209 Ioannidis JPA. Why most published research findings are false. PLoS medicine. Aug. 2005;2(8):696-701. ISI:000231676900008.
210 Blum NJ, Comm DS. The Developmental-Behavioral Pediatrics Research Network: Another Step in the Development of the Field. J Dev Behav Pediatr. Jan. 2012;33(1):78-83. ISI:000299391700019. [pmid: 22218018].
211 Swanson J, Arnold LE, Kraemer H, et al. Evidence, interpretation, and qualification from multiple reports of long-term outcomes in the Multimodal Treatment study of Children With ADHD (MTA): part I: executive summary. J Atten Disord. Jul. 2008;12(1):4-14. [pmid: 18573923].
212 Ebert L, Amaya-Jackson L, Markiewicz J, et al. Development and application of the NCCTS learning collaborative model for the implementation of evidence-based child trauma treatment. McHugh R, Barlow DH, editors. Dissemination and implementation of evidence-based psychological interventions. New York. Oxford University Press. 2012:97-123.