# Methods

This review is funded by the Agency for Healthcare Research and Quality (AHRQ) Effective Health Care (EHC) Program. In 2005, AHRQ created the EHC Program to improve the quality, effectiveness, and efficiency of health care delivery.21 The target audience “includes not only policymakers in government and private health plans but also clinicians, patients, and members of industry.”21

This comparative effectiveness review (CER) assesses the effectiveness, including benefits and harms, of clinical interventions for children exposed to child maltreatment. A team of researchers conducted this review using the methods described in AHRQ’s Methods Guide for Effectiveness and Comparative Effectiveness Reviews.160 The team included three clinical psychologists, a family medicine physician, and developmental psychologist all specializing in child maltreatment, as well as several researchers with expertise in AHRQ CER methodology.

## Topic Nomination, Development, Refinement, and CER Protocol

Through a public nomination process, a clinician in private practice expressed an interest in attunement parenting for foster and adopted children ages 5 to 12 years. The nominator cited current research indicating that childhood trauma led to a chronic state of stress, in turn increasing the potential for problem behaviors. During topic development and refinement, the RTI International–University of North Carolina Evidence-based Practice Center (EPC) followed the guiding principles for identifying and selecting topics established by the EHC program (these principles are described in detail elsewhere).161 The EPC designed the systematic review using a PICOTS (population, interventions, comparators, outcomes, timing, and settings)162 framework and defined a set of key questions (KQs) a priori with input from a range of stakeholders (i.e., key informants).

As originally nominated, the topic was particularly narrow in regard to the interventions (attunement parenting) and setting (foster and adoptive care). Following EHC guidance to explore nominated topics with an understanding of the “clinical logic underlying the rationale for a service,”163 and the nominator’s interest in trauma associated with child abuse and neglect as a potent risk factor for mental and behavioral health problems, the EPC expanded the population to include children exposed to maltreatment and, more broadly, all children involved in the child welfare system regardless of setting (i.e., foster care, adoptive care, or in the care of biological parents).

Following refinement of the topic, AHRQ posted the proposed systematic review framework, including the PICOTS, KQs, and analytic framework, on the EHC Web site from 3/18/2011 to 4/15/2011. After the CER framework posting, the EPC reviewed public comments and consulted with a Technical Expert Panel to finalize the research protocol. Names of the members of Technical Expert Panel are listed at the front of this report. AHRQ posted the research protocol on the EHC Web site on 11/15/2011. Decisions based on clinical heterogeneity156 of the population, diversity of interventions, and the resulting scope of the review led to modifications of the protocol (posted 1/10/2012).

## Literature Search Strategy

### Search Strategy

We systematically searched, reviewed, and analyzed the scientific evidence for each KQ. We conducted focused searches of MEDINE (via PubMed), Social Science Citation Index (SSCI), PsycInfo, and the Cochrane Library. An experienced research librarian used a predefined list of search terms and medical subject headings (MeSH). The librarian completed the first search on 9/29/2011 and an update search on 5/4/2012. We limited searches to publications from 1990 and later to ensure clinical relevancy. We limited the search to studies published in English, based on limited resources. The complete search strategies, including specific limitations used for each database, are presented in Appendix A.

To build on the work of the existing evidence-based registries and databases on interventions for children, we searched the following registries for relevant articles that the systematic literature search may have missed:

- National Child Traumatic Stress Network’s Empirically Supported Treatments and Promising Practices102
- California Evidence-based Clearinghouse for Child Welfare106
- National Registry of Evidence-based Programs and Practices103
- Office of Juvenile Justice and Delinquency Prevention Model Programs Guide105
- Center for the Study and Prevention of Violence Program Database.164

We searched unpublished and grey literature relevant to the review. Methods for identifying grey literature included a review of trial registries, specifically ClinicalTrials.gov, Health Services Research Projects in Progress (www.nlm.nih.gov/hsrproj), and the European Union Clinical Trials Register (www.clinicaltrialsregister.eu). Further, AHRQ requested scientific information packets from the developers and distributors of the interventions identified in the literature review. Scientific information packets provide an opportunity for the intervention developers and distributors to share with the EPC both published and unpublished data that they believe should be considered for the review. We included unpublished studies that met all inclusion criteria and contained enough information on the research methods used for the risk of bias assessment.

Lastly, we searched reference lists of review articles that are pertinent but did not meet inclusion criteria for studies that we should consider for inclusion in this review.

### Inclusion and Exclusion Criteria

Table 4 outlines the population, interventions, comparators, outcomes, timing, and settings (PICOTS) that define the major inclusion criteria for studies in this review. In the sections following the table, we discuss each domain.

Table 4 Population, Intervention, Comparator, Timing, Setting (PICOTS)

Domain | Description
Population | - Children aged 0 to 14 years exposed to child maltreatment. For this review, we used the definition of maltreatment provided by the Centers for Disease Control and Prevention:27; ○ Child abuse: words or overt actions that cause harm, potential harm, or threat of harm to a child; ○ Child neglect: failure to provide for a child’s basic physical, emotional, or educational needs or to protect a child from harm or potential harm; privation (conditions of severe social deprivation).; - Children aged 0 to 14 whose families were involved with child protective services, including children who remained in the care of their biological parent and those placed in out-of-home care (e.g., foster care, kinship care, group home care). We excluded studies that targeted children known to have been placed in out-of-home care because the child’s behavior or condition posed a threat to their community or was beyond the control of his or her family (e.g., youth referred or mandated by the juvenile justice system to out-of-home placement because of multiple criminal offenses; children placed in out-of-home care due to serious emotional disturbance and no involvement with the child protective services).; - The population included the child’s primary caregiver(s) when the intervention targeted the caregiving context. The primary caregiver was defined as the biological parent; foster, kinship (relative), or adoptive caregiver; or caregivers in a residential program or group home.; - Child subgroups were defined by age, type of maltreatment exposure, severity of maltreatment exposure, presence of child behavioral and mental health problems, and sociodemographic groups (race, ethnicity, and sex).; - Caregiver subgroups were defined as caregiving context (i.e., primary caregiver/environment), presence of caregiver substance abuse or other mental health disorder, caregiver sociodemographic characteristics (age, race, ethnicity, and sex).
Interventions | Clinical interventions designed to prevent, ameliorate, or improve mental health symptoms, behavior problems, or psychopathology; optimize child development and functioning; and/or improve child welfare outcomes, including the following:; - Psychotherapy/psychosocial interventions delivered at the individual, caregiver, and/or family level (including Trauma-Focused Cognitive Behavioral Therapy, Parent-Child Interaction Therapy, Attachment and Biobehavioral Catch-up, the Incredible Years).; - General and specific types of pharmacotherapy (e.g., selective serotonin reuptake inhibitors [SSRIs]).; Strategies or approaches designed to improve the system of care for maltreated children and caregivers at the service-delivery or organizational level were excluded. Examples include intensive family preservation or reunification service models, solution-focused/based casework, differential response, and routine preservice foster parent training programs.
Comparator | - The comparison condition as defined in the respective studies. Active controls were comparison groups that received another structured intervention. Inactive controls were comparison groups that did not receive another structured intervention.
Outcomes | Child well-being outcomes; - Child mental and behavioral health (e.g., prevention of or reduction in severity or number of traumatic stress symptoms or syndromes; post-traumatic stress disorder (PTSD); attachment disorders; depressive symptoms; anxiety symptoms; disruptive, aggressive, and delinquent behavior); - Healthy caregiver-child relationship (e.g., secure attachment; increased caregiver responsiveness and sensitivity to the child; positive caregiver-child interaction; increased positive attitudes toward childrearing, perceptions of the child and causal attributions about the child’s behavior, family functioning); - Healthy development (e.g., cognitive, language, physical); - School-based functioning (e.g., grade retention, disciplinary referrals, attendance); Child welfare outcomes; - Safety (e.g., prevention of maltreatment recurrence or reduced number of subsequent involvements with child protective services); - Placement stability for children in out-of-home care; - Positive permanency outcomes for children in out-of-home care; Treatment engagement and adherence; - Readiness or motivation to engage in an intervention; - Treatment completion; Adverse events; - Retraumatization; - Caregiver distress
Timing | - Short-term duration: postintervention (i.e., at treatment completion) to <6 months; - Long-term duration: ≥6 months after treatment completion
Setting | - Studies conducted in the United States or internationally; - Interventions provided in both specialty service delivery settings (e.g., outpatient and inpatient mental health care settings) and nonspecialty service delivery settings (e.g., schools, community-based providers, shelters, prison or diversion programs); - Home-based and out-of-home care (e.g., foster or kin care, residential treatment, group settings)

### Population

The population of interest for this review was children ages 0 to 14 years exposed to maltreatment (using the definitions below), children of the same ages involved with the child welfare system (including foster care), and caregivers of maltreated children when they were the target of an intervention. We used the following definitions for child maltreatment and sexual abuse:

- Child maltreatment—the definition provided by the Centers for Disease Control and Prevention27 includes both child abuse (acts of commission: words or overt actions that cause harm, potential harm, or threat of harm to a child) and child neglect (acts of omission: failure to provide for a child’s basic physical, emotional, or educational needs or to protect a child from harm or potential harm). The harm to a child may or may not be the intended consequence.27
- Sexual abuse—the definition provided by the Child Abuse Prevention and Treatment Act28 is the employment, use, persuasion, inducement, enticement, or coercion of any child to engage in, or assist any other person to engage in, any sexually explicit conduct or simulation of such conduct for the purpose of producing a visual depiction of such conduct; or the rape, and in cases of caretaker or interfamilial relationships, statutory rape, molestation, prostitution, or other form of sexual exploitation of children, or incest with children.28

We excluded adolescents older than 14 years of age in the interest of reducing the clinical heterogeneity of the population for this review. This decision reflects attention to the developmental needs and capacities of older adolescents, which represents a markedly distinct developmental period in physical, cognitive, emotional, and social capacities and challenges—including significant independence, the ascendancy of adolescent peers as a key reference group, and increasingly complex interpersonal relationships. The American Academy of Pediatrics’ Bright Futures Guidelines for Health Supervision of Infants, Children, and Adolescents differentiates “early adolescence” (11 to 14 years) from “middle adolescence” (15 to 17 years).165

Some studies included both children who met the inclusion criteria and those who did not; we call this a “mixed” study population. Examples of mixed populations include study samples with too broad an age range (e.g., 0 to 18) and samples that included children with known maltreatment exposure combined with children for whom maltreatment exposure was unknown and who were receiving intervention because of another type of traumatic exposure or the child’s challenging behavior. We recognize that children identified as maltreated and at risk for maltreatment can present similar clinical and risk profiles.67,166,167 However, concerns about clinical heterogeneity of the study population and an interest in producing a report with results generalizable to a clearly defined population led us to exclude studies with a mixed population unless results were stratified in such a way that we could extrapolate findings for the population meeting inclusion criteria of this review. Of note, studies that did not report the age range of children were assumed to include children through age 17 and were therefore excluded.

### Interventions

For KQs 1 to 4, and KQ 6, interventions of interest included those with the following aims: prevent, ameliorate, or improve mental health symptoms, behavior problems, or psychopathology; optimize child development and functioning; and/or improve child welfare outcomes. We did not include preventive interventions targeting pregnant women, first-time parents, or other parents with risk factors for child abuse or neglect. Clinical interventions included in this CER include both psychosocial and pharmacotherapy approaches delivered at the individual, child-caregiver (dyadic), and/or family level to address the mental and behavioral health needs of the child and/or the quality of the child-caregiver relationship in support of the child’s emotional well-being. Relevant psychosocial interventions include specifically defined treatment components and may also include supportive services such as crisis management and concrete assistance. Due to issues of scope and heterogeneity, strategies or approaches to improve the system of care for maltreated children and caregivers at the service-delivery or organizational level—which were originally considered for inclusion in this review—are excluded. Examples include:

- Child welfare systems case planning and/or management approaches such as differential response (i.e., an alternative assessment model offered by child protective services agencies to families reported for child abuse and neglect depending on the severity of the allegation), solution-focused casework, and investigative decision strategies.
- General categories of services provided to families by the child welfare system such as preservice foster parent training, financial support, respite care, and peer support groups.
- Policy-level interventions in the child welfare system such as subsidized guardianship.
- Cross-systems/systems integration strategies such as interagency collaboration and enhanced case management procedures.
- Court improvement strategies such as accelerated case review, court teams, dependency or drug court court-appointed child advocates, and programs to increase family engagement in the dependency or drug court treatment plan.

For studies involving populations with mental health symptoms, general and specific types of pharmacotherapy are relevant treatment approaches (e.g., selective serotonin-reuptake inhibitors). For KQ 5, we included interventions with the goal of increasing participant engagement to increase retention and patient adherence.

Only interventions that have been studied comparatively with maltreated children and/or their caregivers are included in this review. Intensive family preservation or reunification service models, such as Homebuilders^®^, were eligible for inclusion; however, studies examining these approaches focused on families who received services regardless of child age and thus did not meet the age cut-off set. Several well-researched preventive interventions that are widely used in the field (e.g., Nurse Family Partnership, Early Head Start, and Pathways Triple P) and which may be relevant for preventing recurrence, were not included in this review because the intervention explicitly focuses on prevention with families at risk for poor child outcomes.

### Comparators

All studies included in this CER had at least two arms. We excluded studies that analyzed differences between three or more groups but did not report the results of pairwise comparisons.

Acceptable comparisons included control groups such as usual care or a wait-list strategy. In addition to wait-list control or usual care, comparators included (a) approaches representative of conventional practice in the field (such as child-centered therapy, support groups, and family therapy), and (b) derivations of interventions (wherein the degree to which core components of the original model are implemented is unclear and/or core components are omitted or substantively modified). By derivation, we refer to approaches wherein the authors do not specify the degree to which the original model was implemented and/or modify the core components.

Lastly, we excluded studies comparing the same intervention in different contexts, such as with kin caregivers compared with non-kin caregiver because the study did not directly answer any of the KQs.

### Outcomes

All child well-being outcomes that studies reported were assessed using measures for which psychometric data on reliability and validity (beyond face validity) are available in the extant literature. We did not include measures for which basic reliability properties were reported by the author but no further validity data could be readily found in the extant literature. For psychometric information regarding trauma-specific measures, we consulted the National Child Traumatic Stress Network’s Measures Review Database. We present the list of included measures in Table 5. As noted in the Introduction, we treat parent-level variables as indicators of the healthy caregiver-child relationship outcome in KQ 1. In our results, we differentiate parent self-report outcomes such as attitudes towards corporal punishment, perceptions of child behavior, and parenting practices from direct and objective measures of the quality of the caregiver-child relationship (observations of parent-child interaction and child attachment behavior).

Table 5 Included measures

Outcome | Measures
Mental and Behavioral Health | Achenbach System of Empirically Based Assessment Cambridge Neuropsychological Test and Automated Battery Child Behavior Checklist Child Report of Post-traumatic Symptoms Child Sexual Behavior Inventory Children’s Depression Inventory Children’s Impact of Traumatic Events Scale Coping Inventory Cortisol (salivary) values Eyberg Child Behavior Inventory Kiddie Global Assessment Scale Laboratory Temperment Assessment Battery Life Satisfaction Survey Orvaschel PTSD Scale Parent Daily Report Parent Report of Post-traumatic Symptoms Post Traumatic Stress Symptoms Scale Preschool Age Psychiatric Assessment Revised Behavioral Problem Checklist Rutter Teacher Scale Schedule for Affective Disorders and Schizophrenia for School-Aged Children— Present and Lifetime Version Self-Perception Profile for Children Self-Report Delinquency Scale State-Trait Anxiety Inventory for Children Sutter-Eyberg Student Behavior Inventory—Revised Trauma Symptom Checklist for Children
Healthy Caregiver-Child Relationships | [underlined: Direct:] Strange Situation procedure HOME: Home Observation Measure of the Environment Child Autonomy Observational Scale Observational Record of the Caregiving Environment Parenting Skills Observation Scale [underlined: Indirect:] Adult Adolescent Parenting Inventory Alabama Parenting Questionnaire—Child Alabama Parenting Questionnaire—Parent Beck Depression Inventory Child Abuse Potential Inventory Conflict Tactics Scale—Revised Family Adaptability and Cohesion Evaluation Scale Family Assessment Form Family Functioning Style Scale Impact of Events Scale—Caregiver version MacArthur Story Stem Battery and Narrative Coding Manual—Rochester Revision Maternal Behavior Q-Set McMaster Family Functioning—General Functioning Scale Parent Attachment Diary Parent Daily Report Parent Practices Questionnaire Parenting Locus of Control Scale Parenting Practices Interview Parenting Practices Questionnaire Parenting Self-Agency Measure Parenting Stress Index Perceptions of Adult Attachment Scale Social Support Behaviors Scale Symptom Checklist—Revised (Caregiver)
Healthy Development | Bayley Scales of Infant Development Dimensional Change Card Sort Flanker Task Go/No Go Task Peabody Picture Vocabulary Test Penny Hiding Task Receptive-Expressive Emergent Language Scale Reynell Developmental Language Scale Tool task Wechsler Preschool and Primary Scale of Intelligence Weschler Intelligence Scale for Children

For KQ 2, we included child welfare outcomes using administrative data from the child welfare system. For KQ 6, an adverse event is defined as a “harmful or undesirable outcome that occurs during or after the use of a drug or intervention but is not necessarily caused by it.”168 We did not require a validated measure for assessment of adverse events; however, we did require active surveillance of harms.

### Timing

We included studies reporting short- or long-term outcomes as defined by the authors. We included end-of-intervention results as well as any follow-up data. Intermediate measures, that is, assessments made between baseline and completion of the intervention, are not included in the report.

### Setting

We did not exclude studies based on geography or the setting of service provision.

### Study Designs

To identify appropriate study designs, the research team used the algorithm developed by the Alberta EPC.169 Table 6 describes the study design inclusion criteria developed for this report. All studies were considered efficacy studies unless the study authors clearly identified them as effectiveness trials that were intended to reflect “real world” conditions.170

Table 6 Study inclusion criteria

Category | Criteria for Inclusion
Study design | Systematic reviews, randomized controlled trials, nonrandomized controlled trials, cohort studies (e.g. prospective and retrospective), and case-control studies
Sample size | N≥10
Study location | United States and international Clinics, community-based agencies, and home-based

## Study Selection

Two trained members of the research team independently reviewed all titles and abstracts identified through searches for eligibility against predefined inclusion and exclusion criteria. Abstracts marked for possible inclusion by either reviewer underwent a full-text review. Each full-text article was again independently reviewed by two trained members of the team to determine if it met inclusion criteria. If it did not meet inclusion criteria, each reviewer recorded the reason for exclusion; reviewers resolved disagreements by consensus discussion and consulted a third party if they were unable to reach a consensus. The full-text review form reviewers used is reproduced in Appendix B. If both reviewers agreed that a study did not meet the eligibility criteria, it was excluded. If the reviewers disagreed, they resolved conflicts by discussion and consensus or by consulting a third member of the review team. The project coordinator tracked results of the abstract and full-text reviews in an EndNote database. Appendix C contains a complete list of studies excluded during the full-text review, denoted by primary reason for exclusion.

We screened unpublished studies identified through grey literature search and reviewed scientific information packets using the same title/abstract and full-text review processes.

## Data Extraction

A template for evidence tables to be used for data synthesis was developed using the PICOTS framework. For studies that met inclusion criteria, we abstracted relevant information into these evidence tables using Microsoft Excel. We abstracted characteristics of study populations, interventions, comparators, settings, study designs, methods, and results. One trained reviewer abstracted the relevant data from each included article and a second member of the team reviewed each data abstraction against the original article for completeness and accuracy.

## Risk of Bias Assessment

For each included study, we assessed the potential for selection bias, performance bias, attrition bias, detection bias, and reporting bias (Table 7). Two independent reviewers rated the risk of bias for each study. Disagreements between the two reviewers were resolved by discussion and consensus or by consulting a third member of the team.

Table 7 Risk of bias assessment questions

Abbreviated Criteria in Table | Full Question | Type of Bias Assessed
Similar at baseline | Were groups similar at baseline? | Selection bias
Fidelity | Were measures taken to ensure intervention fidelity? | Performance bias
Assessor blinded | Were outcome assessors unaware of which intervention the participants received (i.e., blinded)? | Detection bias
All outcomes included | Are all prespecified outcomes reported in the results? | Reporting bias
Measures equally applied | Were outcome measures equally applied? | Detection bias
Attrition reported | Do study authors report either attrition statistic or that all participants who started the study completed the study? | Attrition bias
Attrition ≥ 30% | Was the overall attrition for the study ≥ 30%? | Attrition bias
Differential attrition ≥ 15% | Was the differential attrition between groups ≥ 15%? | Attrition bias
QUESTIONS FOR RCTs ONLY
Randomization adequate | Was randomization adequate? | Selection bias
Allocation concealment | Was the intervention/treatment allocation concealed? | Selection bias
ITT analysis | Did investigators use an intention-to-treat (ITT) analysis? | Attrition bias
QUESTIONS FOR NONRANDOMIZED TRIALS AND OBSERVATIONAL STUDIES
Prospective | Is the study design prospective? | Detection bias
Same source population | Were groups recruited from the same source population? | Selection bias
I/E criteria | Were inclusion and exclusion criteria equally applied in both groups? | Selection bias
Control for difference | Were differences between groups taken into account in the statistical analysis? | Confounding

Results of this assessment are summarized in a rating of low, medium, or high risk of bias. In general, a study with a low risk of bias has a strong design, measures outcomes appropriately, uses appropriate statistical and analytical methods, reports low attrition, and reports methods and outcomes clearly and precisely. It should be noted that evaluative criteria such as blinded assessment and concealment are less applicable to child welfare outcomes based on administrative data. Studies with a medium risk of bias are those that do not meet all criteria required for low risk of bias but do not have flaws that are likely to cause major bias. Studies with a high risk of bias include those with at least one major weakness that has the potential to cause significant bias and thus we cannot be confident in the validity of results. Examples of flaws leading to a high risk of bias rating include different application of inclusion/exclusion criteria between groups, substantial differences in groups at baseline, high overall attrition, or differential attrition across study conditions. A high risk of bias rating was not assigned to a study merely because critical information was not reported or unclear.171 However, “unclear” methodology was taken into consideration in grading the strength of evidence based on the study (described later in this chapter). Of note, the most recent methods guidance calls for a designation of “unclear risk of bias.” Because a substantial amount of work on this project preceded this recommendation, however, we were unable to apply the unclear risk of bias rating to this evidence base. To maintain a focus on the best available evidence, we opted to exclude from the Results chapter of this CER studies with a high risk of bias. We list each study rated as high risk of bias along with the reason it was rated as such in Appendix D.

## Data Synthesis

We analyzed the data qualitatively. Across studies, the populations, interventions, and outcome measures used were heterogeneous and did not lend themselves to a pooled analysis.

The Results chapter of this review is organized by KQ. For each question we have two sections: key points and detailed synthesis. The key points section summarizes the results for each outcome in the KQ; the detailed synthesis section describes the study results.

In the detailed analysis section we report key features of the study and the results for each construct analyzed. Two tables accompany the study narrative: one table outlining key study characteristics and a second summarizing the study results. The study characteristics table provides the study design, sample size (at baseline), comparison groups, and risk of bias rating. The results table summarizes the within- and between-group differences in the construct measured over time or at the study endpoint. Data on magnitude of effect are also included in the results tables. We report magnitude of effect data provided by authors in the studies reviewed. We did not perform additional effect size calculations, except for one study that provided the effect size without the significance level.

Given the complexity of our analyses, we adopted some conventions for presenting comparative data (Table 8). Statistically significant within-group changes are indicated by a superscript “+”or “−”; a “+” indicates improvement on the construct measured; a “−” indicates a detriment. In addition, we designate nonsignificant results with “ns.” Significant between-group differences are indicated by a “<“ or “>“ between group one (G1) and group two (G2). If a study found no between-group differences, we will say “no differences between G1 and G2.”

Table 8 Intervention A versus usual care, results (sample table)

First Author, Year | Comparison Groups | Mental Health Outcomes
Jones et al., 2002 | G1: Intervention A G2: Usual care | Changes in Overall Mental Health and Behavior(Child Behavior Checklist) No difference between G1^+^ and G2^ns^ p=0.66 Changes in Depression(Children’s Depression Inventory) G1^+^>G2^−^ p=0.04
Jones et al., 2003 | G1: Intervention A G2: Usual care | Changes in Traumatic Stress Symptoms(Trauma Symptoms Checklist for Children) G1>G2 p=NR (sig)

Abbreviations: G = group; NR = not reported; ns =within-group change over time p>0.05; sig = significant; + = within-group improvement over time p≥0.05; − = within-group detriment over time p≥0.05

Table 8 shows that, in Jones et al., 2002, the overall mental health and behavior of participants in G1 improved significantly over time while members of G2 did not change significantly on these outcomes. The between-group differences in change over time were not significant (p= 0.66) for this measure. On a measure of depression, G1 showed significant improvements while G2 showed a significant detriment. The between-group differences in change over time (G1>G2) were significant for this measure (p=0.04), favoring participants in G1. In Jones et al., 2003, children in G1 exhibited a significantly greater improvement in traumatic stress symptoms than children in G2 (p=NR, within-group change not reported).

## Strength of the Body of Evidence

We graded the SOE based on EPC guidance established for the AHRQ EHC Program, as detailed in a recent paper by Owens and colleagues.172 The EPC approach incorporates four key domains: risk of bias, consistency, directness, and precision of the evidence.

- Risk of bias is determined according to the “degree to which the included studies for a given outcome or comparison have a high likelihood of adequate protection against bias.” It is graded as high, medium, or low.
- Consistency is the “degree to which reported effect sizes from included studies appear to have the same direction of effect.” It is graded as consistent or nonconsistent. Consistency cannot be assessed when a body of evidence has only a single study (unknown or not applicable). When a body of evidence includes both consistent and inconsistent findings, the presence of one or more consistent findings will result in a “consistent” grade for the outcome of interest.
- Directness is determined based on “whether the evidence links the interventions directly to health outcomes.” It is graded direct or indirect. In this report, healthy caregiver-child relationship outcomes were predominantly indirect; many measures assessed outcomes indirectly related to the caregiver-child relationship (e.g., parent attitudes toward discipline; parent-related stress) rather than direct observations of parent-child interaction or child attachment behavior. When a body of evidence includes both indirect and direct measures, the presence of one or more direct measures will result in a “direct” grade.
- Lastly, precision is determined according to “the degree of certainty surrounding an effect estimate.” “Precise” indicates a clinically useful conclusion that is statistically significant, and “imprecise” indicates that no conclusion can be drawn as to whether either treatment is superior or whether the treatments are equivalent.

The overall grades for SOE, based on the scores for the above domains, are described in Table 9. Grades reflect the strength of the body of evidence to answer the KQs on the comparative effectiveness, efficacy, and harms of the interventions in this review. In general, bodies of evidence earning a grade of “high” include several studies with a low to medium risk of bias with consistent results directly answering the KQ with precision. A “moderate” SOE grade may result from fewer studies meeting the same criteria (i.e., low/medium risk of bias, direct evidence, consistent and precise results) and also evidence from large effectiveness trials, which leads to increased confidence in the SOE. When evidence supporting an intervention is sparse (2 or fewer studies) the body of evidence is graded as “low.”

Table 9 Definitions of the grades of overall strength of evidence

Grade | Definition
High | High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
Moderate | Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate.
Low | Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate.
Insufficient | Evidence either is unavailable or does not permit estimation of an effect.

Source: Owens et al., 2010^172^

Lastly, some bodies of evidence do not permit a conclusion because of inconsistent or imprecise results; these bodies of evidence are graded as “insufficient.” For example, in the case of nonsignificant findings, the precision of noninferiority (i.e., that the experimental treatment is not clinically worse than the active control) or equivalence (i.e., that the experimental treatment is clinically similar to the active control) can only be assessed if the study planned and analyzed the data using a prespecified noninferiority or equivalence margin of clinically significant difference with a sufficiently powered sample size to detect that difference.173 If a study is not identified as an equivalence or noninferiority trial by the authors, or it is identified as a noninferiority or equivalence trial but the quality or reporting does not permit clear interpretation of the precision of the findings (e.g., sample size calculations are not reported), the body of evidence for the outcome would be graded as insufficient.

Two reviewers assessed each domain independently and also assigned an overall grade for each key outcome listed in the framework; they resolved any conflicts through consensus discussion. If a consensus was not met, the team brought in a third party to settle the conflict. In the key points section we present the SOE for each comparison and overarching outcome (e.g., mental health and behavior) as defined by the KQs. We then explain the SOE grade in the detailed synthesis and also provide a table summarizing the SOE grading.

## Applicability

We assessed the applicability both of individual studies and of the body of evidence.172 For individual studies, we examined conditions that may limit applicability based on the PICOTS structure. Examples of characteristics examined include:

Population
- Narrow eligibility criteria, or exclusion of patients with comorbidities.
- Large differences between the demographics of the study population and community patients.

Intervention
- Intensity and delivery of interventions that may not be feasible for routine use.
- Highly selected intervention team or level of training/proficiency not widely available.

Comparators
- Comparison group does not represent an available alternative treatment.

Such conditions may be associated with heterogeneity of treatment effect and the ability to generalize the effectiveness of an intervention to use in everyday practice. We abstracted key characteristics of applicability into evidence tables.

During data synthesis, we assessed the applicability of the body of evidence using the abstracted characteristics. KQ 4 includes a detailed analysis of intervention efficacy in population subgroups.

## Peer Review and Public Commentary

Experts in children’s mental health, specifically psychosocial development, maltreatment exposure, and evidence-based interventions, were invited to provide external peer review of this CER. AHRQ and an associate editor also provided comments. The draft report was posted on the AHRQ Web site for 4 weeks to elicit public comment. We responded to all reviewer comments and noted any resulting revisions to the text in the “Disposition of Comments Report.” This report will be made available 3 months after the final CER is the posted on the AHRQ Web site.