# Introduction

## Background

Exposure to abuse and/or neglect in childhood has serious adverse consequences across the lifespan, including increased risk of emotional and behavioral disturbances, delinquency, violent crime, and chronic disease.1–7 Because a primary caregiver (i.e., parent or other family member serving in this role) is the source of psychological harm, child maltreatment violates the child’s fundamental need for a sense of security, trust, and meaning in the world.8–12 As such, maltreatment represents severe disruption of the parent-child relationship, frequently enduring, that can cause prolonged high levels of stress that overwhelm the child’s capacity for effective coping.13–15 For children who are removed from the home and placed in out-of-home care, separation from and loss of the primary caregiver can exert its own toxic stress that compound the original insult of the abuse or neglect. The unrelenting chronic stress associated with severe and repeated maltreatment has been shown to trigger a cascade of maladaptive physiological and psychological responses, propelling the child along a trajectory of accumulating problems that can ultimately lead to the wide-ranging and persistent pathologies documented in the scientific literature.9,13,16–19

The current comparative effectiveness review (CER)20 on the topic of child maltreatment is the first in a two-part series focusing on interventions that address child exposure to maltreatment and other traumatic experiences. The second review in the series focuses on interventions with children exposed to traumatic events other than maltreatment or family violence; these include terrorism, community violence, war, school violence, natural disasters, medical trauma, and death of a loved one. Both reviews were carried out under the auspices of the Agency for Healthcare Research and Quality’s Effective Health Care Program, the goal of which is to improve the quality, effectiveness, and efficiency of healthcare delivery21 with rigorous and transparent systematic reviews. As such, this review was undertaken to provide stakeholders with a comprehensive review of the available comparative research in the field of child maltreatment. We acknowledge that the rigorous approach specified for a CER limited the range of interventions that could be included. In this regard, readers may be surprised to find that several approaches relevant to current practice in the trauma field are not represented. Thus, we advise readers to be cautious in drawing conclusions with regard to recommending specific approaches. While the review does illuminate the relative strength of evidence based on the comparative research that is presently available, its central purpose is to identify critical areas to address in future intervention research with maltreated children.

The topic of child maltreatment necessitated its own review, separate from a consideration of other types of trauma, for two key reasons that pertain to clinical heterogeneity. First, maltreatment presents a different clinical scenario than other types of traumatic exposure, as the interpersonal nature of the traumatic experience can result in different clinical presentations, system responses (e.g., child protective services), and intervention approaches. The critical differentiating feature of maltreatment compared with other traumatic exposures is the subversion of parenting and family as the source of protection and sanctuary. When the maltreating parent violates these fundamental assumptions, children’s sense of security and predictability may give way to terror and hopelessness. Second, children exposed to abuse and neglect are widely heterogeneous in terms of the caregiving context (e.g., maltreated children may live in foster care, in a residential setting, or at home with the offending biological parent), type of maltreatment experienced, nature of the perpetrator (one or both parents, parent’s partner, relative, sibling), severity and nature of symptomatology, and prior and concurrent exposures to other traumatic or stressful conditions, particularly intimate partner (domestic) violence.22–25

We call the reader’s attention to the absence of domestic violence research in this review. As the topic for this CER was refined during the review process, the decision was made to include only studies that specifically target maltreatment, thus omitting studies with a broad focus on family violence or a specific focus on intimate partner or domestic violence. We recognize that exposure to maltreatment and exposure to domestic violence are related epidemiologically,26 such that studies that address maltreatment will de facto include children exposed to domestic violence. Because of this co-occurrence, it can be difficult to determine whether outcomes related to maltreatment and interpersonal violence involve a common or unique clinical pathway. The challenge is complicated further when recognizing that predisposition, prior experience and exposure, and environmental context and responses can represent both points of convergence and divergence. Our primary intent related to the narrowed scope was to limit, to the extent possible, clinical heterogeneity arising from maltreatment as directed toward the child and from domestic violence as directed toward another adult, where the child is a witness and sometimes ancillary victim.

### Definitions

The term child maltreatment is defined variously in the scientific literature and across the many health and human services sectors that address the issue. For this review, we used two sources to define maltreatment: a report from the U.S. Centers for Disease Control and Prevention (CDC) proposing uniform definitions for improved public health surveillance27 and language from the key federal legislation that sets the standards states must incorporate into their statutory definitions, the Child Abuse and Prevention Treatment Act (CAPTA; 42 U.S.C. §5101, as amended by the CAPTA Reauthorization Act of 2010).28 Thus, we define maltreatment as any act or series of acts of commission or omission by a parent (custodial and noncustodial parents) or other caregiver that results in harm, potential for harm, or threat of harm to a child; the harm to a child may or may not be the intended consequence. For this review, we also define neglect as privation or severe social deprivation, as can be the case in institutional care if the child does not have the opportunity to form a close relationship with a primary caregiver.

However, moving from definition to identification in the area of child maltreatment presents a number of thorny challenges. There are two primary ways that children are identified as maltreated: (1) report to the child welfare system, or (2) screening and assessment by another child-serving system (e.g., pediatrics, mental health, schools). A report to Child Protective Services (CPS) may be screened out (i.e., no investigation is conducted), investigated without confirmation of maltreatment, or substantiated (i.e., evidence for maltreatment is strong). Yet even substantiation cannot serve as a sufficient index of maltreatment, as the definitions of maltreatment vary widely across US states and foreign nations. In instances of maltreatment not substantiated, sufficient indicators to affirm maltreatment are lacking yet its unequivocal absence cannot be proven. Moreover, many maltreated children, arguably a majority, are not reported to CPS. A subset of children not reported to CPS may be identified through other child-serving systems, which are also subject to false positive or false negative conclusions owing to varied methods of screening and assessment (with varying degrees of reliability and validity), definitional criteria, and skill with which conclusions are drawn. Not surprisingly, these many factors affecting identification can result in confusion and inaccuracy for researchers, clinicians, and policymakers, leading to inconsistency in the way maltreatment has been operationalized in the scientific literature.

### Incidence and Prevalence

Child maltreatment is a global public health problem affecting high-, middle-, and low-income countries. According to a recent report from the World Health Organization and the International Society for the Prevention of Child Abuse and Neglect,6 international studies have reported high rates of child physical abuse (between 25% to 50% of all children, depending on the country). Global estimates of child sexual abuse are also high: 20 percent of women and 5 percent to 10 percent of men report experiencing sexual abuse during childhood.6 Child welfare agencies in the high-income countries of the United Kingdom, Canada, and Australia report rates of maltreatment among substantiated cases ranging from 34 percent to 60 percent for neglect, 10 percent to 28 percent for physical abuse, and 7 percent to10 percent for sexual abuse.7

In the United States, a nationally representative survey on child exposure to violence conducted in 2008 found that more than 1 in 10 children (10.2%) had experienced some form of maltreatment (including physical abuse, psychological or emotional abuse, and child neglect) during the previous year.29 Nearly 1 in 5 children (18.6%) had been exposed to maltreatment in their lifetimes.30 Important incidence and prevalence data for the United States are also available from investigated reports of maltreatment to state CPS agencies (National Child Abuse and Neglect Data System, NCANDS).31 However, a caveat about the accuracy of these data is warranted: it is generally understood that (a) minimum standards set by federal and state laws for defining abuse and neglect, and (b) misidentification of cases serve to greatly underestimate the true incidence.32 The most recent NCANDS data, for federal fiscal year 2010, indicate that approximately 5.9 million children were involved in 3.3 million referrals to CPS; 2 million referrals were screened in and received a CPS response. Of the nearly 1.8 million reports that received an investigation, 436,321 were found to be substantiated, and 24,976 were found to be indicated (meaning that maltreatment was highly likely despite insufficient evidence to substantiate).31

Among substantiated cases, the most prevalent type of maltreatment was neglect (78.3%) followed by physical abuse (17.6%). Approximately 9 percent of victims experienced sexual abuse and 8 percent suffered psychological maltreatment.31 Infants less than 1 year of age had the highest rate of victimization at 20.6 per 1,000 children. Approximately 34 percent of victimized children were infants and toddlers (0 to 3 years of age); 23.4 percent were 4 to 7 years of age, 18.7 percent were 8 to 11 years of age, and 17.3 percent were 12 to 15 years of age. Victimization was split almost evenly between the sexes, regardless of age group. More than one-third (37.2%) experienced victimization by their mother acting alone, 19.1 percent were maltreated by their father acting alone, and nearly 18.5 percent were maltreated by both parents.31

Regarding race and ethnicity, the majority of children with substantiated maltreatment in 2010 were Caucasian (44.8%), followed by African American (21.9%), and Hispanic (21.4%).31 African American, American Indian or Alaska Native, and children of multiple racial descent had the highest victimization rates (14.6, 11.0, and 12.7 per 1,000 children, respectively). African American children, in particular, are disproportionately represented in the child welfare system relative to their percentage in the general population (approximately 15%). Whether these figures represent actual higher rates of maltreatment among African American children or bias resulting from systematic differential attention to them in CPS referrals, investigation, or service allocation is a matter of considerable debate in this field.33,34

Child maltreatment is multiply determined; the numerous risk factors for child abuse and neglect cut across domains of parent/caregiver, family, child, and environment.6,35,36 At the caregiver level, a major risk factor is the parent’s own history of maltreatment as well as depression, substance abuse, negative ideations about the child, lack of or inaccurate knowledge of normative child development, harsh discipline practices, and being a young/adolescent parent. At the family level, risk factors include single parenting, stress, social isolation, marital conflict, and domestic violence and, at the environmental level, poverty and community violence. Several child attributes that put additional physical and emotional demands on the parent/caregiver are also recognized as risk factors, including young age of the child (younger than 3 years) and child physical, cognitive, and emotional disabilities. Experts generally agree that the unhealed emotional wounds of childhood maltreatment can coalesce with other risk factors to carry maltreatment’s negative effects on parenting forward across generations, although rates and patterns of intergenerational maltreatment vary substantially across studies.37–42

### Etiology

A burgeoning knowledge base in psychobiological research is advancing our understanding of the toxic effects of prolonged, severe, and unpredictable stress on brain development and child mental and behavioral outcomes. Exposure to toxic or traumatic stress in the form of maltreatment may alter the developing brain by sensitizing neural pathways and overdeveloping regions of the brain where fear and anxiety responses are activated.43 One specific pathway of effect is dysregulation of the hypothalamic-pituitary-adrenal axis. Specifically, chronic exposure to stressful and arousing events is associated with activation of this axis, which releases a cascade of steroid hormones, including the primary stress hormone cortisol. Excess cortisol production alters children’s baseline for arousal such that even nonthreatening environments stimulate a fear response.44 Dysregulation of neurochemical regulatory processes is especially damaging in the early years of development when neurological structures are undergoing formation (see Gunnar et al., 2006^45^ for a review). In the case of maltreated infants and young children, researchers have found that children in foster care exhibit atypical diurnal cortisol production patterns;46 similarly, research with children exposed to severe social deprivation in institutional care prior to adoption have identified alterations in brain functioning including significantly reduced cortical activity and dysregulation of neuroendocrine systems.47,48 Atypical cortisol production in adults has been found to be associated with conduct disorder, antisocial personality disorder, depression, and substance abuse.47,49,50

Another critical source of toxic stress contributing to poor mental and behavioral outcomes in this vulnerable population is the experience of repeated disruption in care when children are removed from the home and placed in foster care. Although the majority of children reported to CPS remain living at home with their biological caregiver,51 approximately 254,000 children in the United States enter foster care annually. Foster care is a component of the child welfare system that entails “placement of a child in a substitute home environment when the child’s parents are unable or unwilling to provide appropriate care. It is intended to be a time-limited placement on the way to determining one of the following three permanency plan options: reunification with the biological parent, conversion of the foster home to a legally permanent guardianship or adoption, or placement of the child into another legally permanent family.”52^,p.1404^ Approximately 20 percent of children placed in out-of-home care are removed from their homes because of risks other than maltreatment, per se, that threaten their safety (namely because of a substance-abusing parent, prenatal substance-exposure, or domestic violence). CAPTA allows states wide latitude in their definitions of maltreatment that allow them to make appropriate referrals and develop service plans for the “safe care of the child,” such that states may or may not define prenatal alcohol or drug exposure or parental substance abuse as a category of child abuse or neglect.28 That said, the vast majority of children are removed because of substantiated abuse or neglect.31

Approximately 30 percent of children whom CPS removes from the home are eventually reunified with their prior, often biological, primary caregiver.51,53–55 However, these children are very likely to be removed from the home again. One study that examined re-entry rates in the Multistate Foster Care Data Archive, a longitudinal dataset representing 1.3 million foster children in 12 states, found that the majority (nearly 70%) of children reunified with their primary caregivers re-entered care within a year and that nearly 40 percent of these children were placed again within 90 days.56,57 Another study using this same dataset examining re-entry rates among infants found that the 27 percent who were discharged from foster care eventually returned and that re-entry rates differed by placement type. Specifically, infants placed with relatives and then discharged to relatives were least likely to reenter foster care (11.9%) compared with children discharged to their parent (28.5%) or placed with a traditional foster family (32%).58 A typical child in foster care will experience slightly more than three placement changes over 3 years.54 Children with medical, developmental, and mental health problems are especially likely to be moved from placement to placement.59 This scenario of repeated separation from primary caregivers and the corollary loss of important attachment relationships aggravates the child’s sense of fear, isolation, and betrayal caused by the original insult of maltreatment. Particularly in the earliest years of life, attachment disruption as a result of repeated separations from and loss of important caregivers puts children at risk for socioemotional dysregulation and developmental problems.60,61

Given the variability in children’s maltreatment exposure and experiences related to foster care, it follows that mental and behavioral problems among abused and neglected children vary widely in type and severity of symptoms, which include traumatic stress, depression, anxiety, and behavioral problems. As described earlier, when maltreatment is chronic, cumulative, and prolonged, it may present as a form of complex trauma, a subset of psychological trauma, with potentially profound negative effects on fundamental developmental processes in childhood.8 When children experience unpredictable detachment, neglect, violence, and repeated abandonment in the context of their early caregiving relationship, their sense of self, other, and self in relation to other becomes disturbed when, under normal conditions, it should be becoming consolidated.8,14,18,62 The disruption of healthy attachment in turn impairs the child’s capacity for emotional regulation, empathy, and coping.14,15,60,61

These early impairments can lead to chronic dysregulation of affective experience, including mood disorders, as well as under- and overcontrolled behavior patterns.63 Yet most children experiencing complex trauma do not meet diagnostic criteria for post-traumatic stress disorder (PTSD), in part because exposure to maltreatment and traumatic loss associated with separation from caregivers do not necessarily meet the American Psychological Association’s Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition, Text Revision (DSM-IV-TR) criteria for a traumatic event. Diagnosis of PTSD and other mental or behavioral disorders is particularly complicated for young children who, in the context of rapid development and maturation, seldom meet full standard or diagnostic criteria. Rather, they often exhibit symptom clusters that can be characterized in terms of alternate diagnostic systems (e.g., 0 to 3 Diagnostic Classification64) that address developmentally specific clinical presentations that can be precursors to later poor outcomes throughout childhood and adolescence and into adulthood. Recently, a Developmental Trauma Disorders Task Force of the National Child Traumatic Stress Network has begun to conceptualize a new diagnosis, developmental trauma disorder, to address with greater precision the developmental, psychological, biological, and social factors that serve as both causes and outcomes of child maltreatment.65 Although consensus is lacking on this emerging diagnosis, attention to children’s complex trauma histories in diagnostic assessment and effective treatment is a central topic in children’s clinical care.63,65

### Disease Burden

The National Survey on Child and Adolescent Well-Being (NSCAW) provides key indicators of child well-being among children investigated for maltreatment in the United States, tracking the extent of mental and behavioral health needs in this population over time.51,66 Among children who come in contact with CPS, 48 percent show signs of an emotional or behavioral problem and more than 30 percent of children birth to 3 years have developmental delays.67 However, only 25 percent of the NSCAW population receives any specialty intervention to address their developmental and other special needs.68,69 Data from the National Survey of Adoptive Parents (NSAP) finds that children adopted from foster care have similarly high morbidity rates including attention deficit hyperactivity disorder (38%) and behavior and conduct problems (25%).70 Research with international adoptees has found that children who experienced severe social deprivation in institutional care prior to adoption have more behavioral and social problems than international adoptees without such preadoption adversity.71 One study found that children adopted from countries where the conditions of large-group institutional care put children at risk for social deprivation (such as Romania) were 2 to 2.5 times more likely to experience disability, including impaired functioning due to emotional impairment, compared with children adopted domestically.72

Child maltreatment also represents a significant economic burden to society, cutting across many different service sectors including child welfare, health care, special education, and criminal justice. A recent study provides estimates of the aggregate lifetime costs of fatal and nonfatal child maltreatment. In addition to child welfare, special education, and criminal justice costs, the authors factored both short- and long-term health care costs as well as lost productivity into their estimations. Using incidence data from 2008, the researchers estimated that the total lifetime costs (in 2010 dollars) of nonfatal child maltreatment for CPS-investigated cases (that is, substantiated cases of child maltreatment) are $122 billion; in fatal cases, estimated costs (also based on CPS data) are $2 billion.32 These estimates reflect approximately $25 billion in short-and long-term health care costs, $84 billion in productivity losses, $4 billion in child welfare costs, $4 billion in criminal justice costs, and $5 billion in special education costs.32 Another dimension of societal cost burden is the impact on Medicaid, as children in foster care account for a disproportionate share of Medicaid expenditures relative to their proportion of Medicaid enrollment. Much of this disparity results from foster children’s disproportionate receipt of mental health services. Youth in foster care use Medicaid-reimbursed mental health services at a rate 8 to 15 times higher than other Medicaid-eligible youth.73–76

## Intervention Strategies

Interventions represented in the literature that met our criteria for this review focus on the clinical needs of the child and/or the child-caregiver relationship to improve child well-being and positive child welfare outcomes. Relevant interventions include both psychosocial or pharmacological interventions; however, no eligible studies addressing pharmacotherapy were identified for inclusion. Although there are many interventions in the field that aim to improve the system of care for maltreated children and families, broadly defined service delivery strategies are not included in this review. These encompass an array of approaches such as differential response, respite care, case management procedures, financial support, subsidized guardianship, and court improvement strategies. We recognize system-level approaches are highly relevant to the child welfare system; however, their inclusion would have stretched the limits of the current review in terms of both scope and generalizability. This issue is addressed also in the Methods chapter when we describe the exclusion and inclusion criteria for studies included in this review.

Intervention research with maltreated children is challenging due to the complexity of their clinical needs. As discussed earlier, maltreatment is seldom an isolated event but is cumulative and tends to co-occur with multiple traumatic exposures; given this clinical picture, maltreated children often present with multiple mental health issues. A subset of interventions included in this review comprise treatment components specifically designed to address traumatic stress and other mental and behavioral health symptoms attributable to a particular exposure (e.g., sexual or physical abuse), although these interventions are commonly applied across a wide range of symptoms or symptom severity. However, the majority of intervention studies in this review target children based only on exposure rather than the presence, type, or degree of symptomatology.

The interventions included in this review are diverse in theoretical basis, target (child, parent, parent and child, family), modality (e.g., individual, dyadic, group format), setting (clinic, community agency, and/or home), intervention strategies, intensity, and outcomes. Several interventions are adaptations of or derived from approaches designed for other populations. By adaptation, we refer to approaches that in their adaptation and/or augmentation maintain the integrity of the original intervention (i.e., with minor modifications to the curriculum or manual and/or supplemental components). By derivation, we refer to approaches wherein the authors do not specify the degree to which the original model was implemented and/or the extent to which core components of the standard approach were modified. For this review, we categorized the interventions as parenting, trauma-focused treatments that are predominantly child-focused, or enhanced foster care approaches. In the section that follows, we describe each of these intervention types and provide a table defining their key features.

### Parenting Interventions

The majority of interventions eligible for inclusion in this review are parent-mediated approaches; that is, their primary aim is to modify parenting behavior and thereby improve child outcomes. Parenting interventions with maltreating parents target core caregiver- and/or family-level risk factors associated with child well-being including: increasing the caregiver’s attunement, sensitivity, and responsiveness to the child’s needs; improving negative attitudes toward the child and/or the role of parenting; teaching positive discipline techniques to use in managing challenging behavior instead of corporal punishment; improving family functioning; and/or addressing safety risks in the home. Parenting interventions with maltreating families also commonly focus on reducing the parent’s stress and promoting the parent’s emotional well-being. Interventions also commonly include a component of practical assistance (e.g., assistance with food insecurity or substandard housing) or support to ameliorate stressful circumstances for the family.

When interventions are directed at the foster or kin caregiver, the focus is on increasing the caregiver’s understanding of the effects of abuse and neglect on children; empathy towards the child; and capacity to provide nurturing, responsive, and developmentally appropriate care. Many parenting interventions with foster or kinship parents are directed at supporting the caregiver in effectively managing child behavioral problems and reducing the caregiver’s stress related to the behavioral challenges. The interrelated goals of these interventions are to improve child functioning, avoid a failed out-of-home placement which results in a negative placement change (e.g., the child being moved to a new foster care placement, a more restrictive environment such as psychiatric care or juvenile detention center, or child runaways), and expedite a positive permanent placement for the child. Treatment plans often include concurrent planning that simultaneously aims to support the child’s relationship with the biological and foster caregiver in the interest of a positive exit from foster care and timely permanent placement (that is, either reunification with the biological parent or other relative or adoption).

Table 1 outlines key features of the parenting interventions addressed in the report.

Table 1 Parenting interventions: Key features

Intervention | Brief Description
Attachment and Biobehavioral Catch-up77–85 | - Home-based approach to help foster parents provide nurturing, sensitive care that promotes child regulatory capabilities and attachment formation; - Employs manualized parenting curriculum, flexibility in responding to current issues, and use of videotapes of parent-child interaction to illuminate child cues and strengths in the relationship; - 10, 1-hour weekly home visits with child and foster parent or child and biological caregiver together; - Children ages birth to 5 years
Attachment-based Intervention86 | - Home-based approach loosely derived from Attachment and Biobehavioral Catch-up and other attachment-focused interventions; focuses on maternal sensitivity to child emotional and behavioral cues to support secure attachment; - Employs individualized parent-child interaction support, video feedback, and discussion of attachment/emotion regulation-related themes; - 8, 1.5-hour weekly home visits; - Children ages 1 to 5 years
Child-Parent Psychotherapy87,88 | - Dyadic home- or clinic-based approach; relationship-based dyadic psychotherapy as developed and manualized by Cicchetti and colleagues, with focus on supporting formation of and repairing the parent-child attachment relationship; - Based on infant mental health principles; attachment and developmental psychopathology theory; - Employs the parent-child relationship as the “port of entry” for therapeutic work; - 50, approximately 1-hour weekly home visits with child and caregiver together; - Children ages 12 months to 5 years
Incredible Years Adaptation89 | - Incredible Years90 adapted for use with foster and biological parent pairs to address placement issues such as safety and attachment; supplemented with a coparenting component based on structural family systems theory; focuses on supporting a positive, nonconflicted relationship between caregivers and promotes a caregiving environment sensitive to the child’s needs; - 12, 2-hour weekly parent group sessions for biological-foster parent pairs, supplemented weekly sessions (duration not specified) with individual families (biological and foster parent pair and target child); - Children ages 3 to 10 years
Keeping Foster Parents Trained and Supported91,92 | - Didactic group-based parent training approach to increase foster and kin parents’ positive reinforcement relative to discipline, based on the foster parent training component in the Multidimensional Treatment Foster Care model (see Table 2 below); focuses on positive discipline strategies; - Delivered by paraprofessionals; employs role plays, videotapes, homework practice; - Employs didactic training and group discussion related to primary curriculum concepts; - 16, 1.5-hour weekly parent group sessions, with 15-minute didactic presentations by facilitators then group discussion related to primary curriculum concepts; - Children ages 5 to 12 years
Nurse Home Visitation Intervention93 | - Home-visiting approach; focuses on intensive family support, parent education, and referrals to health and social services; derived from Olds and colleagues preventive intervention but authors developed their own manual94; - Employs mutual problem identification, goal setting, and problem-solving strategies; supporting positive parent-child interaction; - 6 months of 1.5-hour weekly home visits with parent, then visits every 2 weeks for 6 months, then monthly visits for 12 months; - Children ages birth to 13 years
Parent-Child Interaction Therapy Adaptation95–97 | - Standard parent-child interaction therapy98 adapted for abusive or neglectful parents; based on social learning and attachment theory; includes a motivational intervention orientation; - Three phases: (1) motivational intervention (orientation phase); (2) child-directed interaction phase during which parents develop child-centered interaction skills; (3) parent-directed interaction phase during which effective discipline skills are the focus; - Employs live parent-child skills practice/rehearsal, with live coaching by the therapist (immediate feedback from therapist from observation room to parent via wireless earphone); coaching driven by behavioral principles such as modeling, reinforcement, and selective attending to shape parents’ behaviors; - Motivational intervention: 6 clinic-based parent group sessions/therapeutic sessions: 12 to 14 approximately 1-hour clinic-based individual sessions with parent and child together; - Children ages 4 to 12 years
SafeCare100 | - Home-based multifaceted parent services to prevent and treat child abuse and neglect, formerly known as Project 12-Ways; - Modules address parent-child or parent-infant interaction, parental stress, and home safety risks including behavior management, problem solving, infant and child health and nutrition, and social support.; - Home visits at least weekly for 6 months (duration not specified); - Children ages 0 to 12 years
Videotape Intervention101 | - Brief videotape intervention informed by social learning theory to increase supportive maternal behaviors following sexual abuse of a child and the child’s subsequent medical evaluation; - Videotape provides specific information about short- and long-term psychological and behavioral effects commonly seen in sexually abused children, common reactions of parents, and importance of how parent respond to children; suggested responses presented as “BRAVE To Tell” representing five specific supportive behavioral approaches for interacting with child; - 22-minute videotape presented to parents during child’s forensic examination; - Children ages 4 to 12 years

Note: This table only includes interventions that are included in the Results chapter of this review. There are many other interventions that are commonly used with this population; however, we did not identify any comparative studies with low or medium risk of bias that empirically assessed these interventions. Descriptions based on information provided by the authors in the included studies, the intervention Web sites (when available), and several registries of programs and practices.102–106

### Trauma-Focused Treatments

Several interventions eligible for inclusion in this review were designed explicitly to target children’s trauma and/or other mental and behavioral health symptoms. Most of these interventions also include a caregiver-directed component in the form of sessions that occur either alone or jointly with the child. Trauma-focused treatments include trauma-specific treatment strategies such as assisting the child to develop a trauma narrative, cognitive reframing and coping skills related to the trauma, and gradual exposure and mastery of traumatic reminders. Table 2 outlines key features of the trauma-focused treatments addressed in the report.

Table 2 Trauma-focused treatments: Key features

Treatment | Brief Description
Combined Parent-Child Cognitive Behavioral Therapy107 | - Cognitive behavioral treatment approach for physically abusive parents, incorporates components of trauma-focused cognitive behavioral therapy108,109 and abuse-focused cognitive behavioral therapy110,111; - Treatment components: child gradual exposure/construction of a trauma narrative (child group), parent abuse clarification process (parent group), and joint trauma narrative/abuse clarification and negotiation/rehearsal of safety plan (parent-child group); also incorporates psychoeducation and parent skills training (e.g., cognitive-coping, anger management, and problem-solving skills); - Employs modeling, role plays, behavioral rehearsal, praise, corrective feedback, and homework assignments; - 16, 2-hour weekly group sessions (over 16 to 20 week period); - Children ages 7 to 13 years
Eye Movement Desensitization and Reprocessing112 | - Information-processing treatment; addresses the experiential contributors of a wide range of pathologies; attends to past experiences and current situations that trigger dysfunctional emotions, beliefs, and sensations; - Contains elements of many psychotherapies in structured protocols, including psychodynamic, cognitive behavioral, interpersonal, experiential, and body-centered therapies; - Treatment components: 8 phases using various procedures including “dual stimulation” in which client, using either bilateral eye movements, tones, or taps, attends momentarily to past memories, present triggers, or anticipated future experiences while simultaneously focusing on a set of external stimulus; - 12 or fewer 30- to 45-minute sessions; - Children ages 3 years and older
Group Psychotherapy for Sexually Abused Girls113 | - Psychoeducational approach with symptomatic sexually abused girls; includes generic and sexual abuse-specific components; social-work support group for caregivers; - Treatment components: engaging girls and their caregivers, maintaining the therapeutic alliance, managing anxieties and appropriately handling postabuse and current concerns; - Up to 18, 50-minute group sessions (girls), with concurrent parent group sessions every 2 weeks; - Children ages 6 years and older
Group Treatment Program for Sexual Abuse114 | - Group psychotherapy for sexual-abuse victims; - Treatment components: discussing the abuse in a supportive peer environment, increasing feelings of self-worth, providing psychoeducation to reduce future victimization, ameliorating future psychological problems, providing children with appropriate adult role models, and providing support regarding court participation; - Weekly meetings for 6 months; children spend several cycles of the group, spending about 9 to 12 months in treatment; - Children ages 9 to 12 years
Trauma-Focused Cognitive Behavioral Therapy108,115,116 | - Cognitive behavioral approach for reducing the child’s maladaptive responses to exposure to a traumatic event (namely sexual abuse); intended for children who have significant behavioral or emotional problems related to traumatic life events; - Treatment components: skills in expressing feeling; recognizing the relationships between thoughts, feelings, and behaviors; training in coping skills; gradual exposure (also referred to as creating the child’s trauma narrative); cognitive processing of the abuse experience(s); joint child-parent sessions; psychoeducation about child sexual abuse and body safety; parent behavior management support; - 12 to 16 weekly, 1- to 1.5-hour sessions with individual child, individual parent, and conjoint sessions with child and parent together, typically provided in outpatient clinics but also used in hospital, group home, school, community, and in-home settings; - Children ages 3 to 18 years

Note: This table only includes interventions that are included in the Results chapter of this review. There are many other interventions that are commonly used with this population; however, we did not identify any comparative studies with low or medium risk of bias that empirically assessed these interventions. Descriptions based on information provided by the authors in the included studies, the intervention Web sites (when available), and several registries of programs and practices.102–106

### Enhanced Foster Care Interventions

This review includes three interventions that provide a comprehensive set of intervention and supportive services for children in foster care. These approaches include one that is solely child-focused, one that is directed at both the child and the foster parent, and two that are multimodal in nature (i.e., comprising multiple clinical intervention components including individualized treatment such as medication management). Table 3 outlines key features of the enhanced foster care interventions addressed in the report.

Table 3 Enhanced foster care interventions: Key features

Interventions | Brief Description
Bucharest Early Intervention Project117–129 | - Specialized social work foster care network providing infant mental health-informed counseling and parenting support to foster parents caring for institutionalized infants and toddlers in Bucharest, Romania; adapted from New Orleans Intervention approach130; - Intervention delivered via a team of social workers trained extensively in basic principles of infant mental health, including building attachment relationships, understanding children’s postinstitutional adjustment, and managing common behavior problems; - Intervention components: frequent in-home monitoring of child adjustment progress and problems; developmental interventions, particularly in the area of communicative behavior; behavioral intervention (including support and developmentally informed guidance regarding child behavior and emotional problems); service referrals; foster parent support group; - Home visit every 10 to 14 days reduced to every 3 months after a year, with frequent phone contact throughout intervention period; - Children ages 6 months to 3 years
Fostering Healthy Futures131,132 | - Two-component approach comprising skills groups and mentoring; designed to foster resilience through the promotion of adaptive functioning in maltreated children in out-of-home care; - Employs cognitive-behavioral skills group activities with process-oriented materials; curriculum was based on materials from other programs;133–135 mentoring component is individually tailored, targets creating empowering relationships with children, linking/supporting children in needed services receipt, helping children generalize skills learned in group to real world with weekly activities, engaging children in extracurricular, educational, social, cultural, and recreational activities, and promoting positive future orientation; - 30, 1.5-hour weekly sessions plus up to 4 hours per week of individual meeting with mentor; - Children ages 9 to 11 years
Middle School Success136,137 | - Didactic, highly structured brief (summer) intervention for girls in foster care to build self-efficacy skills and reduce internalizing and externalizing problems; separate component for foster parents to facilitate placement stability by improving parenting skills; - Youth intervention components: setting personal goals; establishing and maintaining positive relationships with peers and adults; developing effective decision-making and problem-solving strategies; developing support systems for reaching goals; and modeling, practicing, and reinforcing adaptive behaviors; - Youth intervention employs role plays, games, or activities for practicing new skills; discussions; and ceremony during final session for participants to proclaim goals and commitments; - Foster parent intervention focuses on establishing and maintaining stability in the foster home, preparing girls for the start of middle school, and preventing early adjustment problems during transition to middle school; foster parents taught to use a behavioral reinforcement system to encourage adaptive behaviors across home, school, and community setting via home practice assignments; - 6 youth group sessions, meeting twice weekly for 3 weeks (high staff: participant ratio of 1:2 to allow for individual attention, one-to-one modeling/practicing of new skills, and frequent reinforcement of positive behaviors) and 6 concurrent parent group sessions; - Throughout first year of middle school, 2-hour weekly session was provided to both foster parents and girls to provide follow-up training and support; - Girls ages 10 to 12 years
Muiltidimensional Treatment Foster Care for Preschoolers138–144 | - Family-based intervention directed at child, foster care provider, and permanent placement resource (birth parents; adoptive relatives or nonrelatives); delivered by a treatment team; adaptation of the Multidimensional Treatment Foster Care behavioral treatment alternative for adolescents in residential settings; - Intervention components: (1) intensive preplacement foster parent training, foster parent postplacement support and supervision from a foster parent consultant via daily telephone contact, weekly foster parent support group meetings, and 24-hour on-call crisis intervention; (2) child services from a behavioral specialist working in preschool or day care and home-based settings and participation in weekly therapeutic playgroup sessions where child behavioral, social, and developmental progress is monitored and addressed; (3) necessary medication management to address symptoms of attention deficit hyperactivity disorder, anxiety, and other disorders; (4) family therapy to reinforce and facilitate generalization of new parenting strategies across a range of contexts; - 12-hour intensive training for foster parents; children/families typically receive services for 6 to 9 months; - Children ages 3 to 6 years
New Orleans Intervention for Maltreated Children in Foster Care130 | - Partnership between university faculty with expertise in infant mental health and child welfare agency to address the developmental and mental health needs of children younger than 48 months placed in foster care for abuse or neglect in New Orleans, Louisiana; - Directed at the child and birth and foster families; delivered by a multidisciplinary treatment team specializing in infant mental health; - Intervention components: (1) intensive assessment, comprising an average of 15 to 20 hours of face-to-face contact with children and their important caregivers and contexts (including home- and clinic-based observations, standardized procedures and naturalistic observations, structured and unstructured interviews, and self-report measures); culminates in a case conference for involved professionals, a feedback sessions for parents, and a letter to the juvenile court detailing specific findings and recommendations; (2) comprehensive, multimodal, individualized treatment to meet the goals defined in the court-ordered case plan for the family, which often includes individual psychotherapy with parents, dyadic psychotherapy with parents and young children, medication, and crisis intervention; - Children birth to 4 years

Note: This table only includes interventions that are included in the Results chapter of this review. There are many other interventions that are commonly used with this population; however, we did not identify any comparative studies with low or medium risk of bias that empirically assessed these interventions. Descriptions based on information provided by the authors in the included studies, the intervention Web sites (when available), and several registries of programs and practices.102–106

## Scope and Key Questions

### Scope of This Review

This review provides a critical analysis and synthesis of the comparative efficacy and effectiveness of interventions (psychosocial and pharmacological) for children ages birth to 14 years that address child well-being and/or promote positive child welfare outcomes (safety, placement stability, and permanency). The review also examines (1) how interventions with different characteristics (modality, theoretical orientation, setting) compare in improving child outcomes, (2) how interventions compare in terms of treatment engagement and retention, and (3) adverse events associated with the interventions reviewed. Our intention was to balance the concerns of real-world practice and policy while at the same time carefully limiting heterogeneity in the studies we reviewed so as to maximize the generalizability of the findings.

Several peer-reviewed systematic reviews have been conducted on interventions with maltreated children; however, the reviews available to date each represent only a cross-section or a subset of the outcome of interest covered in this comprehensive CER. Examples include a meta-analysis of the effects of psychotherapy with sexually abused children and adolescents145 and a meta-analysis of parent training programs to reduce parents’ risk of abusing a child.146 A Cochrane review is available on behavioral and cognitive behavioral training interventions with foster caregivers in the management of difficult behavior;147 another Cochrane review, in the protocol stage as of 2012, will assess the effectiveness of family therapy for improving outcomes for children who have experienced physical abuse and preventing recurrence of abuse.148 A relevant systematic review is also available from the Social Care Institute for Excellence of the National Institute for Health and Clinical Excellence (NICE) examining the effectiveness of training and support for foster caregivers and other professionals on the physical and emotional health and well-being of children and adolescents in foster care in the United Kingdom.149

In 2010, the Office of Planning, Research and Evaluation (OPRE) in the U.S. Administration for Children and Families (ACF) made available the results of a systematic review examining the effectiveness of home visiting models serving pregnant women or families with children from birth to age 5 years.150 Although reduction in child maltreatment was an outcome domain in the ACF/OPRE review, its focus on secondary prevention with at-risk families and narrow age range minimized the overlap with this review, because we target clinical interventions with children ages 0 to 14 years old already exposed to abuse or neglect or with known involvement with CPS. Other reviews with limited overlap because of their focus on preventive intervention include a recent systematic review by researchers at the World Health Organization151 and by the Preventing Violence Across the Lifespan Research Network (PreVAiL).152,153

Additionally, several government and nonprofit organizations have developed highly regarded and widely used evidence-based registries and informational resources in this field. These sources help guide clinical and other practitioners, funders, and policymakers in selecting and supporting effective interventions to mitigate risk and to address the mental and behavioral health needs of children exposed to maltreatment. Examples include the National Child Traumatic Stress Network’s library of Empirically Supported Treatments and Promising Practices,102 the National Registry of Evidence-based Programs and Practices (made available by the Substance Abuse and Mental Health Services Administration),103 and the California Evidence-based Clearinghouse for Child Welfare.106 Other seminal resources include a report on evidence-based practices for child abuse treatment by the Chadwick Center on Children and Families154 and a set of guidelines for child physical and sexual abuse treatment from the Department of Justice.155 This review will further help clinicians and other decisionmakers by providing a next step in understanding effective treatments with a comprehensive, systematic review of the comparative benefits and harms of evidence-based intervention with children exposed to maltreatment.

We used a population, intervention, comparators, outcomes, timing, and settings (PICOTS) framework to define these elements for the review (see Methods for a complete description of the PICOTS for this review). Specificity in defining each element in the PICOTS framework is a critical step in ensuring that a systematic review yields generalizable findings. The chief concern in defining the PICOTS with high specificity is to address the problem of clinical heterogeneity or “the variation in study population characteristics, coexisting conditions, cointerventions, and outcomes evaluated across studies included in a systematic review that may influence or modify the magnitude of the intervention measure of effect.”156^,p.6,157^ The complexity of maltreatment exposure presented particular challenges related to clinical heterogeneity for this review, and this problem ultimately necessitated limitations in scope.

Thus, we focus on (1) children who represent a range of symptom expression or children for whom symptomatology is not reported; (2) diverse exposure experiences in type, severity, developmental timing and chronicity, as well as children whose specific maltreatment experiences are not reported; and (3) different caregiving contexts (e.g., living at home with the biological parent who perpetrated the abuse or neglect or living in out-of-home care). Given these broad inclusion criteria, the EPC team imposed an age cutoff of 14 years so as to exclude from the population youth whose developmental capabilities and needs are distinct from those of younger children. Additionally, due to concerns about heterogeneity, we elected to exclude intervention studies that focused on primary or secondary prevention (i.e., study populations that were not currently involved with child welfare or where the description of the study population was too vague to make a determination regarding maltreatment exposure).

Defining and classifying relevant interventions for this review also presented major challenges because of their diversity. These include clinical treatments such as psychotherapy or psychosocial approaches with the child, parent, and/or child-parent together and pharmacotherapy; training programs with biological or foster parents delivered through the child welfare system; and service delivery approaches or strategies at the system level to improve the quality of care for children and their caregivers and families. Through the literature review process, we determined that system- or service-delivery level approaches were qualitatively distinct from discrete clinical interventions in terms of the degree of specificity regarding core treatment components and their implementation and specificity about the population. Ultimately the EPC determined that including both clinical and system- or service-delivery level studies was beyond the scope of a single review.

### Need for Comparative Effectiveness of Interventions for Maltreated Children

Currently no national guidelines inform the selection of interventions for improving child well-being and child welfare outcomes for children who have been exposed to maltreatment. Although numerous resources and evidence-based registries exist that caregivers, clinicians, policymakers, and other decisionmakers can turn to for guidance on selecting and supporting treatments for maltreated children, differences in the rating schemas and approaches across these resources can present conflicting information that is confusing for consumers. Because consumers may not be aware of all resources available in the field or of important differences across the available resources, their decisions may not be fully informed.

Absent clear guidance on efficacious or effective treatment interventions with this population, at least one controversial approach with the potential to cause serious harm has been publicized and disseminated. “Holding” or containment therapy is an alternative child mental health therapy intended to treat attachment disorders; it has resulted in at least six documented fatalities.158 In 2006, the American Professional Society on the Abuse of Children published a task force report critical of coercive practices in therapy promoted as forms of attachment therapy.158 In April 2007, the Association for Treatment and Training in the Attachment of Children formally adopted a white paper stating its unequivocal opposition to the use of coercive practices in therapy, while advocating attunement, sensitivity, and regulation-focused techniques.159

### Key Questions

1. What is the comparative effectiveness of interventions with children exposed to maltreatment for promoting child well-being? Specifically:
  a. Mental and behavioral health
  b. Healthy caregiver-child relationship (e.g., secure attachment; increased caregiver responsivity and sensitivity; positive parental attitudes toward childrearing; positive parental perceptions of the child and causal attributions about the child’s behavior; decreased negative parent-child interactions; increased family functioning)
  c. Healthy development (e.g., cognitive, language, physical maturation)
  d. School-based functioning (e.g., grade retention, disciplinary referrals, attendance)
2. What is the comparative effectiveness of interventions with children exposed to maltreatment for promoting child welfare outcomes? Specifically:
  a. Safety (i.e., prevention of maltreatment recurrence)
  b. Placement stability
  c. Permanency
3. Among the interventions under review, how do interventions with particular characteristics compare in improving child outcomes. Intervention characteristics may include:
  a. Modality (i.e., individual, dyadic, group, family-based)
  b. Theoretical orientation (e.g., cognitive behavioral, psychodynamic)
  c. Type of setting (i.e., specialty or nonspecialty service-delivery settings)
4. How do interventions compare for improving child outcomes within population subgroups? Population subgroups comprise the following:
  a. Child subgroups
    i. Age and other sociodemographic subgroups (e.g., race, ethnicity, sex)
    ii. Type of maltreatment exposure (e.g., neglect, physical abuse, sexual abuse)
    iii. Severity of maltreatment exposure
    iv. Presence of mental or behavioral health problems (e.g., complex traumatic stress disorders, serious emotional disturbance) or other special needs (e.g., failure to thrive, prenatal substance exposure)
  b. Caregiver subgroups
    i. Primary caregiving context: biological parent; foster, kin (relative), or adoptive caregivers; residential program or group home)
    ii. Presence of mental health problems, substance abuse, or domestic violence
    iii. Sociodemographic groups (e.g., age, race, ethnicity, sex)
5. What is the comparative effectiveness of interventions with children exposed to maltreatment for engaging children and/or caregivers in treatment (e.g., treatment adherence, treatment withdrawal)?
6. What adverse events are associated with interventions for children exposed to maltreatment (e.g., retraumatization, caregiver distress)?

### Analytic Framework

Figure 1 presents the analytical framework for this review. This framework is a conceptual model that guided the analyses for this CER; key questions (KQs) are noted as appropriate to the linkages in this model.

Figure 1 Analytic framework for comparative effectiveness of interventions for child maltreatment

^a^ Population may include the child’s primary caregiver(s) when the intervention targets the caregiving context.

Abbreviation: KQ = key question

Figure 1. Analytic Framework. Figure 1 depicts the analytic framework for the comparative effectiveness of interventions for children exposed to maltreatment. The populations included in this review are children and adolescents who have been exposed to maltreatment and their caregivers when applicable. Key Question 1 will assess the effectiveness of the interventions in improve improving child outcomes, specifically, mental and behavioral health, a healthy caregiver-child relationship, healthy development, and school-based functioning. Key Question 2 assesses child welfare outcomes, specifically, safety, placement stability, and permanency. The effectiveness of interventions in population subgroups will be compared in Key Question 4, while differences in efficacy by intervention characteristics will be reviewed in Key Question 3. Key Question 5 reviews the evidence on treatment adherence, and Key Question 6 assesses adverse events during treatment.

The populations included in this review are children and young adolescents who have been exposed to maltreatment. Caregivers are also included in the population when the intervention targets the parent or includes a caregiver-directed component. KQ 1 assesses the effectiveness of the interventions reviewed in improving child outcomes, specifically mental and behavioral health and other aspects of healthy development such as physical, language, and cognitive development; the quality of the caregiver-child relationship; and school-based functioning. KQ 2 assesses outcomes that are of specific interest to the child welfare system: safety (i.e., maltreatment recurrence), placement stability while in out-of-home care, and permanency (e.g., successful permanent placement; time to permanency). The efficacy of interventions in important population subgroups is compared in KQ 4, while differences in efficacy by intervention characteristics such as theoretical orientation and modality are reviewed in KQ 3. KQ 5 assesses the evidence on treatment adherence, and KQ 6 reviews the literature on adverse events associated with treatment.

For the purpose of this review, caregiver-level outcomes (e.g., parenting attitudes, parenting practices, family functioning, and caregiver emotional well-being) are treated not as mediators of child outcomes but as indicators of the quality of the caregiver-child relationship outcome. We treat caregiver outcomes as such because the quality of the caregiver-child relationship is inherent to child well-being;10 additionally, analyzing mediating and moderating results was beyond the scope of this CER.

### Organization of This Report

The remainder of this review describes our methods in detail, documents our results, and provides a discussion of our findings and recommendations for filling important research gaps. Appendixes provide details of the search strategy (Appendix A), forms used for review (Appendix B), studies excluded at the full-text review stage (Appendix C), risk of bias ratings (Appendix D), and comprehensive evidence tables (Appendix E).